# CHAPTER 8 REFERENCES

Abbasi SA, Nipaney PC, Soni R. 1989. Environmental status of cobalt and its microdetermination with 7-nitroso-8-hyrdoxyquinoline-5-sulfonic acid in waters, aquatic weeds and animal tissues. Anal Lett 22(1):225–235. 10.1080/00032718908051196.
Abdel-Daim MM, Khalil SR, Awad A, 2020. Ethanolic extract of Moringa oleifera leaves influences NF-κB signaling pathway to restore kidney tissue from cobalt-mediated oxidative injury and inflammation in rats. Nutrients 12(4):1031. 10.3390/nu12041031.32283757
Abraham JL, Hunt A. 1995. Environmental contamination by cobalt in the vicinity of a cemented tungsten carbide tool grinding plant. Environ Res 69(1):67–74. 10.1006/enrs.1995.1026.7588496
Afridi HI, Kazi TG, Kazi NG, 2009. Evaluation of arsenic, cobalt, copper and manganese in biological samples of steel mill workers by electrothermal atomic absorption spectrometry. Toxicol Ind Health 25(1):59–69. 10.1177/0748233709103036.19318505
AIHA. 2016. Cobalt. In: 2016 ERPG/WEEL handbook. American Industrial Hygiene Association, 22–31.
Ajibade TO, Oyagbemi AA, Omobowale TO, 2017. Quercetin and vitamin C mitigate cobalt chloride-induced hypertension through reduction in oxidative stress and nuclear factor kappa beta (NF-Kb) expression in experimental rat model. Biol Trace Elem Res 175(2):347–359. 10.1007/s12011-016-0773-5.27283837
Akinrinde AS, Adebiyi OE. 2019. Neuroprotection by luteolin and gallic acid against cobalt chloride-induced behavioural, morphological and neurochemical alterations in Wistar rats. Neurotoxicology 74:252–263. 10.1016/j.neuro.2019.07.005.31362009
Akinrinde AS, Omobowale O, Oyagbemi A, 2016a. Protective effects of kolaviron and gallic acid against cobalt-chloride-induced cardiorenal dysfunction via suppression of oxidative stress and activation of the ERK signaling pathway. Can J Physiol Pharmacol 94(12):1276–1284. 10.1139/cjpp-2016-0197.27548501
Akinrinde AS, Oyagbemi AA, Omobowale TO, 2016b. Alterations in blood pressure, antioxidant status and caspase 8 expression in cobalt chloride-induced cardio-renal dysfunction are reversed by Ocimum gratissimum and gallic acid in Wistar rats. J Trace Elem Med Biol 36:27–37. 10.1016/j.jtemb.2016.03.015.27259349
Akinrinde AS, Oyagbemi AA, Omobowale TO, 2016c. Cobalt chloride-induced hepatic and intestinal damage in rats: Protection by ethyl acetate and chloroform fractions of Ocimum gratissimum. Toxicol Int 23(1):38–48. 10.22506/ti/2016/v23/i1/146668.
Akita K, Okamura H, Yoshida K, 2007. Cobalt chloride induces apoptosis and zinc chloride suppresses cobalt-induced apoptosis by Bcl-2 expression in human submandibular gland HSG cells. Int J Oncol 31(4):923–929.17786326
Al-Abcha A, Wang L, Reilly MJ, 2021. Work-related asthma in cobalt-exposed workers. J Asthma 58(8):1032–1041. 10.1080/02770903.2020.1759090.32308078
Alarifi S, Ali D, Suliman Y AO, 2013. Oxidative stress contributes to cobalt oxide nanoparticles-induced cytotoxicity and DNA damage in human hepatocarcinoma cells. Int J Nanomedicine 8:189–199. 10.2147/IJN.S37924.23326189
Alaux-Negrel G, Beucaire C, Michard G, 1993. Trace-metal behaviour in natural granitic waters. J Contam Hydrol 13:309–325. 10.1016/0169-7722(93)90068-4.
Albals D, Al-Momani IF, Issa R, 2021. Multi-element determination of essential and toxic metals in green and roasted coffee beans: A comparative study among different origins using ICP-MS. Sci Prog 104(2):368504211026162. 10.1177/00368504211026162.34152891
Albrecht A. 2003. Validating riverine transport and speciation models using nuclear reactor-derived radiocobalt. J Environ Radioact 66:295–307. 10.1016/S0265-931X(02)00133-9.12600761
Alexa T, Luca A, Bohotin C, 2015. The effect of cobalt chloride preconditioning on paclitaxel-induced peripheral neuropathy. Rev Med Chir Soc Med Nat Iasi 119(2):447–453.26204651
Alexander CS. 1969. Cobalt and the heart. Ann Intern Med 70(2):411–413. 10.7326/0003-4819-70-2-411.5764511
Alexander CS. 1972. Cobalt-beer cardiomyopathy. A clinical and pathologic study of twenty-eight cases. Am J Med 53(4):395–417. 10.1016/0002-9343(72)90136-2.4263183
Alexandersson R. 1988. Blood and urinary concentrations as estimators of cobalt exposure. Arch Environ Health 43(4):299–303. 10.1080/00039896.1988.10545953.3415357
Ali AA. 2019. Evaluation of some biological, biochemical, and hematological aspects in male albino rats after acute exposure to the nano-structured oxides of nickel and cobalt. Environ Sci Pollut Res Int 26(17):17407–17417. 10.1007/s11356-019-05093-2.31020524
Alinaghi F, Bennike NH, Egeberg A, 2019. Prevalence of contact allergy in the general population: A systematic review and meta-analysis. Contact Dermatitis 80(2):77–85. 10.1111/cod.13119.30370565
Alinaghi F, Friis UF, Deleuran MG, 2020. Exposure analysis using x-ray fluorescence device and a cobalt spot test in four patients with cobalt allergy. Contact Dermatitis 82(1):67–69. 10.1111/cod.13394.31487039
Alinovi R, Goldoni M, Pinelli S, 2015. Oxidative and pro-inflammatory effects of cobalt and titanium oxide nanoparticles on aortic and venous endothelial cells. Toxicol In Vitro 29(3):426–437. 10.1016/j.tiv.2014.12.007.25526690
Alinovi R, Goldoni M, Pinelli S, 2017. Titanium dioxide aggregating nanoparticles induce autophagy and under-expression of microRNA 21 and 30a in A549 cell line: A comparative study with cobalt(II, III) oxide nanoparticles. Toxicol In Vitro 42:76–85. 10.1016/j.tiv.2017.04.007.28400205
Amacher DE, Paillet SC. 1980. Induction of trifluorothymidine-resistant mutants by metal ions in L5178Y/TK+/- cells. Mutat Res 78(3):279–288. 10.1016/0165-1218(80)90110-x.7432364
Amiard J, Amiard-Triquet C. 1979. Distribution of cobalt 60 in a mollusc, a crustacean and a freshwater teleost: Variations as a function of the source of pollution and during elimination. Environ Pollut 20(3):199–213. 10.1016/0013-9327(79)90005-3.
Amundsen CE, Hanssen JE, Semb A, 1992. Long-range atmospheric transport of trace elements to southern Norway. Atmos Environ 26A(7):1309–1324. 10.1016/0960-1686(92)90391-W.
Anaissi F, Horsth D, Dalastra J, 2020. Design, synthesis, and application of colored cobalt pigments (pink, blue, green). J Braz Chem Soc 31(11):2265–2273. 10.21577/0103-5053.20200078.
Anavekar NS, Nixon R. 2006. Occupational allergic contact dermatitis to cobalt octoate included as an accelerator in a polyester resin. Australas J Dermatol 47(2):143–144. 10.1111/j.1440-0960.2006.00251.x.16637815
Andersen O. 1983. Effects of coal combustion products and metal compounds on sister chromatid exchange (SCE) in a macrophagelike cell line. Environ Health Perspect 47:239–253. 10.1289/ehp.8347239.6337826
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Anderson MB, Pedigo NG, Katz RP, 1992. Histopathology of testes from mice chronically treated with cobalt. Reprod Toxicol 6(1):41–50. 10.1016/0890-6238(92)90019-p.1562797
Anderson MB, Lepak K, Farinas V, 1993. Protective action of zinc against cobalt-induced testicular damage in the mouse. Reprod Toxicol 7(1):49–54. 10.1016/0890-6238(93)90009-v.8448416
Andersson E, Knutsson A, Hagberg S, 2006. Incidence of asthma among workers exposed to sulphur dioxide and other irritant gases. Eur Respir J 27(4):720–725. 10.1183/09031936.06.00034305.16585079
Andersson L, Hedbrant A, Bryngelsson IL, 2020. Respiratory health and inflammatory markers-exposure to cobalt in the Swedish hard metal industry. J Occup Environ Med 62(10):820–829. 10.1097/jom.0000000000001952.33009343
Andersson L, Hedbrant A, Persson A, 2021. Inflammatory and coagulatory markers and exposure to different size fractions of particle mass, number and surface area air concentrations in the Swedish hard metal industry, in particular to cobalt. Biomarkers 26(6):557–569. 10.1080/1354750x.2021.1941260.34128444
Andre S, Metivier H, Masse R. 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles- Part III: Lung clearance of inhaled cobalt oxide particles in baboons. J Aerosol Sci 20(2):205–217. 10.1016/0021-8502(89)90042-6.
Apostoli P, Porru S, Alessio L. 1994. Urinary cobalt excretion in short time occupational exposure to cobalt powders. Sci Total Environ 150(1–3):129–132. 10.1016/0048-9697(94)90139-2.7939585
Apostoli P, Giusti S, Bartoli D, 1998. Multiple exposure to arsenic, antimony, and other elements in art glass manufacturing. Am J Ind Med 34(1):65–72. 10.1002/(sici)1097-0274(199807)34:1<65::aid-ajim9>3.0.co;2-p.9617389
Arimoto R, Duce RA, Ray BJ, 1985. Atmospheric trace elements at Enewetak Atoll: 2. Transport to the ocean by wet and dry deposition. J Geophys Res 90(D1):2391–2408. 10.1029/JD090iD01p02391.
Arlauskas A, Baker RS, Bonin AM, 1985. Mutagenicity of metal ions in bacteria. Environ Res 36(2):379–388. 10.1016/0013-9351(85)90032-5.3884331
Arslan S, Aksan S, Ucar R, 2015. Contact dermatitis to cobalt chloride with an unusual mechanism. Prosthet Orthot Int 39(5):419–421. 10.1177/0309364614534293.24876170
Ashrap P, Watkins DJ, Mukherjee B, 2020. Predictors of urinary and blood metal(loid) concentrations among pregnant women in Northern Puerto Rico. Environ Res 183:109178. 10.1016/j.envres.2020.109178.32007748
ATSDR. 1989. Decision guide for identifying substance- specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37617–37634.
ATSDR. 1995. Public health assessment: Blackbird Mine, Cobalt, Lemhi County, Idaho. Atlanta, GA: Agency of Toxic Substances and Disease Registry.
ATSDR. 1998. Toxicological profile for sulfur dioxide. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB99122020. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB99122020.xhtml. December 6, 2023.
ATSDR. 1999. Toxicological profile for ionizing radiation. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services. PB99163388. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB99163388.xhtml. December 6, 2023.
ATSDR. 2018. Draft guidance for the preparation of toxicological profiles Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/toxprofiles/guidance/profile_development_guidance.pdf. December 7, 2023.
ATSDR. 2001. Summary report for the ATSDR Soil-Pica Workshop June 2000 Atlanta, Georgia. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/child/pdf/summary-report-ATSDR-soil-pica-workshop-june-2000–508.pdf. June 24, 2024.
ATSDR. 2022. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources. June 8, 2023.
ATSDR. 2023. Sanders2015 HLCs used in SHOWER Model v3 and PHAST. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Awoyemi OV, Okotie UJ, Oyagbemi AA, 2017. Cobalt chloride exposure dose-dependently induced hepatotoxicity through enhancement of cyclooxygenase-2 (COX-2)/B-cell associated protein X (BAX) signaling and genotoxicity in Wistar rats. Environ Toxicol 32(7):1899–1907. 10.1002/tox.22412.28303633
Ayala-Fierro F, Firriolo JM, Carter DE. 1999. Disposition, toxicity, and intestinal absorption of cobaltous chloride in male Fischer 344 rats. J Toxicol Environ Health A 56(8):571–591. 10.1080/00984109909350178.10321386
Badsha KS, Goldspink CR. 1988. Heavy metal levels in three species of fish in Tjeukemeer, a Dutch polder lake. Chemosphere 17(2):459–463. 10.1016/0045-6535(88)90235-4.
Baes CF, Sharp RD. 1983. A proposal for estimation of soil leaching and leaching constants for use in assessment models. J Environ Qual 12(1):17–28. 10.2134/jeq1983.00472425001200010003x.
Bailey MR, Roy M. 1994. Annexe E. Clearance of particles from the respiratory tract. Ann ICRP 24(1–3):301–413. 10.1016/0146-6453(94)90043-4.
Bailey MR, Kreyling WG, Andre S, 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles- Part I: Objectives and summary of results. J Aerosol Sci 20(2):169–188. 10.1016/0021-8502(89)90042-6.
Bailey MR, Ansoborlo E, Guilmette RA, 2007. Updating the ICRP human respiratory tract model. Radiat Prot Dosimetry 127(1–4):31–34. 10.1093/rpd/ncm249.18192668
Baker DH, Czarnecki-Maulden GL. 1987. Pharmacological role of cysteine in ameliorating or exacerbating mineral toxicities. J Nutr 117(6):1003–1010. 10.1093/jn/117.6.1003.3298579
Banza CL, Nawrot TS, Haufroid V, 2009. High human exposure to cobalt and other metals in Katanga, a mining area of the Democratic Republic of Congo. Environ Res 109(6):745–752. 10.1016/j.envres.2009.04.012.19486963
Banza Lubaba Nkulu C, Casas L, Haufroid V, 2018. Sustainability of artisanal mining of cobalt in DR Congo. Nat Sustain 1(9):495–504. 10.1038/s41893-018-0139-4.30288453
Barany E, Bergdahl IA, Bratteby LE, 2005. Iron status influences trace element levels in human blood and serum. Environ Res 98(2):215–223. 10.1016/j.envres.2004.09.010.15820728
Barceloux DG. 1999. Cobalt. J Toxicol Clin Toxicol 37(2):201–206. 10.1081/clt-100102420.10382556
Bargagli R. 2000. Trace metals in Antarctica related to climate change and increasing human impact. Rev Environ Contam Toxicol 166:129–173.10868078
Bargagli R, Barghigiani C, Siegel BZ, 1991. Trace metal anomalies in surface soils and vegetation on two active island volcanoes: Stromboli and Volcano (Italy). Sci Total Environ 102:209–222. 10.1016/0048-9697(91)90315-6.
Barlas N. 1999. A pilot study of heavy metal concentration in various environments and fishes in the Upper Sakarya River Basin, Turkey. Environ Toxicol 14(3):367–373. 10.1002/(sici)1522–7278(199907)14:3<367::Aid-tox11>3.0.Co;2-9.
Barnaby CF, Smith T, Thompson BD. 1968. Dosimetry of the radioisotopes of cobalt. Phys Med Biol 13(3):421–433. 10.1088/0031-9155/13/3/309.5700181
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486. 10.1016/0273-2300(88)90047-5.3222488
Barnes JE, Kanapilly GM, Newton GJ. 1976. Cobalt-60 oxide aerosols: methods of production and short-term retention and distribution kinetics in the beagle dog. Health Phys 30(5):391–398. 10.1097/00004032-197605000-00003.1270267
Basketter DA, Angelini G, Ingber A, 2003. Nickel, chromium and cobalt in consumer products: revisiting safe levels in the new millennium. Contact Dermatitis 49(1):1–7. 10.1111/j.0105-1873.2003.00149.x.14641113
Bastian S, Busch W, Kuhnel D, 2009. Toxicity of tungsten carbide and cobalt-doped tungsten carbide nanoparticles in mammalian cells in vitro. Environ Health Perspect 117(4):530–536. 10.1289/ehp.0800121.19440490
Battistini B, Petrucci F, De Angelis I, 2020. Quantitative analysis of metals and metal-based nano-and submicron-particles in tattoo inks. Chemosphere 245:125667. 10.1016/j.chemosphere.2019.125667.31877461
Baumgardt B, Jackwerth E, Otto H, 1986. Trace analysis to determine heavy metal load in lung tissue. A contribution to substantiation of occupational hazards. Int Arch Occup Environ Health 58(1):27–34. 10.1007/BF00378537.3721588
Behl M, Stout MD, Herbert RA, 2015. Comparative toxicity and carcinogenicity of soluble and insoluble cobalt compounds. Toxicology 333:195–205. 10.1016/j.tox.2015.04.008.25896363
Beijer K, Jernelov A. 1986. Sources, transport and transformation of metals in the environment. In: Friberg L, Nordberg GF, Vouk V, eds. Handbook on the toxicology of metals. 2^nd^ ed. Amsterdam, Netherlands: Elsevier Science Publishers B.V., 68–84.
Beleznay E, Osvay M. 1994. Long-term clearance of accidentally inhaled ^60^Co aerosols in humans. Health Phys 66(4):392–399. 10.1097/00004032-199404000-00003.8138404
Bencko V, Wagner V, Wagnerova M, 1983. Immuno-biochemical findings in groups of individuals occupationally and non-occupationally exposed to emissions containing nickel and cobalt. J Hyg Epidemiol Microbiol Immunol 27(4):387–394.
Benes P, Jurak M, Cernik M. 1989. Factors affecting interaction of radiocobalt with river sediments. II. Composition and concentration of sediment, temperature. J Radioanal Nucl Chem 132(2):225–239. 10.1007/BF02136082.
Berniyanti T, Palupi R, Kriswandini IL, 2020. Suitability of MDA, 8-OHdG and wild-type p53 as genotoxic biomarkers in metal (Co, Ni and Cr) exposed dental technicians: a cross-sectional study. BMC Oral Health 20(1):65. 10.1186/s12903-020-1049-1.32138726
Beskid M. 1963. The effect of administration of cobalt chloride on the pancreas in the guinea-pig. Folia Histochem Cytochem (Krakow) 1:95–102.
Biego GH, Joyeux M, Hartemann P, 1998. Daily intake of essential minerals and metallic micropollutants from foods in France. Sci Total Environ 217(1–2):27–36. 10.1016/s0048-9697(98)00160-0.9695171
Bocca B, Forte G, Petrucci F, 2007. Levels of nickel and other potentially allergenic metals in Ni-tested commercial body creams. J Pharm Biomed Anal 44(5):1197–1202. 10.1016/j.jpba.2007.04.031.17566689
Bocca B, Ruggieri F, Pino A, 2019. Human biomonitoring to evaluate exposure to toxic and essential trace elements during pregnancy. Part A. Concentrations in maternal blood, urine and cord blood. Environ Res 177:108599. 10.1016/j.envres.2019.108599.31374401
Bocca B, Ruggieri F, Pino A, 2020. Human biomonitoring to evaluate exposure to toxic and essential trace elements during pregnancy. Part B: Predictors of exposure. Environ Res 182:109108. 10.1016/j.envres.2019.109108.32069754
Bonefeld CM, Nielsen MM, Vennegaard MT, 2015. Nickel acts as an adjuvant during cobalt sensitization. Exp Dermatol 24(3):229–231. 10.1111/exd.12634.25580744
Bonenfant JL, Auger C, Miller G, 1969. Quebec beer-drinkers' myocardosis: pathological aspects. Ann N Y Acad Sci 156(1):577–582. 10.1111/j.1749-6632.1969.tb16752.x.5291149
Bourg WJ, Nation JR, Clark DE. 1985. The effects of chronic cobalt exposure on passive-avoidance performance in the adult rat. Bull Psychonomic Soc 23(6):527–530. 10.3758/BF03329874.
Bowie EA, Hurley PJ. 1975. Cobalt chloride in the treatment of refractory anaemia in patients undergoing long-term haemodialysis. Aust N Z J Med 5(4):306–314. 10.1111/j.1445-5994.1975.tb03263.x.810127
Brandao MH, Gontijo B. 2012. Contact sensitivity to metals (chromium, cobalt and nickel) in childhood. An Bras Dermatol 87(2):269–276. 10.1590/s0365-05962012000200012.22570032
Bregnbak D, Zachariae C, Thyssen JP. 2015a. Occupational exposure to metallic cobalt in a baker. Contact Dermatitis 72(2):118–119. 10.1111/cod.12321.25418534
Bregnbak D, Thyssen JP, Zachariae C, 2015b. Association between cobalt allergy and dermatitis caused by leather articles-a questionnaire study. Contact Dermatitis 72(2):106–114. 10.1111/cod.12319.25407465
Bregnbak D, Opstrup MS, Jellesen MS, 2017. Allergic contact dermatitis caused by cobalt in leather - clinical cases. Contact Dermatitis 76(6):366–368. 10.1111/cod.12721.28497626
Briani C, Cacciavillani M, Nicolli A, 2015. 'Snake eyes' MRI sign: possible role of cobalt toxicity? J Neurol 262(2):471–472. 10.1007/s00415-014-7580-8.25488472
Brock T, Stopford W. 2003. Bioaccessibility of metals in human health risk assessment: evaluating risk from exposure to cobalt compounds. J Environ Monit 5(4):71N-76N. 10.1039/b307520f.
Broding HC, Michalke B, Goen T, 2009. Comparison between exhaled breath condensate analysis as a marker for cobalt and tungsten exposure and biomonitoring in workers of a hard metal alloy processing plant. Int Arch Occup Environ Health 82(5):565–573. 10.1007/s00420-008-0390-5.19034487
Brooks SC, Herman JS, Hornberger GM, 1998. Biodegradation of cobalt-citrate complexes: Implications for cobalt mobility in groundwater. J Contam Hydrol 32:99–115. 10.1016/S0169-7722(97)00083-1.
Brown DM, Johnston HJ, Gaiser B, 2018. A cross-species and model comparison of the acute toxicity of nanoparticles used in the pigment and ink industries. NanoImpact 11:20–32. 10.1016/j.impact.2018.02.001.
Browning E. 1969. Cobalt. In: Toxicity of industrial metals. 2^nd^ ed. New York, NY: Appleton-Century-Crofts, 132.
Brugmann L. 1988. Some peculiarities of the trace-metal distribution in Baltic waters and sediments. Mar Chem 23(3–4):425–440. 10.1016/0304-4203(88)90109-0.
Brune D, Kjaerheim A, Paulsen G, 1980. Pulmonary deposition following inhalation of chromium-cobalt grinding dust in rats and distribution in other tissues. Scand J Dent Res 88(6):543–551. 10.1111/j.1600-0722.1980.tb01265.x.6941368
Brusseau ML, Zachara JM. 1993. Transport of Co2+ in a physically and chemically heterogeneous porous medium. Environ Sci Technol 27(9):1937–1939. 10.1021/es00046a026.
Bryan SE, Bright JE. 1973. Serum protein responses elicited by iron, cobalt and mercury. Toxicol Appl Pharmacol 26(1):109–117. 10.1016/0041-008x(73)90091-4.4748130
Bucher JR, Elwell MR, Thompson MB, 1990. Inhalation toxicity studies of cobalt sulfate in F344/N rats and B6C3F1 mice. Fundam Appl Toxicol 15(2):357–372. 10.1016/0272-0590(90)90061-n.2227161
Bucher JR, Hailey JR, Roycroft JR, 1999. Inhalation toxicity and carcinogenicity studies of cobalt sulfate. Toxicol Sci 49:56–67. 10.1093/toxsci/49.1.56.10367342
Bucher JR, Hailey JR, Roycroft JR, 2022. Correction to: Inhalation toxicity and carcinogenicity studies of cobalt sulfate. Toxicol Sci 188(2):276. 10.1093/toxsci/kfac063.35726922
Buchter B, Davidoff B, Amacher MC, 1989. Correlation of Freundlich Kd and n retention parameters with soils and elements. Soil Science 148(5):370–379.
Burba P, Rocha J, Klockow D. 1994. Labile complexes of trace metals in aquatic humic substances: Investigations by means of an ion exchange-based flow procedure. Fresenius J Anal Chem 349:800–807. 10.1007/BF00323109.
Burger J, Gochfeld M. 1988. Metals in tern eggs in a New Jersey estuary: A decade of change. Environ Monit Assess 11(2):127–135. 10.1007/BF00401725.24248886
Burke DH, Brooks JC, Ryan RP, 1978. p-Chloroamphetamine antagonism of cobaltous chloride-induced hypothermia in mice. Eur J Pharmacol 60:241–243. 10.1016/0014-2999(79)90224-3.
Burzlaff A, Creutzenberg O, Schaudien D, 2022a. A tiered approach to investigate the inhalation toxicity of cobalt substances. Tier 4: Effects from a 28-day inhalation toxicity study with tricobalt tetraoxide in rats. Regul Toxicol Pharmacol 130:105129. 10.1016/j.yrtph.2022.105129.35124138
Burzlaff A, Creutzenberg O, Schaudien D, 2022b. Supplemental material: A tiered approach to investigate the inhalation toxicity of cobalt substances. Tier 4: Effects from a 28-day inhalation toxicity study with tricobalt tetraoxide in rats. Regul Toxicol Pharmacol 130 10.1016/j.yrtph.2022.105129.
Byczkowski JZ, Gearhart JM, Fisher JW. 1994. "Occupational" exposure of infants to toxic chemicals via breast milk. Nutrition 10(1):43–48.8199422
Cahill JL, Andersen KE. 2010. Occupational cobalt-allergic contact dermatitis resulting from polyester resin. Contact Dermatitis 63(5):292–294. 10.1111/j.1600-0536.2010.01781.x.20946461
Caicedo M, Jacobs JJ, Reddy A, 2008. Analysis of metal ion-induced DNA damage, apoptosis, and necrosis in human (Jurkat) T-cells demonstrates Ni2+ and V3+ are more toxic than other metals: Al3+, Be2+, Co2+, Cr3+, Cu2+, Fe3+, Mo5+, Nb5+, Zr2+. J Biomed Mater Res A 86(4):905–913. 10.1002/jbm.a.31789.18050301
Camean A, Lopez-Artiguez M, Roca I, 1998. Determination of cobalt, manganese, and alcohol content in beers. J Food Prot 61(1):129–131. 10.4315/0362-028x-61.1.129.9708269
Camner P, Boman A, Johansson A, 1993. Inhalation of cobalt by sensitised guinea pigs: effects on the lungs. Br J Ind Med 50(8):753–757. 10.1136/oem.50.8.753.8398863
Cao S, Duan X, Zhao X, 2014. Health risks from the exposure of children to As, Se, Pb and other heavy metals near the largest coking plant in China. Sci Total Environ 472:1001–1009. 10.1016/j.scitotenv.2013.11.124.24345860
Capomazza C, Botta A. 1991. Cobalt chloride induces micronuclei in human lymphocytes. Med Sci Res 19:219–220.
Carvalho FP. 1987. Comparative uptake from sea water and tissue distribution of ^60^Co in marine mollusks. Health Phys 53(1):73–81. 10.1097/00004032-198707000-00008.3597101
CDC. 2017. National health and nutrition examination survey. 2015–2016 Data documentation, codebook, and frequencies. Chromium & cobalt (CRCO_I). Centers for Disease Control and Prevention. https://wwwn.cdc.gov/Nchs/Nhanes/2015-2016/CRCO_I.htm. June 8, 2021.
CDC. 2018. National health and nutrition examination survey. 2015–2016 Data documentation, codebook, and frequencies. Metals - urine (UM_I). Centers for Disease Control and Prevention. https://wwwn.cdc.gov/Nchs/Nhanes/2015-2016/UM_I.htm. June 8, 2021.
CDC. 2022. National report on human exposure to environmental chemicals. Updated March 2022. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/index.html. October 13, 2022.
CDC. 2023. Blood cobalt (2015 – 2018). Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/report/pdf/cgroup54_LBXBCO_2011-p.pdf. December 6, 2023.
Chamberlain JL. 1961. Thyroid enlargement probably induced by cobalt: A report of 3 cases. J Pediatr 59(1):81–86. 10.1016/s0022-3476(61)80213-8.13692213
Chen F, Khan ZI, Zafar A, 2021. Evaluation of toxicity potential of cobalt in wheat irrigated with wastewater: health risk implications for public. Environ Sci Pollut Res Int 28(17):21119–21131. 10.1007/s11356-020-11815-8.33410057
Chen H, Chai M, Cheng J, 2022. Occurrence and health implications of heavy metals in preschool children's clothing manufactured in four Asian regions. Ecotoxicol Environ Saf 245:114121. 10.1016/j.ecoenv.2022.114121.36179449
Cheong SH, Choi YW, Choi HY, 2014. Nickel and cobalt release from jewellery and metal clothing items in Korea. Contact Dermatitis 70(1):11–18. 10.1111/cod.12141.24152201
Chester R, Berry AS, Murphy KJT. 1991. The distributions of particulate atmospheric trace metals and mineral aerosols over the Indian Ocean. Mar Chem 34:261–290. 10.1016/0304-4203(91)90007-J.
Chetty KN, Subba Rao DS, Drummond L, 1979. Cobalt induced changes in immune response and adenosine triphosphatase activities in rats. J Environ Sci Health B 14(5):525–544. 10.1080/03601237909372148.157363
Cheyns K, Banza Lubaba Nkulu C, Ngombe LK, 2014. Pathways of human exposure to cobalt in Katanga, a mining area of the D.R. Congo. Sci Total Environ 490:313–321. 10.1016/j.scitotenv.2014.05.014.24858229
Christensen JM, Poulsen OM. 1994. A 1982–1992 surveillance programme on Danish pottery painters. Biological levels and health effects following exposure to soluble or insoluble cobalt compounds in cobalt blue dyes. Sci Total Environ 150(1–3):95–104. 10.1016/0048-9697(94)90134-1.7939615
Christensen JM, Poulsen OM, Thomsen M. 1993. A short-term cross-over study on oral administration of soluble and insoluble cobalt compounds: sex differences in biological levels. Int Arch Occup Environ Health 65(4):233–240. 10.1007/BF00381196.8144233
Christova T, Duridanova D, Braykova A, 2001. Heme oxygenase is the main protective enzyme in rat liver upon 6-day administration of cobalt chloride. Arch Toxicol 75:445–451. 10.1007/s002040100253.11757667
Christova TY, Duridanova DB, Setchenska MS. 2002. Enhanced heme oxygenase activity increases the antioxidant defense capacity of guinea pig liver upon acute cobalt chloride loading: comparison with rat liver. Comp Biochem Physiol C Toxicol Pharmacol 131(2):177–184. 10.1016/s1532-0456(01)00287-3.11879785
Chu Z, Lin C, Yang K, 2022. Lability, bioaccessibility, and ecological and health risks of anthropogenic toxic heavy metals in the arid calcareous soil around a nonferrous metal smelting area. Chemosphere 307(Pt 4):136200. 10.1016/j.chemosphere.2022.136200.36030943
Cikrt M, Tichy M. 1981. Biliary excretion of cobalt in rats. J Hyg Epidemiol Microbiol Immunol 25(4):364–368.
Clark J. 2023. Chemistry of cobalt. LibreText Chemistry. https://chem.libretexts.org/@go/page/3721?pdf. December 6, 2023.
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Clifford D, Subramonian S, Sorg TJ. 1986. Removing dissolved inorganic contaminants from water. Environ Sci Technol 20(11):1072–1080. 10.1021/es00153a001.
Clyne N, Lins L- E, Pehrsson SK, 1988. Distribution of cobalt in myocardium, skeletal muscle and serum in exposed and unexposed rats. Trace Elem Med 5(2):52–54.
Clyne N, Hofman-Bang C, Haga Y, 2001. Chronic cobalt exposure affects antioxidants and ATP production in rat myocardium. Scand J Clin Lab Invest 61(8):609–614. 10.1080/003655101753267964.11768320
Coakley JP, Nagy E, Serodes J- B. 1994. Spatial and vertical trends in sediment-phase contaminants in the upper estuary of the St. Lawrence river. Estuaries 16(3B):653–669. 10.2307/1352802.
Coleman ME, Elder RS, Koppenaal GP. 1992. Trace metals in edible tissues of livestock and poultry. J AOAC Int 75(4):615–625. 10.1093/jaoac/75.4.615.
Collecchi P, Esposito M, Brera S, 1986. The distribution of arsenic and cobalt in patients with laryngeal carcinoma. J Appl Toxicol 6(4):287–289. 10.1002/jat.2550060410.3760455
Collier CG, Bailey MR, Hodgson A. 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles-Part V: Lung clearance of inhaled cobalt oxide particles in hamsters, rats and guinea-pigs. J Aerosol Sci 20(2):233–247. 10.1016/0021-8502(89)90046-3.
Collier CG, Hodgson A, Gray SA, 1991. The lung clearance kinetics of ^57^Co_3_O_4_ in rats of various ages. J Aerosol Sci 22(4):537–549. 10.1016/0021-8502(91)90009-7.
Corazza M, Baldo F, Pagnoni A, 2009. Measurement of nickel, cobalt and chromium in toy make-up by atomic absorption spectroscopy. Acta Derm Venereol 89(2):130–133. 10.2340/00015555-0595.19325995
Corrier DE, Mollenhauer HH, Clark DE, 1985. Testicular degeneration and necrosis induced by dietary cobalt. Vet Pathol 22(6):610–616. 10.1177/030098588502200616.4082387
Costa M, Heck JD, Robison SH. 1982. Selective phagocytosis of crystalline metal sulfide particles and DNA strand breaks as a mechanism for the induction of cellular transformation. Cancer Res 42:2757–2763.7083166
Cross DP, Ramachandran G, Wattenberg EV. 2001. Mixtures of nickel and cobalt chlorides induce synergistic cytotoxic effects: implications for inhalation exposure modeling. Ann Occup Hyg 45(5):409–418.11418091
Cyr F, Mehra MC, Mallet VN. 1987. Leaching of chemical contaminants from a municipal landfill site. Bull Environ Contam Toxicol 38(5):775–782. 10.1007/BF01616700.3580592
Dabeka RW. 1989. Survey of lead, cadmium, cobalt and nickel in infant formulas and evaporated milks and estimation of dietary intakes of the elements by infants 0–12 months old. Sci Total Environ 89(3):279–289. 10.1016/0048-9697(89)90267-2.2617291
Dabeka RW, McKenzie AD. 1995. Survey of lead, cadmium, fluoride, nickel, and cobalt in food composites and estimation of dietary intakes of these elements by Canadians in 1986–1988. J AOAC Int 78(4):897–909.7580328
Daniel J, Ziaee H, Pradhan C, 2010. Renal clearance of cobalt in relation to the use of metal-on-metal bearings in hip arthroplasty. J Bone Joint Surg Am 92(4):840–845. 10.2106/JBJS.H.01821.20360506
Danzeisen R, Williams DL, Viegas V, 2020a. Bioelution, bioavailability, and toxicity of cobalt compounds correlate. Toxicol Sci 174(2):311–325. 10.1093/toxsci/kfz249.32058562
Danzeisen R, Williams DL, Viegas V, 2020b. Supplemental material: Bioelution, bioavailability, and toxicity of cobalt compounds correlate. Toxicol Sci 174(2) 10.1093/toxsci/kfz249.
Danzeisen R, Weight D, Blakeney M, 2022a. A tiered approach to investigate the inhalation toxicity of cobalt substances. Introduction: Cobalťs essential role in nature and technology. Regul Toxicol Pharmacol 130:105125. 10.1016/j.yrtph.2022.105125.35085603
Danzeisen R, Jänig GR, Burzlaff A, 2022b. The underlying mode of action for lung tumors in a tiered approach to the assessment of inhaled cobalt compounds. Regul Toxicol Pharmacol 130:105140. 10.1016/j.yrtph.2022.105140.35158000
Dasch JM, Wolff GT. 1989. Trace inorganic species in precipitation and their potential use in source apportionment studies. Water Air Soil Pollut 43:401–412. 10.1007/BF00279205.
Davis JE, Fields JP. 1958. Experimental production of polycythemia in humans by administration of cobalt chloride. Proc Soc Exp Biol Med 99(2):493–495. 10.3181/00379727-99-24395.13601915
Davison AG, Haslam PL, Corrin B, 1983. Interstitial lung disease and asthma in hard-metal workers: bronchoalveolar lavage, ultrastructural, and analytical findings and results of bronchial provocation tests. Thorax 38(2):119–128. 10.1136/thx.38.2.119.6857569
Dawson EB, Evans DR, Harris WA, 2000. Seminal plasma trace metal levels in industrial workers. Biol Trace Elem Res 74(2):97–105. 10.1385/BTER:74:2:97.11051584
Day GA, Virji MA, Stefaniak AB. 2009. Characterization of exposures among cemented tungsten carbide workers. Part II: Assessment of surface contamination and skin exposures to cobalt, chromium and nickel. J Expo Sci Environ Epidemiol 19(4):423–434. 10.1038/jes.2008.33.18523457
De Boeck M, Lison D, Kirsch-Volders M. 1998. Evaluation of the in vitro direct and indirect genotoxic effects of cobalt compounds using the alkaline comet assay. Influence of interdonor and interexperimental variability. Carcinogenesis 19(11):2021–2029. 10.1093/carcin/19.11.2021.9855019
De Boeck M, Lardau S, Buchet JP, 2000. Absence of significant genotoxicity in lymphocytes and urine from workers exposed to moderate levels of cobalt-containing dust: a cross-sectional study. Environ Mol Mutagen 36(2):151–160. 10.1002/1098-2280(2000)36:2<151::aid-em10>3.3.co;2-m.11013414
De Boeck M, Lombaert N, De Backer S, 2003. In vitro genotoxic effects of different combinations of cobalt and metallic carbide particles. Mutagenesis 18(2):177–186. 10.1093/mutage/18.2.177.12621074
De Cuyper J. 1988. Milling of cobalt ores - An overview. In: Tyroler GP, Landolt CA, eds. Extractive metallurgy of nickel and cobalt symposium. Warrendale: The Metallurgical Society, Inc., 187–210.
Dehaine Q, Tijsseling LT, Glass HJ, 2021. Geometallurgy of cobalt ores: A review. Miner Eng 160:106656. 10.1016/j.mineng.2020.106656.
Deka NC, Sehgal AK, Chhuttani PN. 1981. Absorption and transport of radioactive ^57^cobalt vitamin B_12_ in experimental giardiasis in rats. Indian J Med Res 74:675–679.7341444
Demedts M, Gheysens B, Nagels J, 1984. Cobalt lung in diamond polishers. Am Rev Respir Dis 130(1):130–135. 10.1164/arrd.1984.130.1.130.6742597
Deng JF, Sinks T, Elliott L, 1991. Charaterisation of respiratory health and exposures at a sintered permanent magnet manufacturer. Br J Ind Med 48:609–615. 10.1136/oem.48.9.609.1911403
Derr R, Moelijker N, Hendriks G, 2022. A tiered approach to investigate the inhalation toxicity of cobalt substances. Tier 2 b: Reactive cobalt substances induce oxidative stress in ToxTracker and activate hypoxia target genes. Regul Toxicol Pharmacol 129:105120. 10.1016/j.yrtph.2022.105120.35038485
DOE. 1984. Mobility of organic complexes of nickel and cobalt in soils. Washington, DC: Department of Energy. DE83017897. PNL-4796. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/DE83017897.xhtml. February 15, 2024.
DOE. 1988. Investigation of leaching of radionuclides and hazardous materials from low-level wastes at Oak Ridge National Laboratory. Washington, DC: U.S. Department of Energy. DE87013363. ORNL/TM-9883. https://www.osti.gov/servlets/purl/6308786. December 6, 2023.
DOE. 1996. Evaluation of cobalt mobility in soils from the Nevada test site. Reno, NV: U.S. Department of Energy. DE97001628. DOE/NV/10845–58. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/DE97001628.xhtml. December 7, 2023.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
DOE. 2023. Notice of final determination on 2023 DOE critical materials list. July 2023. U.S. Department of Energy. https://www.federalregister.gov/documents/2023/08/04/2023-16611/notice-of-final-determination-on-2023-doe-critical-materials-list. March 15, 2023.
Dogan CE, Cebi N. 2019. Investigation of antimony, cobalt, and acetaldehyde migration into the drinking water in Turkey. Packag Technol Sci 32(5):239–246. 10.1002/pts.2430.
Domingo JL, Llobet JM. 1984. Treatment of acute cobalt intoxication in rats with L-methionine. Rev Esp Fisiol 40(4):443–448.6531510
Domingo JL, Llobet JM, Corbella J. 1983. The effects of EDTA in acute cobalt intoxication in rats. Toxicol Eur Res 5(6):251–255.6426088
Domingo JL, Llobet JM, Bernat R. 1984. A study of the effects of cobalt administered orally to rats. Arch Farmacol Toxicol 10(1):13–20.6508364
Domingo JL, Llobet JM, Corbella J. 1985a. The effect of L-histidine on acute cobalt intoxication in rats. Food Chem Toxicol 23(1):130–131. 10.1016/0278-6915(85)90242-x.4038677
Domingo JL, Paternian JL, Llobet JM, 1985b. Effects of cobalt on postnatal development and late gestation in rats upon oral administration. Rev Esp Fisiol 41:293–298.4070758
Duckham JM, Lee HA. 1976. The treatment of refractory anaemia of chronic renal failure with cobalt chloride. Q J Med 45(178):277–294. 10.1093/oxfordjournals.qjmed.a067463.940922
Eckel WP, Jacob TA. 1988. Ambient levels of 24 dissolved metals in U.S. surface and ground waters. Prepr Pap Natl Meet Am Chem Soc Div Environ Chem 28(2):371–372.
EFSA. 2009. Scientific Opinion on the use of cobalt compounds as additives in animal nutrition. EFSA J 7(12):1383. 10.2903/j.efsa.2009.1383.
Elbetieha A, Al-Thani AS, Al-Thani RK, 2008. Effects of chronic exposure to cobalt chloride on the fertility and testes in mice. J Appl Biol Sci 2(1):1–6.
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
EPA. 1980. Biological monitoring of toxic trace metals: Volume 1. Biological monitoring and surveillance. Washington, DC: U.S. Environmental Protection Agency. EPA600380089. PB81103475. https://cfpub.epa.gov/si/si_public_record_Report.cfm?Lab=ORD&dirEntryId=49027.December 6, 2023.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. EPA600890066F. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001K4C.txt. December 7, 2023.
EPA. 1997. Method 200.10: Determination of trace elements in marine waters by on-line chelation preconcentration and inductively coupled plasma - mass spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency. https://cfpub.epa.gov/si/si_public_record_report.cfm?Lab=NERL&dirEntryId=309424. December 6, 2023.
EPA. 1998. Hazardous waste management system; identification and listing of hazardous waste; petroleum refining process wastes; land disposal restrictions for newly identified wastes; and CERCLA hazardous substance designation and reportable quantities. Fed Regist 63(151):42110–42189.
EPA. 1999. Compendium of methods for the determination of inorganic compounds in ambient air. Compendium method IO-3.3. Determination of metals in ambient particulate matter using x-ray fluorescence (XRF) spectroscopy. Cincinnati, OH: U.S. Environmental Protection Agency. EPA625R96010a. https://www.epa.gov/sites/default/files/2019-11/documents/mthd-3-3.pdf.December 6, 2023.
EPA. 2000. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822B00001.
EPA. 2008. Provisional peer reviewed toxicity values for cobalt (CASRN 7440–48-4). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R08008F. https://cfpub.epa.gov/ncea/pprtv/documents/Cobalt.pdf. November 22, 2023.
EPA. 2009. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/default/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2017. The third unregulated contaminant monitoring rule (UCMR 3): Data summary, January 2017. U.S. Environmental Protection Agency. EPA815S17001. https://www.epa.gov/sites/production/files/2017-02/documents/ucmr3-data-summary-january-2017.pdf.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2020. Air quality system: Cobalt. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. January 10, 2021.
EPA. 2022a. IRIS assessment plan and protocol for assessing cancer risk from inhalation exposure to cobalt and cobalt compounds (scoping and problem formulation materials). Washington, DC: U.S. Environmental Protection Agency. EPA635R22248. https://ordspub.epa.gov/ords/eims/eimscomm.getfile?p_download_id=545669. December 5, 2023.
EPA. 2022b. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2023a. Applicability: Description of the primary nickel and cobalt subcategory. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 421.230. https://www.govinfo.gov/content/pkg/CFR-2010-title40-vol28/pdf/CFR-2010-title40-vol28-sec421-230.pdf. December 12, 2023.
EPA. 2023b. Applicability: Description of the secondary tungsten and cobalt subcategory. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 421.310. https://www.govinfo.gov/content/pkg/CFR-2011-title40-vol29/pdf/CFR-2011-title40-vol29-sec421-307.pdf. December 8, 2023.
EPA. 2023c. Applicability: Description of the nickel-cobalt forming sub-category. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 471.30. https://www.govinfo.gov/content/pkg/CFR-2022-title40-vol32/pdf/CFR-2022-title40-vol32-sec471-30.pdf. December 8, 2023.
EPA. 2023d. Annual summary data: Cobalt. Air data: Air quality data collected at outdoor monitors across the US. U.S. Environmental Protection Agency. https://www.epa.gov/outdoor-air-quality-data. April 19, 2023.
EPA. 2023e. Subject: Lithium battery recycling regulatory status and frequently asked questions. Washington, DC: U.S. Environmental Protection Agency. https://rcrapublic.epa.gov/files/14957.pdf. February 12, 2024.
Erlandsson B, Ingemansson T, Mattsson S. 1983. Comparative studies of radionuclides from global fallout and local sources in ground level air and sewage sludge. Water Air Soil Pollut 20:331–346. 10.1007/BF00284637.
Ertuğrul H, Yalçın B, Güneş M, 2020. Ameliorative effects of melatonin against nano and ionic cobalt induced genotoxicity in two in vivo Drosophila assays. Drug Chem Toxicol 43(3):279–286. 10.1080/01480545.2019.1585444.30880493
Evans RD, Andrews D, Cornett RJ. 1988. Chemical fractionation and bioavailability of cobalt-60 to benthic deposit-feeders. Can J Fish Aquat Sci 45:228–235. 10.1139/f88-027.
Exelon. 2019. Peach Bottom Atomic Power Station units 2 and 3: Annual radiological environmental operating report Delta, PA: Peach Bottom Atomic Power Station, Exelon Generation. Report No. 76. https://www.nrc.gov/docs/ML1915/ML19154A580.pdf. May 29, 2024.
Eyrolle F, Charmasson S. 2001. Distribution of organic carbon, selected stable elements and artificial radionuclides among dissolved, colloidal and particulate phases in the Rhone River (France): Preliminary results. J Environ Radioact 55:145–155. 10.1016/s0265-931x(00)00188-0.11398374
Farah SB. 1983. The in vivo effect of cobalt chloride on chromosomes. Rev Bras Genet 6(3):433–442.
Farjana SH, Huda N, Mahmud MAP. 2019. Life cycle assessment of cobalt extraction process. J Sustain Min 18(3):150–161. 10.1016/j.jsm.2019.03.002.
FDA. 2023a. Substances prohibited from use in human food. Subpart C - Substances generally prohibited from direct addition or use as human food. Cobaltous salts and its derivatives. Food and Drug Administration. 21 CFR 189.120. https://www.govinfo.gov/content/pkg/CFR-2023-title21-vol3/pdf/CFR-2023-title21-vol3-part189-subpartC.pdf. November 22, 2023.
FDA. 2023b. Secondary direct food additives permitted in food for human consumption. Subpart D - Specific usage additives. Boil water additives. Food and Drug Administration. 21 CFR 173.310. https://www.govinfo.gov/content/pkg/CFR-2023-title21-vol3/pdf/CFR-2023-title21-vol3-sec173-310.pdf. November 22, 2023.
Feng MR, Rossi DT, Strenkoski C, 1998. Disposition kinetics of cobalt mesoporphyrin in mouse, rat, monkey and donkey. Xenobiotica 28(4):413–426. 10.1080/004982598239515.9604304
Ferdenzi P, Giaroli C, Mori P, 1994. Cobalt powdersintering industry (stone cutting diamond wheels): A study of environmental-biological monitoring workplace improvement and health surveillance. Sci Total Environ 150:245–248. 10.1016/0048-9697(94)90160-0.7939603
Finley BL, Monnot AD, Paustenbach DJ, 2012a. Derivation of a chronic oral reference dose for cobalt. Regul Toxicol Pharmacol 64(3):491–503. 10.1016/j.yrtph.2012.08.022.22982439
Finley BL, Monnot AD, Gaffney SH, 2012b. Dose-response relationships for blood cobalt concentrations and health effects: a review of the literature and application of a biokinetic model. J Toxicol Environ Health B Crit Rev 15(8):493–523. 10.1080/10937404.2012.744287.23199219
Finley BL, Unice KM, Kerger BD, 2013. 31-day study of cobalt(II) chloride ingestion in humans: pharmacokinetics and clinical effects. J Toxicol Environ Health A 76(21):1210–1224. 10.1080/15287394.2013.848391.24283372
Finney BP, Huh C- A. 1989. History of metal pollution in the Southern California bight: An update. Environ Sci Technol 23(3):294–303. 10.1021/es00180a005.
Firriolo JM, Ayala-Fierro F, Sipes IG, 1999. Absorption and disposition of cobalt naphthenate in rats after a single oral dose. J Toxicol Environ Health A 58(6):383–395. 10.1080/009841099157223.10580760
Flaten TP. 1991. A nation-wide survey of the chemical composition of drinking water in Norway. Sci Total Environ 102:35–73. 10.1016/0048-9697(91)90307-z.2038665
Forbes JR, Gros P. 2003. Iron, manganese, and cobalt transport by Nramp1 (Slc11a1) and Nramp2 (Slc11a2) expressed at the plasma membrane. Blood 102(5):1884–1892. 10.1182/blood-2003-02-0425.12750164
Forbes RM, Cooper AR, Mitchell HH. 1954. On the occurrence of beryllium, boron, cobalt, and mercury in human tissues. J Biol Chem 209(2):857–865.13192140
Foster PP, Pearman I, Ramsden D. 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles-Part II: Lung clearance of inhaled cobalt oxide in man. J Aerosol Sci 20(2):189–204. 10.1016/0021-8502(89)90043-8.
Freire BM, Gonzaga RG, Pedron T, 2021. Occupational exposure to potentially toxic elements in the foundry industry: an integrated environmental and biological monitoring. Environ Sci Pollut Res Int 28(26):34630–34641. 10.1007/s11356-021-13099-y.33650056
Freitas ACS, Guimaraes JRD, Gouvea VA, 1988. Laboratory experiments on ^60^Co bioaccumulation by tropical seaweeds. In: Seeliger U, de Lacerda LD, Patchineelam SR, eds. Metals in coastal environments of Latin America. Berlin, Germany: Springer-Verlag, 145–154.
Fresquez MR, Pappas RS, Watson CH. 2013. Establishment of toxic metal reference range in tobacco from US cigarettes. J Anal Toxicol 37(5):298–304. 10.1093/jat/bkt021.23548667
Fuentes CA, Gallegos MV, García JR, 2019. Catalytic glycolysis of poly(ethylene terephthalate) using zinc and cobalt oxides recycled from spent batteries. Waste Biomass Valor 11(9):4991–5001. 10.1007/s12649-019-00807-6.
Fujio T, Jyoyama Y, Yasui S, 2009. Cobalt concentration in urine as an indicator of occupational exposure to low level cobalt oxide. J UOEH 31(3):243–257. 10.7888/juoeh.31.243.19750931
Fukunaga M, Kurachi Y, Mizuguchi Y. 1982. Action of some metal ions on yeast chromosomes. Chem Pharm Bull 30(8):3017–3019. 10.1248/cpb.30.3017.
Gallorini M, Edel J, Pietra R, 1994. Cobalt speciation in urine of hard metal workers. A study carried out by nuclear and radioanalytical techniques. Sci Total Environ 150(1–3):153–160. 10.1016/0048-9697(94)90144-9.7939590
Gao Y, Li X, Dong J, 2020. Snack foods and lead ingestion risks for school aged children: A comparative evaluation of potentially toxic metals and children's exposure response of blood lead, copper and zinc levels. Chemosphere 261:127547. 10.1016/j.chemosphere.2020.127547.32717506
Garg AN, Weginwar RG, Chutke NL. 1993. Radiochemical neutron activation analysis of Fe, Co, Zn, Sb and Se in biomedical and environmental samples. Sci Total Environ 139–140:421–430. 10.1016/0048-9697(93)90039-9.
Garoui M, Fetoui H, Ayadi Makni F, 2011. Cobalt chloride induces hepatotoxicity in adult rats and their suckling pups. Exp Toxicol Pathol 63(1–2):9–15. 10.1016/j.etp.2009.09.003.19819122
Garoui M, Troudi A, Fetoui H, 2012. Propolis attenuates cobalt induced-nephrotoxicity in adult rats and their progeny. Exp Toxicol Pathol 64(7–8):837–846. 10.1016/j.etp.2011.03.004.21507616
Garoui E, Ben Amara I, Driss D, 2013. Effects of cobalt on membrane ATPases, oxidant, and antioxidant values in the cerebrum and cerebellum of suckling rats. Biol Trace Elem Res 154(3):387–395. 10.1007/s12011-013-9746-0.23857379
Garrick MD, Singleton ST, Vargas F, 2006. DMT1: which metals does it transport? Biol Res 39(1):79–85. 10.4067/s0716-97602006000100009.16629167
Ge X, Yang A, Huang S, 2021. Sex-specific associations of plasma metals and metal mixtures with glucose metabolism: An occupational population-based study in China. Sci Total Environ 760:143906. 10.1016/j.scitotenv.2020.143906.33341635
Gennart JP, Lauwerys R. 1990. Ventilatory function of workers exposed to cobalt and diamond containing dust. Int Arch Occup Environ Health 62:333–336. 10.1007/BF00640843.2166005
Gennart JP, Baleux C, Verellen-Dumoulin C, 1993. Increased sister chromatid exchanges and tumor markers in workers exposed to elemental chromium-, cobalt- and nickel-containing dusts. Mutat Res 299:55–61. 10.1016/0165-1218(93)90119-x.7679193
Gerhardsson L, Wester PO, Nordberg GF, 1984. Chromium, cobalt and lanthanum in lung, liver and kidney tissue from deceased smelter workers. Sci Total Environ 37(2–3):233–246. 10.1016/0048-9697(84)90099-8.6484565
Gerhardsson L, Brune D, Nordberg GF, 1988. Multielemental assay of tissues of deceased smelter workers and controls. Sci Total Environ 74:97–110. 10.1016/0048-9697(88)90131-3.3222699
Gerritse RG, Vriesema R, Dalenberg JW, 1982. Effect of sewage sludge on trace element mobility in soils. J Environ Qual 11(3):359–364. 10.2134/jeq1982.00472425001100030007x.
Gheysens B, Auwerx J, Van den Eeckhout A, 1985. Cobalt-induced bronchial asthma in diamond polishers. Chest 88(5):740–744. 10.1378/chest.88.5.740.2996839
Gibbs RJ. 1994. Metals in the sediments along the Hudson River Estuary. Environ Int 20(4):507–516. 10.1016/0160-4120(94)90199-6.
Gibson DP, Brauninger R, Shaffi HS, 1997. Induction of micronuclei in Syrian hamster embryo cells: comparison to results in the SHE cell transformation assay for National Toxicology Program test chemicals. Mutat Res 392(1–2):61–70. 10.1016/s0165-1218(97)00045-1.9269331
Glahn F, Schmidt-Heck W, Zellmer S, 2008. Cadmium, cobalt and lead cause stress response, cell cycle deregulation and increased steroid as well as xenobiotic metabolism in primary normal human bronchial epithelial cells which is coordinated by at least nine transcription factors. Arch Toxicol 82(8):513–524. 10.1007/s00204-008-0331-9.18654764
Glooschenko WA, Capocianco J, Coburn J, 1981. Geochemical distribution of trace metals and organochlorine contaminants of a Lake Ontario shoreline marsh. Water Air Soil Pollut 15:197–213. 10.1007/BF00161253.
Gluhcheva Y, Atanasov V, Ivanova J, 2014. Chronic exposure to cobalt compounds - an in vivo study. Cent Eur J Biol 9(10):973–981. 10.2478/s11535-014-0334-x.
Gluhcheva Y, Pavlova E, Petrova E, 2020. The impact of perinatal cobalt chloride exposure on extramedullary erythropoiesis, tissue iron levels, and transferrin receptor expression in mice. Biol Trace Elem Res 194(2):423–431. 10.1007/s12011-019-01790-8.31273683
Goldner MG, Volk BW, Lazarus SS. 1952. The effect of cobaltous chloride on the blood sugar and alpha cells in the pancreatic islets of the rabbit. Metabolism 1:544–548.13002075
Goldoni M, Catalani S, De Palma G, 2004. Exhaled breath condensate as a suitable matrix to assess lung dose and effects in workers exposed to cobalt and tungsten. Environ Health Perspect 112(13):1293–1298. 10.1289/ehp.7108.15345342
Golomb D, Ryan D, Eby N, 1997. Atmospheric deposition of toxics onto Massachusetts Bay- I. Metals. Atmos Environ 31(9):1349–1359. 10.1016/S1352-2310(96)00276-2.
Goodwin DA, Meares CF. 1976. Radiolabeled antitumor agents. Semin Nucl Med 6(4):389–396. 10.1016/s0001-2998(76)80016-5.62401
Greathouse DG, Craun GF. 1978. Cardiovascular disease study - Occurrence of inorganics in household tap water and relationships to cardiovascular mortality rates. Trace Subst Environ Health 12:31–39.
Greenberg DM, Copp DH, Cuthbertson EM. 1943. Studies in mineral metabolism with the aid of artificial radioactive isotopes. VII. The distribution and excretion, particularly by way of the bile, of iron, cobalt, and manganese. J Biol Chem 147:749–756. 10.1016/S0021-9258(18)72374-0.
Gregersen E. 2023. Cobalt-60. In: Encyclopaedia Britannica. Encyclopaedia Britannica, Inc, online. https://www.britannica.com/science/cobalt-60. December 6, 2023.
Gregus Z, Klaassen CD. 1986. Disposition of metals in rats: A comparative study of fecal, urinary, and biliary excretion and tissue distribution of eighteen metals. Toxicol Appl Pharmacol 85:24–38. 10.1016/0041-008x(86)90384-4.3726885
Greig RA, Jones J. 1976. Nondestructive neutron activation analysis of marine organisms collected from ocean dump sites of the middle eastern United States. Arch Environ Contam Toxicol 4(4):420–434. 10.1007/BF02221039.999333
Grice HC, Goodman T, Munro IC, 1969. Myocardial toxicity of cobalt in the rat. Ann N Y Acad Sci 156(1):189–194. 10.1111/j.1749-6632.1969.tb16727.x.5291135
Gross RT, Kriss JP, Spaet TH. 1955. The hematopoletic and goltrogenic effects of cobaltous chloride in patients with sickle cell anemia. Pediatrics 15(3):284–290.14356800
Guieu C, Martin JM, Thomas AJ, 1991. Atmospheric versus river inputs of metals to the Gulf of Lions: Total concentrations, partitioning and fluxes. Mar Pollut Bull 22(4):176–183. 10.1016/0025-326X(91)90467-7.
Gumgum B, Unlu E, Tez Z, 1994. Heavy metal pollution in water, sediment and fish from the Tigris river in Turkey. Chemosphere 29(1):111–116. 10.1016/0045-6535(94)90094-9.8044627
Haddad E, Zikovsky L. 1985. Determination of Al, As, Co, Cr, Cs, Fe, Mn, Sb, Sc, W and Zn in the workroom air by instrumental neutron activation analysis. J Radioanal Nucl Chem 93(6):371–378. 10.1007/BF02210658.
Haga Y, Clyne N, Hatori N, 1996. Impaired myocardial function following chronic cobalt exposure in an isolated rat heart model. Trace Elem Electrolytes 13(2):69–74.
Hagvall L, Pour MD, Feng J, 2021. Skin permeation of nickel, cobalt and chromium salts in ex vivo human skin, visualized using mass spectrometry imaging. Toxicol In Vitro 76:105232. 10.1016/j.tiv.2021.105232.34365006
Hakanson R, Lundquist I, Sundler F. 1974. Elevated levels of insulin-like activity and 5-hydroxytryptamine in guinea pig pancreas following CoCl_2_ treatment. Endocrinology 94(2):318–324. 10.1210/endo-94-2-318.4810374
Hamel SC, Buckley B, Lioy PJ. 1998. Bioaccessibility of metals in soils for different liquid to solid ratios in synthetic gastric fluid. Environ Sci Technol 32(3):358–362. 10.1021/es9701422.
Hamilton EI. 1994. The geobiochemistry of cobalt. Sci Total Environ 150(1–3):7–39. 10.1016/0048-9697(94)90126-0.7939612
Hamilton-Koch W, Snyder RD, Lavelle JM. 1986. Mental-induced DNA damage and repair in human diploid fibroblasts and Chinese hamster ovary cells. Chem Biol Interact 59:17–28. 10.1016/S0009-2797(86)80052-7.3757145
Hamzah NA, Mohd Tamrin SB, Ismail NH. 2014. Metal dust exposure and respiratory health of male steel workers in Terengganu, Malaysia. Iran J Publ Health 43:154–166.
Han I, Richner D, An Han H, 2020. Evaluation of metal aerosols in four communities adjacent to metal recyclers in Houston, Texas, USA. J Air Waste Manag Assoc 70(5):568–579. 10.1080/10962247.2020.1755385.32315255
Hanafy S, Soltan ME. 2004. Effects of vitamin E pretreatment on subacute toxicity of mixture of Co, Pb, and Hg nitrate-induced nephrotoxicity in rats. Environ Toxicol Pharmacol 17(3):159–167. 10.1016/j.etap.2004.04.006.21782727
Hanini A, Massoudi ME, Gavard J, 2016. Nanotoxicological study of polyol-made cobalt-zinc ferrite nanoparticles in rabbit. Environ Toxicol Pharmacol 45:321–327. 10.1016/j.etap.2016.06.010.27375215
Hanna RGM. 1992. The level of heavy metals in the Red Sea after 50 years. Sci Total Environ 125:417–448. 10.1016/0048-9697(92)90405-H.
Hansen HS, Rygard J, Engelholm SA. 1976. Clinical use of combined bleomycin and radiation therapy for head and neck tumours and testicular cancers. Bull Cancer 68(3):371–378.
Hansen T, Clermont G, Alves A, 2006. Biological tolerance of different materials in bulk and nanoparticulate form in a rat model: sarcoma development by nanoparticles. J R Soc Interface 3(11):767–775. 10.1098/rsif.2006.0145.17015296
Hansson HC, Elkholm AKP, Ross HB. 1988. Rainwater analysis: A comparison between proton-induced x-ray emission and graphite furnace atomic absorption spectroscopy. Environ Sci Technol 22(5):527–531. 10.1021/es00170a007.22195622
Harding HE. 1950. Notes on the toxicology of cobalt metal. Br J Ind Med 7(2):76–78. 10.1136/oem.7.2.76.15414282
Harp MJ, Scoular FI. 1952. Cobalt metabolism of young college women on self-selected diets. J Nutr 47(1):67–72. 10.1093/jn/47.1.67.14939083
Hartwig A, Kasten U, Boakye-Dankwa K, 1990. Uptake and genotoxicity of micromolar concentrations of cobalt chloride in mammalian cells. Toxicol Environ Chem 28:205–215. 10.1080/02772249009357604.
Hartwig A, Snyder RD, Schlepegrell R, 1991. Modulation by Co(II) of UV-induced DNA repair, mutagenesis and sister-chromatid exchanges in mammalian cells. Mutat Res 248(1):177–185. 10.1016/0027-5107(91)90099-a.2030707
Hassan NHA, Fahmy MA, Farghaly AA, 2006. Antimutagenic effect of selenium and vitamins against the genotoxicity induced by cobalt chloride in mice. Cytologia 71(3):213–222. 10.1508/cytologia.71.213.
Haynes WM. 2015. [Cobalt]. In: CRC handbook of chemistry and physics: A ready-reference book of chemical and physical data. 95^th^ ed. Boca Raton, FL: CRC Press, 4.10, 14.59–14.61.
He J, Li J, Wu S, 2023. Accumulation of blood chromium and cobalt in the participants with metal objects: findings from the 2015 to 2018 National Health and Nutrition Examination Survey (NHANES). BMC Geriatr 23(1):72. 10.1186/s12877-022-03710-3.36737686
Heaton RW, Rahn KA, Lowenthal DH. 1990. Determination of trace elements, including regional tracers, in Rhode Island precipitation. Atmos Environ 24A(1):147–153. 10.1016/0960-1686(90)90450-2.
Hedbrant A, Eklund D, Andersson L, 2022. Effects on white blood cell counts and the NLRP3 inflammasome due to dust and cobalt exposure in the hard metal industry. Biomarkers 27(1):60–70. 10.1080/1354750x.2021.2013538.34872432
Hellou J, Fancey LL, Payne JF. 1992a. Concentrations of twenty-four elements in bluefin tuna, Thunnus thynnus from the Northwest Atlantic. Chemosphere 24(2):211–218. 10.1016/0045-6535(92)90394-7.
Helmers E, Schrems O. 1995. Wet deposition of metals to the tropical north and the south Atlantic Ocean. Atmos Environ 29(18):2475–2484. 10.1016/1352-2310(95)00159-V.
Hengstler JG, Bolm-Audorff U, Faldum A, 2003. Occupational exposure to heavy metals: DNA damage induction and DNA repair inhibition prove co-exposures to cadmium, cobalt and lead as more dangerous than hitherto expected. Carcinogenesis 24(1):63–73. 10.1093/carcin/24.1.63.12538350
Henquin JC, Lambert AE. 1975. Cobalt inhibition of insulin secretion and calcium uptake by isolated rat islets. Am J Physiol 228(6):1669–1677. 10.1152/ajplegacy.1975.228.6.1669.1098481
Henquin JC, Schmeer W, Meissner HP. 1983. Forskolin, an activator of adenylate cyclase, increases CA2+-dependent electrical activity induced by glucose in mouse pancreatic B cells. Endocrinology 112(6):2218–2220. 10.1210/endo-112-6-2218.6343063
Hewitt PJ. 1988. Accumulation of metals in the tissues of occupationally exposed workers. Environ Geochem Health 10(3–4):113–116. 10.1007/BF01758679.24213651
Hillerdal G, Hartung M. 1983. On cobalt in tissues from hard metal workers. Int Arch Occup Environ Health 53(1):89–90. 10.1007/BF00406180.6654505
Ho JH, Leikin JB, Dargan PI, 2017. Metal-on-metal hip joint prostheses: A retrospective case series investigating the association of systemic toxicity with serum cobalt and chromium concentrations. J Med Toxicol 13(4):321–328. 10.1007/s13181-017-0629-1.28900863
Hoet P, Jacquerye C, Deumer G, 2013. Reference values and upper reference limits for 26 trace elements in the urine of adults living in Belgium. Clin Chem Lab Med 51(4):839–849. 10.1515/cclm-2012-0688.23314559
Hoffmeister T, Schwenke D, Krug O, 2018. Effects of 3 weeks of oral low-dose cobalt on hemoglobin mass and aerobic performance. Front Physiol 9:1289. 10.3389/fphys.2018.01289.30283349
Hoffmeister T, Schwenke D, Wachsmuth N, 2019. Erythropoietic effects of low-dose cobalt application. Drug Test Anal 11(2):200–207. 10.1002/dta.2478.30110719
Holcombe LJ, Eynon BP, Switzer P. 1985. Variability of elemental concentrations in power plant ash. Environ Sci Technol 19(7):615–620. 10.1021/es00137a006.22148304
Hollins JG, McCullough RS. 1971. Radiation dosimetry of internal contamination by inorganic compounds of cobalt: an analysis of cobalt metabolism in rats. Health Phys 21(2):233–246. 10.1097/00004032-197108000-00010.5094193
Holly RG. 1955. Studies on iron and cobalt metabolism. J Am Med Assoc 158(15):1349–1352. 10.1001/jama.1955.02960150019005.13242351
Holy CE, Zhang S, Perkins LE, 2022. Site-specific cancer risk following cobalt exposure via orthopedic implants or in occupational settings: A systematic review and meta-analysis. Regul Toxicol Pharmacol 129:105096. 10.1016/j.yrtph.2021.105096.34896478
Hong HH, Hoenerhoff MJ, Ton TV, 2015. Kras, Egfr, and Tp53 mutations in B6C3F1/N mouse and F344/NTac rat alveolar/bronchiolar carcinomas resulting from chronic inhalation exposure to cobalt metal. Toxicol Pathol 43(6):872–882. 10.1177/0192623315581192.26059825
Horiguchi H, Oguma E, Nomoto S, 2004. Acute exposure to cobalt induces transient methemoglobinuria in rats. Toxicol Lett 151(3):459–466. 10.1016/j.toxlet.2004.03.018.15261990
Horng CJ, Horng PH, Hsu JW, 2003. Simultaneous determination of urinary cadmium, cobalt, lead, and nickel concentrations in steel production workers by differential pulse stripping voltammetry. Arch Environ Health 58(2):104–110. 10.3200/AEOH.58.2.104-110.12899211
Houeto P, Houze P, Baud FJ. 2018. Comparative study of the tissue distribution of equimolar repeated doses of hydroxocobalamin and cobalt chloride in the rats. Ann Biol Clin (Paris) 76(2):179–184. 10.1684/abc.2017.1318.29623888
Houk AEH, Thomas AW, Sherman HC. 1946. Some interrelationships of dietary iron, copper and cobalt in metabolism. J Nutr 31:609–620. 10.1093/jn/31.5.609.20983450
Hu X, Zheng T, Cheng Y, 2015. Distributions of heavy metals in maternal and cord blood and the association with infant birth weight in China. J Reprod Med 60(1–2):21–29.25745747
Huber AL, Loving TJ. 1991. Fatal asthma attack after inhaling sulfur fumes. JAMA 266(16):2225.
Hussien NA, Mohamed HRH. 2018. The protective role of omega-3 against genotoxicity and reproductive toxicity of cobalt oxide nanoparticles acute treatment in male mice. Asian J Pharmaceut Clin Res 11(5):423. 10.22159/ajpcr.2018.v11i5.25245.
Hutter HP, Wallner P, Moshammer H, 2016. Dust and cobalt levels in the Austrian tungsten industry: Workplace and human biomonitoring data. Int J Environ Res Public Health 13(9):931. 10.3390/ijerph13090931.27657104
Huy TXN, Nguyen TT, Reyes AWB, 2022. Cobalt (II) chloride regulates the invasion and survival of Brucella abortus 544 in RAW 264.7 cells and B6 mice. Pathogens 11(5):596. 10.3390/pathogens11050596.35631117
IAEA. 1982. Elemental composition of human and animal milk: A review. . Vienna, Italy: International Atomic Energy Agency. World Health Organization. IAEA-TECDOC-269. https://inis.iaea.org/collection/NCLCollectionStore/_Public/14/767/14767925.pdf. December 7, 2023.
IARC. 1991. Chlorinated drinking-water; chlorination by-products; some other halogenated compounds; cobalt and cobalt compounds. IARC monographs on the evaluation of carcinogenic risks to humans. Vol. 52. Lyon, France: World Health Organization, International Agency for Research on Cancer. 125–127, 363–450. https://monographs.iarc.who.int/wp-content/uploads/2018/06/mono52.pdf.December 6, 2023.
IARC. 2006. Cobalt in hard metals and cobalt sulfate, gallium arsenide, indium phosphide and vanadium pentoxide. IARC monographs on the identification of carcinogenic hazards to humans. Vol. 86. Lyon, France: International Agency for Research on Cancer, World Health Organization. https://publications.iarc.fr/104. February 7, 2024.
IARC. 2023. Cobalt, antimony compounds, and weapons-grade tungsten alloy. IARC monographs on the identification of carcinogenic hazards to humans. Vol. 131. Lyon, France: International Agency for Research on Cancer, World Health Organization. 49–355. https://publications.iarc.fr/618. February 6, 2024.
Iarmarcovai G, Sari-Minodier I, Chaspoul F, 2005. Risk assessment of welders using analysis of eight metals by ICP-MS in blood and urine and DNA damage evaluation by the comet and micronucleus assays; influence of XRCC1 and XRCC3 polymorphisms. Mutagenesis 20(6):425–432. 10.1093/mutage/gei058.16234265
Ichikawa Y, Kusaka Y, Goto S. 1985. Biological monitoring of cobalt exposure, based on cobalt concentrations in blood and urine. Int Arch Occup Environ Health 55(4):269–276. 10.1007/BF00377685.4008051
ICRP. 1979. Limits for intakes of radionuclides by workers. Annals of the ICRP. Vol. 2(3/4). New York: Pergamon Press, International Commission on Radiological Protection. https://www.icrp.org/publication.asp?id=ICRP%20Publication%2030%20(Part%201). December 6, 2023.
ICRP. 1994. Human respiratory tract model for radiological protection. Pergamon Press. International Commission on Radiological Protection. ICRP Publication 66. https://journals.sagepub.com/doi/pdf/10.1177/ANIB_24_1-3. December 6, 2023.
ICRP. 1995. Cobalt. International Commission on Radiological Protection. Ann ICRP 25(3–4):19–25. https://www.icrp.org/publication.asp?id=ICRP%20Publication%2071. December 8, 2023.
ICRP. 2016. ICRP Publication 134: Occupational intakes of radionuclides: Part 2. International Commission on Radiological Protection. Ann ICRP 45(3–4):7–349. 10.1177/0146645316670045.
Ikarashi Y, Ohno K, Tsuchiya T, 1992a. Differences of draining lymph node cell proliferation among mice, rats and guinea pigs following exposure to metal allergens. Toxicology 76:283–292. 10.1016/0300-483X(92)90196-L.1471161
Ikarashi Y, Tsuchiya T, Nakamura A. 1992b. Detection of contact sensitivity of metal salts using the murine local lymph node assay. Toxicol Lett 62:53–61. 10.1016/0378-4274(92)90078-X.1509507
Imbrogno P, Alborghetti F. 1994. Evaluation and comparison of the levels of occupational exposure to cobalt during dry and/or wet hard metal sharpening. Environmental and biological monitoring. Sci Total Environ 150:259–262. 10.1016/0048-9697(94)90163-5.7939606
Inaba J, Suzuki-Yasumoto M. 1979. A kinetic study of radionuclide absorption through damaged and undamaged skin of the guinea pig. Health Phys 37(4):592–595.536221
Inaba J, Nishimura Y, Ichikawa R. 1980. Comparative metabolism of ^54^Mn, ^59^Fe, ^60^Co and ^65^Zn incorporated into Chlorella and in inorganic form in rats. Health Phys 39:611–617. 10.1097/00004032-198010000-00003.7429866
Inozemtsev AN, Bokieva SB, Karpukhina OV, 2008. Effects of combined treatment with heavy metals and piracetam on learning and memory in rats. Dokl Biol Sci 422:301–304. 10.1134/s0012496608050062.19024677
IRIS. 2023. Cobalt and cobalt compounds. Integrated Risk Information System: Chemical landing page. Washington, DC: U.S. Environmental Protection Agency. https://iris.epa.gov/ChemicalLanding/&substance_nmbr=708. November 27, 2023.
Ishihara N, Yoshida A, Koizumi M. 1987. Metal concentrations in human pancreatic juice. Arch Environ Health 42(6):356–360. 10.1080/00039896.1987.9934359.3439813
Jackman AP, Kennedy VC, Bhatia N. 2001. Interparticle migration of metal cations in stream sediments as a factor in toxics transport. J Hazard Mater B 82:27–41. 10.1016/s0304-3894(00)00349-6.
Jacobziner H, Raybin HW. 1961. Poison control... Accidental cobalt poisoning. Arch Pediatr 78:200–205.
James AC, Stahlhofen W, Rudolf G, 1994. Annexe D. Deposition of inhaled particles. Ann ICRP 24(1–3):231–299. 10.1016/0146-6453(94)90042-6.
Jansen HM, Knollema S, van der Duin LV, 1996. Pharmacokinetics and dosimetry of cobalt-55 and cobalt-57. J Nucl Med 37(12):2082–2086.8970539
Jefferson JA, Escudero E, Hurtado ME, 2002. Excessive erythrocytosis, chronic mountain sickness, and serum cobalt levels. Lancet 359(9304):407–408. 10.1016/s0140-6736(02)07594-3.11844517
Jervois. 2024. Idaho cobalt operations. Jervois. https://jervoisglobal.com/projects/idaho-cobalt-operations/. September 30, 2024.
Jin R, Zhu X, Shrubsole MJ, 2018. Associations of renal function with urinary excretion of metals: Evidence from NHANES 2003–2012. Environ Int 121(Pt 2):1355–1362. 10.1016/j.envint.2018.11.002.30442456
Johansson A, Robertson B, Camner P. 1987. Nodular accumulation of type II cells and inflammatory lesions caused by inhalation of low cobalt concentrations. Environ Res 43(1):227–243. 10.1016/s0013-9351(87)80074-9.3582309
Johansson A, Curstedt T, Camner P. 1991. Lung lesions after combined inhalation of cobalt and nickel. Environ Res 54(1):24–38. 10.1016/s0013-9351(05)80192-6.2004635
Johansson A, Curstedt T, Rasool O, 1992. Rabbit lung after combined exposure to soluble cobalt and trivalent chromium. Environ Res 58(1):80–96. 10.1016/s0013-9351(05)80206-3.1597170
Jorhem L, Sundstrom B. 1993. Levels of lead, cadmium, zinc, copper, nickel, chromium, manganese, and cobalt in foods on the Swedish market, 1983–1990. J Food Compost Anal 6:223–241. 10.1006/jfca.1993.1025.
Julander A, Skare L, Mulder M, 2010. Skin deposition of nickel, cobalt, and chromium in production of gas turbines and space propulsion components. Ann Occup Hyg 54(3):340–350. 10.1093/annhyg/meq002.20150401
Junque E, Grimalt JO, Fernandez-Somoano A, 2020. Urinary cobalt and ferritin in four-years-old children. Environ Res 183:109147. 10.1016/j.envres.2020.109147.32000000
Kada T, Kanematsu N. 1978. Reduction of N-methyl-N'-nitro-N-nitrosoguanidine-induced mutations by cobalt chloride in Escherichia coli. Proc Japan Acad Ser B 54B:234–237.
Kakinuma J, Orii H. 1982. DNA interaction with 57Co-bleomycin. Nuklearmedizin 21(6):232–235.6188112
Kanematsu N, Hara M, Kada T. 1980. Rec assay and mutagenicity studies on metal compounds. Mutat Res 77(2):109–116. 10.1016/0165-1218(80)90127-5.6769036
Kapstad B. 1978. Treatment of squamous cell carcinomas of the head and neck region with cobalt and bleomycin. Int J Radiat Oncol Biol Phys 4(1–2):91–94. 10.1016/0360-3016(78)90121-9.75879
Kapstad B. 1979. Cobalt and bleomycin against carcinomas of head and neck. A controlled clinical study. Acta Otolaryngol Suppl 360:171–173. 10.3109/00016487809123507.88161
Karduri RKR. 2023. Cobalt in battery production: implications for the mining community. Int J Adv Res Basic Eng Sci Technol 10(11):9–15.
Kargar F, Shahtaheri SJ, Golbabaei F, 2013. Evaluation of occupational exposure of glazers of a ceramic industry to cobalt blue dye. Iran J Publ Health 42(8):868–875.
Kasprzak KS, Zastawny TH, North SL, 1994. Oxidative DNA base damage in renal, hepatic, and pulmonary chromatin of rats after intraperitoneal injection of cobalt(II) acetate. Chem Res Toxicol 7(3):329–335. 10.1021/tx00039a009.8075364
Kasten U, Mullenders LH, Hartwig A. 1997. Cobalt(II) inhibits the incision and the polymerization step of nucleotide excision repair in human fibroblasts. Mutat Res 383(1):81–89. 10.1016/s0921-8777(96)00052-3.9042422
Kawakami T, Hanao N, Nishiyama K, 2012. Differential effects of cobalt and mercury on lipid metabolism in the white adipose tissue of high-fat diet-induced obesity mice. Toxicol Appl Pharmacol 258(1):32–42. 10.1016/j.taap.2011.10.004.22019852
Kaya B, Creus A, Velazquez A, 2002. Genotoxicity is modulated by ascorbic acid. Studies using the wing spot test in Drosophila. Mutat Res 520(1–2):93–101. 10.1016/s1383-5718(02)00173-0.12297148
Kayembe-Kitenge T, Nkulu CBL, Musanzayi SM, 2023. Transplacental transfer of cobalt: Evidence from a study of mothers and their neonates in the African Copperbelt. J Trace Elem Med Biol 80:127294. 10.1016/j.jtemb.2023.127294.37677922
Kennedy KJ, Esmen NA, Buchanich JM, 2017. Mortality among hardmetal production workers: Occupational exposures. J Occup Environ Med 59(12):e297–e305. 10.1097/JOM.0000000000001068.28704227
Kent NL, McCance RA. 1941. The absorption and excretion of 'minor' elements by man: Silver, gold, lithium, boron and vanadium. Biochem J 35(7):837–844. 10.1042/bj0350837.16747371
Kerfoot EJ. 1974. Semi-chronic inhalation study on cobalt: a dissertation. Doctorate in Philosophy: Physiology. Ann Arbor, MI: Wayne State University.
Kesteloot H, Roelandt J, Willems J, 1968. An enquiry into the role of cobalt in the heart disease of chronic beer drinkers. Circulation 37(5):854–864. 10.1161/01.cir.37.5.854.5646867
Kettelarij J, Nilsson S, Midander K, 2016. Snapshot of cobalt, chromium and nickel exposure in dental technicians. Contact Dermatitis 75(6):370–376. 10.1111/cod.12681.27633504
Kettelarij J, Midander K, Liden C, 2018a. Contamination of skin and surfaces by cobalt in the hard metal industry. Contact Dermatitis 79(4):226–231. 10.1111/cod.13056.30009432
Kettelarij J, Midander K, Liden C, 2018b. Neglected exposure route: cobalt on skin and its associations with urinary cobalt levels. Occup Environ Med 75(11):837–842. 10.1136/oemed-2018-105099.30173144
Khalil SR, El Bohi KM, Khater S, 2020. Moringa oleifera leaves ethanolic extract influences DNA damage signaling pathways to protect liver tissue from cobalt -triggered apoptosis in rats. Ecotoxicol Environ Saf 200:110716. 10.1016/j.ecoenv.2020.110716.32450433
Khan MR, Ahmad N, Ouladsmane M, 2021. Heavy metals in acrylic color paints intended for the school children use: a potential threat to the children of early age. Molecules 26(8):2375. 10.3390/molecules26082375.33921808
Khan MU, Ahmed M, Nazim K, 2022. Bioaccumulation of heavy metals in Poecilia reticulata (guppy fish): an important biotic component of food chain. J Black Sea/Mediterr Environ 28(1):97–110.
Kharab P, Singh I. 1985. Genotoxic effects of potassium dichromate, sodium arsenite, cobalt chloride and lead nitrate in diploid yeast. Mutat Res 155(3):117–120. 10.1016/0165-1218(85)90128-4.3883155
Killey RW, McHugh JO, Champ DR, 1984. Subsurface cobalt-60 migration from a low-level waste disposal site. Environ Sci Technol 18(3):148–157. 10.1021/es00121a004.22263727
Kim EY, Goto R, Tanabe S, 1998. Distribution of 14 elements in tissues and organs of oceanic seabirds. Arch Environ Contam Toxicol 35(4):638–645. 10.1007/s002449900426.9776782
Kincaid JF, Strong JS, Sunderman FW. 1954. Toxicity studies of cobalt carbonyls. AMA Arch Ind Health 10(3):210–212.13196697
King LD. 1988. Retention of metals by several soils of the southeastern United States. J Environ Qual 17(2):239–246. 10.2134/jeq1988.00472425001700020013x.
Kinoshita K, Fujita T. 1972. Metabolism of ^57^Co-methylcobalamin in rat and guinea pig. Chem Pharm Bull 20(12):2561–2569. 10.1248/cpb.20.2561.
Kirchgessner M, Reuber S, Kreuzer M. 1994. Endogenous excretion and true absorption of cobalt as affected by the oral supply of cobalt. Biol Trace Elem Res 41:175–189. 10.1007/BF02917227.7946905
Kirkland D, Brock T, Haddouk H, 2015. New investigations into the genotoxicity of cobalt compounds and their impact on overall assessment of genotoxic risk. Regul Toxicol Pharmacol 73(1):311–338. 10.1016/j.yrtph.2015.07.016.26210821
Klasson M, Lindberg M, Bryngelsson IL, 2017. Biological monitoring of dermal and air exposure to cobalt at a Swedish hard metal production plant: does dermal exposure contribute to uptake? Contact Dermatitis 77(4):201–207. 10.1111/cod.12790.28675438
Kloke A, Sauerbeck DR, Vetter H. 1984. The contamination of plants and soils with heavy metals and the transport of metals in terrestrial food chains. In: Nriagu JO, ed. Changing metal cycles and human health. Berlin, Germany: Springer-Verlag, 113–141.
Knauer GA, Martin JH, Gordon RM. 1982. Cobalt in north-east Pacific waters. Nature 297(5861):49–51. 10.1038/297049a0.
Knopfel M, Smith C, Solioz M. 2005. ATP-driven copper transport across the intestinal brush border membrane. Biochem Biophys Res Commun 330(3):645–652. 10.1016/j.bbrc.2005.03.023.15809046
Knutson AB, Klerks PL, Levinton JS. 1987. The fate of metal contaminated sediments in Foundry Cove, New York. Environ Pollut 45(4):291–304. 10.1016/0269-7491(87)90103-5.15092747
Kocylowski R, Grzesiak M, Gaj Z, 2019. Associations between the level of trace elements and minerals and folate in maternal serum and amniotic fluid and congenital abnormalities. Nutrients 11(2):328. 10.3390/nu11020328.30717440
Kokelj F, Daris F, Lutmann A, 1994. Nickel, chromate and cobalt in toilet soaps analyzed by inductively coupled plasma mass spectrometry. Contact Dermatitis 31:270. 10.1111/j.1600-0536.1994.tb02009.x.7842693
Koponen M, Gustafsson T, Kalliomaki P- L. 1982. Cobalt in hard metal manufacturing dusts. Am Ind Hyg Assoc J 43(9):645–651. 10.1080/15298668291410350.
Kopp B, Zalko D, Audebert M. 2018. Genotoxicity of 11 heavy metals detected as food contaminants in two human cell lines. Environ Mol Mutagen 59(3):202–210. 10.1002/em.22157.29150881
Kovacheva-Ninova VK, Savov GM, Vassileva V, 2018. Trends in the development of cobalt production. Electrotech Electron 53:84–94.
Krakowiak A, Dudek W, Tarkowski M, 2005. Occupational asthma caused by cobalt chloride in a diamond polisher after cessation of occupational exposure: a case report. Int J Occup Med Environ Health 18(2):151–158.16201206
Krasovskii GN, Fridlyand SA. 1971. Experimental data for the validation of the maximum permissible concentration of cobalt in water bodies. Hyg Sanit 26:277–279.
Krecisz B, Kiec-Swierczynska M, Krawczyk P, 2009. Cobalt-induced anaphylaxis, contact urticaria, and delayed allergy in a ceramics decorator. Contact Dermatitis 60(3):173–174. 10.1111/j.1600-0536.2008.01465.x.19260918
Kreyling WG. 1990. Interspecies comparison of lung clearance of "insoluble" particles. J Aerosol Med 3(S1):S93–S110. 10.1089/jam.1990.3.Suppl_1.S-93.
Kreyling WG, Ferron GA, Haider B. 1984. Lung retention and clearance of cobalt oxide particles depending on their physicochemical parameters. EUR 9384:141–146.
Kreyling WG, Ferron GA, Haider B. 1986. Metabolic fate of inhaled Co aerosols in beagle dogs. Health Phys 51(6):773–795. 10.1097/00004032-198612000-00007.3781852
Kreyling WG, Ferron GA, Haider B. 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles- Part IV: Lung clearance of inhaled cobalt oxide particles in beagle dogs. J Aerosol Sci 20(2):219–232. 10.1016/0021-8502(89)90045-1.
Kreyling WG, André S, Collier CG, 1991. Interspecies comparison of lung clearance after inhalation of monodisperse, solid cobalt oxide aerosol particles. J Aerosol Sci 22(4):509–535. 10.1016/0021-8502(91)90008-6.
Kriss JP, Carnes WH, Gross RT. 1955. Hypothyroidism and thyroid hyperplasia in patients treated with cobalt. J Am Med Assoc 157(2):117–121. 10.1001/jama.1955.02950190017004.13211322
Kumagai S, Kusaka Y, Goto S. 1996. Cobalt exposure level and variability in the hard metal industry of Japan. Am Ind Hyg Assoc J 57(4):365–369. 10.1080/15428119691014909.8901238
Kusaka Y, Ichikawa Y, Shirakawa T, 1986a. Effect of hard metal dust on ventilatory function. Br J Ind Med 43(7):486–489. 10.1136/oem.43.7.486.3718896
Kusaka Y, Yokoyama K, Sera Y, 1986b. Respiratory diseases in hard metal workers: an occupational hygiene study in a factory. Br J Ind Med 43(7):474–485. 10.1136/oem.43.7.474.3718895
Kyono H, Kusaka Y, Homma K, 1992. Reversible lung lesions in rats due to short-term exposure to ultrafine cobalt particles. Ind Health 30(3–4):103–118. 10.2486/indhealth.30.103.1301410
Lacy SA, Merritt K, Brown SA, 1996. Distribution of nickel and cobalt following dermal and systemic administration with in vitro and in vivo studies. J Biomed Mater Res 32(2):279–283. 10.1002/(SICI)1097-4636(199610)32:2<279::AID-JBM18>3.0.CO;2-E.8884506
Lai CH, Ho SC, Pan CH, 2021. Chronic exposure to metal fume PM(2.5) on inflammation and stress hormone cortisol in shipyard workers: A repeat measurement study. Ecotoxicol Environ Saf 215:112144. 10.1016/j.ecoenv.2021.112144.33743405
Laing ME, Hackett CB, Murphy GM. 2005. Unusual allergen in nurse uniform trousers. Contact Dermatitis 52(5):293. 10.1111/j.0105-1873.2005.0573i.x.
Lam CW, Castranova V, Driscoll K, 2023. A review of pulmonary neutrophilia and insights into the key role of neutrophils in particle-induced pathogenesis in the lung from animal studies of lunar dusts and other poorly soluble dust particles. Crit Rev Toxicol 53(8):441–479. 10.1080/10408444.2023.2258925.37850621
Lantin AC, Mallants A, Vermeulen J, 2011. Absence of adverse effect on thyroid function and red blood cells in a population of workers exposed to cobalt compounds. Toxicol Lett 201(1):42–46. 10.1016/j.toxlet.2010.12.003.21182909
Lantin AC, Vermeulen J, Mallants A, 2013. Occupational exposure to cobalt is not associated with incipient signs of dilated cardiomyopathy in a Belgian refinery. Occup Environ Med 70(6):386–392. 10.1136/oemed-2012-100930.23503418
Lantzy RJ, Mackenzie FT. 1979. Atmospheric trace metals: global cycles and assessment of man's impact. Geochim Cosmochim Acta 43:511–525. 10.1016/0016-7037(79)90162-5.
Lasfargues G, Wild P, Moulin JJ, 1994. Lung cancer mortality in a French cohort of hard-metal workers. Am J Ind Med 26(5):585–595. 10.1002/ajim.4700260502.7832207
Lasfargues G, Lardot C, Delos M, 1995. The delayed lung responses to single and repeated intratracheal administration of pure cobalt and hard metal powder in the rat. Environ Res 69:108–121. 10.1006/enrs.1995.1032.8608770
Lazarus SS, Goldner MG, Volk BW. 1953. Selective destruction of pancreatic alpha cells by cobaltous chloride in the dog; physiologic implications. Metabolism 2(6):513–520.13110759
Lee JN, Kim SG, Lim JY, 2016. 3-Aminotriazole protects from CoCl2-induced ototoxicity by inhibiting the generation of reactive oxygen species and proinflammatory cytokines in mice. Arch Toxicol 90(4):781–791. 10.1007/s00204-015-1506-9.25820916
Lee YS, Sung JH, Song KS, 2019. Derivation of occupational exposure limits for multi-walled carbon nanotubes and graphene using subchronic inhalation toxicity data and a multi-path particle dosimetry model. Toxicol Res (Camb) 8(4):580–586. 10.1039/c9tx00026g.31367339
Leggett RW. 2008. The biokinetics of inorganic cobalt in the human body. Sci Total Environ 389(2–3):259–269. 10.1016/j.scitotenv.2007.08.054.17920105
Legostaeva GA, Zaksas NP, Gluhcheva YG, 2013. Effect of CoCl(2) on the content of different metals and a relative activity of DNA-hydrolyzing abzymes in the blood plasma of mice. J Mol Recognit 26(1):10–22. 10.1002/jmr.2217.23280613
Leikin JB, Karydes HC, Whiteley PM, 2013. Outpatient toxicology clinic experience of patients with hip implants. Clin Toxicol (Phila) 51(4):230–236. 10.3109/15563650.2013.768343.23421810
Lenntech. 2023. Chemistry of cobalt. Lenntech B.V. https://www.lenntech.com/periodic/elements/co.htm. December 6, 2023.
Leonard KS, McCubbin D, Harvey BR. 1993a. Chemical speciation and environmental behaviour of ^60^Co discharged from a nuclear establishment. J Environ Radioact 20:1–21. 10.1016/0265-931X(93)90015-Y.
Leonard KS, McCubbin D, Harvey BR. 1993b. A radiochemical procedure for the determination and speciation of radiocobalt in environmental waters. Sci Total Environ 130/131:237–251. 10.1016/0048-9697(93)90078-K.
Leyssens L, Vinck B, Van Der Straeten C, 2020. The ototoxic potential of cobalt from metal-on-metal hip implants: Objective auditory and vestibular outcome. Ear Hear 41(1):217–230. 10.1097/AUD.0000000000000747.31169566
Leyssens L, Vinck B, Van Der Straeten C, 2021. The ototoxic potential of cobalt from metal-on-metal hip implants: a pilot study on the patient-reported auditory, vestibular, and general neurological outcome. Int J Audiol 60(1):44–53. 10.1080/14992027.2020.1789922.32687006
Li P, Ding D, Salvi R, 2015. Cobalt-induced ototoxicity in rat postnatal cochlear organotypic cultures. Neurotox Res 28(3):209–221. 10.1007/s12640-015-9538-8.26153487
Li L, Mok H, Jhaveri P, 2018. Anticancer therapy and lung injury: molecular mechanisms. Expert Rev Anticancer Ther 18(10):1041–1057. 10.1080/14737140.2018.1500180.29996062
Lichtenstein ME, Bartl F, Pierce RT. 1975. Control of cobalt exposures during wet process tungsten carbide grinding. Am Ind Hyg Assoc J 36(12):879–885. 10.1080/0002889758507360.1211358
Linauskiene K, Dahlin J, Ezerinskis Z, 2021. Occupational exposure to nickel, cobalt, and chromium in the Lithuanian hard metal industry. Contact Dermatitis 84(4):247–253. 10.1111/cod.13756.33277692
Linna A, Oksa P, Palmroos P, 2003. Respiratory health of cobalt production workers. Am J Ind Med 44(2):124–132. 10.1002/ajim.10258.12874844
Linna A, Oksa P, Groundstroem K, 2004. Exposure to cobalt in the production of cobalt and cobalt compounds and its effect on the heart. Occup Environ Med 61(11):877–885. 10.1136/oem.2003.009605.15477280
Linna A, Uitti J, Oksa P, 2020. Effects of occupational cobalt exposure on the heart in the production of cobalt and cobalt compounds: a 6-year follow-up. Int Arch Occup Environ Health 93(3):365–374. 10.1007/s00420-019-01488-3.31745627
Linnainmaa M, Kangas J, Kalliokoski P. 1996. Exposure to airborne metals in the manufacture and maintenance of hard metal and stellite blades. Am Ind Hyg Assoc J 57(2):196–201. 10.1080/15428119691015142.8615327
Lisk DJ, Gutenmann WH, Rutzke M, 1992. Survey of toxicants and nutrients in composted waste materials. Arch Environ Contam Toxicol 22:190–194. 10.1007/BF00213284.
Lison D. 2015. Cobalt. In: Nordberg GF, Fowler BA, Nordberg M, eds. Handbook on the toxicology of metals. 4^th^ ed. San Diego: Academic Press, 743–763. 10.1016/B978-0-444-59453–2.00034-2.
Lison D, Buchet JP, Swennen B, 1994. Biological monitoring of workers exposed to cobalt metal, salt, oxides, and hard metal dust. Occup Environ Med 51(7):447–450. 10.1136/oem.51.7.447.8044242
Lison D, Carbonnelle P, Mollo L, 1995. Physicochemical mechanism of the interaction between cobalt metal and carbide particles to generate toxic activated oxygen species. Chem Res Toxicol 8:600–606. 10.1021/tx00046a015.7548741
Lison D, Lauwerys R, Demedts M, 1996. Experimental research into the pathogenesis of cobalt/hard metal lung disease. Eur Respir J 9:1024–1028. 10.1183/09031936.96.09051024.8793467
Little JA, Sunico R. 1958. Cobalt-induced goiter with cardiomegaly and congestive failure. J Pediatr 52(3):284–288. 10.1016/s0022-3476(58)80117-1.13526084
Liu S, Hammond SK, Rojas-Cheatham A. 2013. Concentrations and potential health risks of metals in lip products. Environ Health Perspect 121(6):705–710. 10.1289/ehp.1205518.23674482
Llobet JM, Domingo JL, Corbella J. 1988. Comparative effects of repeated parenteral administration of several chelators on the distribution and excretion of cobalt. Res Commun Chem Pathol Pharmacol 60(2):225–233.2839877
Looker AC, Dallman PR, Carroll MD, 1997. Prevalence of iron deficiency in the United States. JAMA 277(12):973–976. 10.1001/jama.1997.03540360041028.9091669
Loven K, Isaxon C, Ahlberg E, 2023. Size-resolved characterization of particles >10 nm emitted to air during metal recycling. Environ Int 174:107874. 10.1016/j.envint.2023.107874.36934572
Lukac N, Massanyi P, Zakrzewski M, 2007. Cobalt-induced alterations in hamster testes in vivo. J Environ Sci Health A Tox Hazard Subst Environ Eng 42(3):389–392. 10.1080/10934520601144709.17365306
Mackie JA, Natali SM, Levinton JS, 2007. Declining metal levels at Foundry Cove (Hudson River, New York): response to localized dredging of contaminated sediments. Environ Pollut 149(2):141–148. 10.1016/j.envpol.2007.01.010.17382440
Maenhaut W, Zoller WH, Duce RA, 1979. Concentration and size distribution of particulate trace elements in the South Polar atmosphere. J Geophys Res 84(C5):2421–2431. 10.1029/JC084iC05p02421.
Mahara Y, Kudo A. 1981. Interaction and mobility of cobalt-60 between water and sediments in marine environments possible effects by acid rain. Water Res 15(4):413–419. 10.1016/0043-1354(81)90051-8.
Mandervelt C, Clottens FL, Demedts M, 1997. Assessment of the sensitization potential of five metal salts in the murine local lymph node assay. Toxicology 120(1):65–73. 10.1016/s0300-483x(97)03629-9.9160110
Mantoura RFC, Dickson A, Riley JP. 1978. The complexation of metals with humic materials in natural waters. Estuarine Coastal Shelf Sci 6:387–408. 10.1016/0302-3524(78)90130-5.
Marsh GM, Buchanich JM, Zimmerman S, 2017a. Mortality among hardmetal production workers: US cohort and nested case-control studies. J Occup Environ Med 59(12):e306–e326. 10.1097/JOM.0000000000001075.29215485
Marsh GM, Buchanich JM, Zimmerman S, 2017b. Mortality among hardmetal production workers: Pooled analysis of cohort data from an international investigation. J Occup Environ Med 59(12):e342–e364. 10.1097/JOM.0000000000001151.29215487
Marshall E. 1984. Juarez: an unprecedented radiation accident. Science 223(4641):1152–1154. 10.1126/science.6701516.6701516
Mateuca R, Aka PV, De Boeck M, 2005. Influence of hOGG1, XRCC1 and XRCC3 genotypes on biomarkers of genotoxicity in workers exposed to cobalt or hard metal dusts. Toxicol Lett 156(2):277–288. 10.1016/j.toxlet.2004.12.002.15737490
Mathur N, Jain GC, Pandey G. 2011. Hepatotoxicity of cobalt chloride in albino rat. Pharmacologyonline 2:179–185.
Mayfield KP, Lai J, Porreca F. 1994. Selective upregulation of opioid delta receptors in NG 108–15 cells by treatment with cobalt: Possible hypoxic regulation. Regul Peptides 54(1):183–184.
McElvenny DM, MacCalman LA, Sleeuwenhoek A, 2017. Mortality among hardmetal production workers: UK cohort and nested case-control studies. J Occup Environ Med 59(12):e275–e281. 10.1097/JOM.0000000000001036.28697060
McLaren RG, Lawson DM, Swift RS. 1986. Sorption and desorption of cobalt by soils and soil components. J Soil Sci 37:413–426. 10.1111/j.1365-2389.1986.tb00374.x.
McLean RI, Summers JK. 1990. Evaluation of transport and storage of 60Co, 134Cs, 137Cs and 65Zn by river sediments in the lower Susquehanna River. Environ Pollut 63(2):137–153. 10.1016/0269-7491(90)90064-j.15092325
Medyńska-Juraszek A, Cwielag-Piasecka I, Jerzykiewicz M, 2020. Wheat straw biochar as a specific sorbent of cobalt in soil. Materials (Basel) 13(11):2462. 10.3390/ma13112462.32481699
Meltzer HM, Brantsaeter AL, Borch-Iohnsen B, 2010. Low iron stores are related to higher blood concentrations of manganese, cobalt and cadmium in non-smoking, Norwegian women in the HUNT 2 study. Environ Res 110(5):497–504. 10.1016/j.envres.2010.03.006.20381026
Meranger JC, Subramanian KS, Chalifoux C. 1981. Survey for cadmium, cobalt, chromium, copper, nickel, lead, zinc, calcium, and magnesium in Canadian drinking water supplies. J Assoc Off Anal Chem 64(1):44–53.7204309
Merian E. 1985. Introduction on environmental chemistry and global cycles of chromium, nickel, cobalt, beryllium, arsenic, cadmium and selenium, and their derivatives. Curr Top Environ Toxicol Chem 8:3–32. 10.1080/02772248409357038.
Mermut AR, Jain JC, Song L, 1996. Trace element concentrations of selected soils and fertilizers in Saskatchewan, Canada. J Environ Qual 25:845–853. 10.2134/jeq1996.00472425002500040028x.
Meyer-Bisch C, Pham QT, Mur JM, 1989. Respiratory hazards in hard metal workers: a cross sectional study. Br J Ind Med 46(5):302–309. 10.1136/oem.46.5.302.2787666
Michée IB, Merveille K, Tresort K, 2023. Assessment of soil pollution by metallic trace elements (MTE): case of environment of Ruashi Mining/Haut-Katanga (DR Congo). Eur J Environ Earth Sci 4(1):69–72. 10.24018/ejgeo.2023.4.1.338.
Midander K, Julander A, Skare L, 2014. Cobalt skin dose resulting from short and repetitive contact with hard metals. Contact Dermatitis 70(6):361–368. 10.1111/cod.12198.24617983
Midander K, Hurtig A, Borg Tornberg A, 2016. Allergy risks with laptop computers - nickel and cobalt release. Contact Dermatitis 74(6):353–359. 10.1111/cod.12525.27133625
Milford JB, Davidson CI. 1985. The sizes of particulate trace elements in the atmosphere-a review. J Air Pollut Control Assoc 35(12):1249–1260. 10.1080/00022470.1985.10466027.3910700
Miller AC, Mog S, McKinney L, 2001. Neoplastic transformation of human osteoblast cells to the tumorigenic phenotype by heavy metal-tungsten alloy particles: induction of genotoxic effects. Carcinogenesis 22(1):115–125. 10.1093/carcin/22.1.115.11159749
Miyaki M, Akamatsu N, Ono T, 1979. Mutagenicity of metal cations in cultured cells from Chinese hamster. Mutat Res 68(3):259–263. 10.1016/0165-1218(79)90157-5.514305
Moche H, Chevalier D, Vezin H, 2015. Genotoxicity of tungsten carbide-cobalt (WC-Co) nanoparticles in vitro: mechanisms-of-action studies. Mutat Res Genet Toxicol Environ Mutagen 779:15–22. 10.1016/j.mrgentox.2015.02.002.25813722
Mochizuki H, Kada T. 1982. Antimutagenic action of cobaltous chloride on Trp-P-1-induced mutations in Salmonella typhimurium TA98 and TA1538. Mutat Res 95(2–3):145–157. 10.1016/0027-5107(82)90253-6.6750380
Moger WH. 1983. Effects of the calcium-channel blockers cobalt, verapamil, and D600 on Leydig cell steroidogenesis. Biol Reprod 28(3):528–535. 10.1095/biolreprod28.3.528.6303461
Mohamed AA, Metwally MMM, Khalil SR, 2019. Moringa oleifera extract attenuates the CoCl2 induced hypoxia of raťs brain: Expression pattern of HIF-1α, NF-kB, MAO and EPO. Biomed Pharmacother 109:1688–1697. 10.1016/j.biopha.2018.11.019.30551423
Mohiuddin SM, Taskar PK, Rheault M, 1970. Experimental cobalt cardiomyopathy. Am Heart J 80(4):532–543. 10.1016/0002-8703(70)90202-4.5471215
Mohmand J, Eqani SA, Fasola M, 2015. Human exposure to toxic metals via contaminated dust: Bio-accumulation trends and their potential risk estimation. Chemosphere 132:142–151. 10.1016/j.chemosphere.2015.03.004.25840340
Mollenhauer HH, Corrier DE, Clark DE, 1985. Effects of dietary cobalt on testicular structure. Virchows Arch B Cell Pathol Incl Mol Pathol 49(3):241–248. 10.1007/BF02912101.2865847
Monteiller C, Tran L, MacNee W, 2007. The pro-inflammatory effects of low-toxicity low-solubility particles, nanoparticles and fine particles, on epithelial cells in vitro: the role of surface area. Occup Environ Med 64(9):609–615. 10.1136/oem.2005.024802.17409182
Morelli L, Di Giulio C, Iezzi M, 1994. Effect of acute and chronic cobalt administration on carotid body chemoreceptors responses. Sci Total Environ 150(1–3):215–216. 10.1016/0048-9697(94)90153-8.7939599
Morfeld P, Gross JV, Erren TC, 2017. Mortality among hardmetal production workers: German historical cohort study. J Occup Environ Med 59(12):e288–e296. 10.1097/JOM.0000000000001061.29215484
Morin YL, Foley AR, Martineau G, 1967. Quebec beer-drinkers' cardiomyopathy: forty-eight cases. Can Med Assoc J 97(15):881–883.6051256
Morin Y, Tetu A, Mercier G. 1971. Cobalt cardiomyopathy: clinical aspects. Br Heart J 33(Suppl):175–178. 10.1136/hrt.33.suppl.175.
Morvai V, Szakmary E, Tatrai E, 1993. The effects of simultaneous alcohol and cobalt chloride administration on the cardiovascular system of rats. Acta Physiol Hung 81(3):253–261.8197880
Mosconi G, Bacis M, Vitali MT, 1994. Cobalt excretion in urine: results of a study on workers producing diamond grinding tools and on a control group. Sci Total Environ 150(1–3):133–139. 10.1016/0048-9697(94)90140-6.7939586
Moshtaghie AA, Badii A, Mohammadian T. 2004. The comparative study of binding characteristics of cobalt and iron to human serum transferrin. J Res Med Sci 6:250–254.
Moulin JJ, Wild P, Mur JM, 1993. A mortality study of cobalt production workers: an extension of the follow-up. Am J Ind Med 23(2):281–288. 10.1002/ajim.4700230205.8427256
Moulin JJ, Wild P, Romazini S, 1998. Lung cancer risk in hard-metal workers. Am J Epidemiol 148(3):241–248. 10.1093/oxfordjournals.aje.a009631.9690360
Moulin JJ, Clavel T, Roy D, 2000. Risk of lung cancer in workers producing stainless steel and metallic alloys. Int Arch Occup Environ Health 73(3):171–180. 10.1007/s004200050024.10787132
Müller H, Müller W, Wehner M, 2012. Artists' colors. In: Ullmann's encyclopedia of industrial chemistry. Vol. 4. Wiley‐VCH Verlag GmbH & Co. KGaA, 241–254. 10.1002/14356007.a03_143.pub2.
Mumtaz MM, Ray M, Crowell SR, 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Mur JM, Moulin JJ, Charruyer-Seinerra MP, 1987. A cohort mortality study among cobalt and sodium workers in an electrochemical plant. Am J Ind Med 11(1):75–81. 10.1002/ajim.4700110108.3812499
Muramatsu Y, Parr RM. 1988. Concentrations of some trace elements in hair, liver and kidney from autopsy subjects - Relationship between hair and internal organs. Sci Total Environ 76:29–40. 10.1016/0048-9697(88)90280-x.3238413
Murdock HR. 1959. Studies on the pharmacology of cobalt chloride. J Am Pharm Assoc 48(3):140–142. 10.1002/jps.3030480303.
Murthy GK, Rhea U, Peeler JT. 1971. Levels of antimony, cadmium, chromium, cobalt, manganese, and zinc in institutional total diets. Environ Sci Technol 5(5):436–442. 10.1021/es60052a009.
Mutafova-Yambolieva V, Staneva-Stoytcheva D, Lasova L, 1994. Effects of cobalt or nickel on the sympathetically mediated contractile responses in rat-isolated vas deferens. Pharmacology 48(2):100–110. 10.1159/000139168.8134401
Mwesigye AR, Young SD, Bailey EH, 2016. Population exposure to trace elements in the Kilembe copper mine area, Western Uganda: A pilot study. Sci Total Environ 573:366–375. 10.1016/j.scitotenv.2016.08.125.27572529
Nakaona L, Maseka KK, Hamilton EM, 2020. Using human hair and nails as biomarkers to assess exposure of potentially harmful elements to populations living near mine waste dumps. Environ Geochem Health 42(4):1197–1209. 10.1007/s10653-019-00376-6.31317372
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
Nation JR, Bourgeois AE, Clark DE, 1983. The effects of chronic cobalt exposure on behavior and metallothionein levels in the adult rat. Neurobehav Toxicol Teratol 5(1):9–15.6856014
Naylor GP, Harrison JD. 1995. Gastrointestinal iron and cobalt absorption and iron status in young rats and guinea pigs. Hum Exp Toxicol 14(12):949–954. 10.1177/096032719501401203.8962745
Nemery B, Casier P, Roosels D, 1992. Survey of cobalt exposure and respiratory health in diamond polishers. Am Rev Respir Dis 145(3):610–616. 10.1164/ajrccm/145.3.610.1312313
Newton D, Rundo J. 1971. The long-term retention of inhaled cobalt-60. Health Phys 21(3):377–384. 10.1097/00004032-197109000-00003.5095637
Nimmo M, Chester R. 1993. The chemical speciation of dissolved nickel and cobalt in Mediterranean rainwaters. Sci Total Environ 135:153–160. 10.1016/0048-9697(93)90286-F.
Nimmo M, Fones GR. 1997. The potential pool of Co, Ni, Cu, Pb and Cd organic complexing ligands in coastal and urban rain waters. Atmos Environ 31(5):693–702. 10.1016/s1352-2310(96)00243-9.
NIOSH. 1989. Health hazard evaluation-report no. HETA 85–295-1907. General Electric Carboloy Systems, Detroit, Michigan. Cincinnati, OH: National Institute for Occupational Safety and Health. PB89121008. https://www.cdc.gov/niosh/hhe/reports/pdfs/85-295-1907.pdf. December 8, 2023.
NIOSH. 1994. Cobalt metal dust and fume (as Co). Immediately dangerous to life or health (IDLH) values. The National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/idlh/7440484.html. November 27, 2023.
NIOSH. 2013. Occupational exposure to carbon nanotubes and nanofibers. National Institute for Occupational Safety and Health. Current intelligence bulletin 65. DHHS (NIOSH) Publication No. 2013–145. https://www.cdc.gov/niosh/docs/2013-145/default.html. December 5, 2023.
NIOSH. 2019a. Cobalt carbonyl (as Co). NIOSH pocket guide to chemical hazards. The National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0147.html. November 27, 2023.
NIOSH. 2019b. Cobalt hydrocarbonyl (as Co). NIOSH pocket guide to chemical hazards. The National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0148.html. November 27, 2023.
NIOSH. 2019c. Cobalt metal dust and fume (as Co). NIOSH pocket guide to chemical hazards. The National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0146.html. November 27, 2023.
Nishimura Y, Inaba J, Ichikawa R. 1978. Fetal uptake of ^60^CoCl_2_ and ^57^Co-cyanocobalamin in different gestation stages of rats. J Radiat Res 19(3):236–245. 10.1269/jrr.19.236.739444
Nishioka H. 1975. Mutagenic activities of metal compounds in bacteria. Mutat Res 31(3):185–189. 10.1016/0165-1161(75)90088-6.805366
NLM. 2022a. RBC count. MedlinePlus medical encyclopedia. National Library of Medicine. https://medlineplus.gov/ency/article/003644.htm. August 17, 2023.
NLM. 2022b. Reticulocyte count. MedlinePlus medical encyclopedia. National Library of Medicine. https://medlineplus.gov/ency/article/003637.htm. August 18, 2023.
NLM. 2023a. PubChem: Compound summary for cobalt. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/104730. December 8, 2023.
NLM. 2023b. PubChem: Compound summary for cobalt(II) chloride. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/substance/363902174. December 8, 2023.
NLM. 2023c. PubChem: Compound summary for cobalt(II) nitrate. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/25000. December 8, 2023.
NLM. 2023d. PubChem: Compound summary for cobalt(II) oxide. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/14786. December 8, 2023.
NLM. 2023e. PubChem: Compound summary for cobalt tetraoxide. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/substance/470299191. December 8, 2023.
NLM. 2023f. PubChem: Compound summary for cobalt(II) sulfate. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/24965. December 8, 2023.
NLM. 2023g. PubChem: Compound summary for cobalt(II) sulfide. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/14832. December 8, 2023.
NLM. 2023h. PubChem: Compound summary for cobalt arsenide. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/117908. December 8, 2023.
NLM. 2023i. PubChem: Compound summary for cobalt(II) hydroxide. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/substance/470502232. December 8, 2023.
NLM. 2023j. PubChem: Compound summary for cobalt(II) carbonate. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/10565. December 8, 2023.
NNDC. 2023. Cobalt. Decay radiation results. National Nuclear Data Center. https://www.nndc.bnl.gov/. October 18, 2023.
NRC. 1981. Evaluation of isotope migration-land burial: Water chemistry at commercially operated low-level radioactive waste disposal sites. Washington, DC: Nuclear Regulatory Commission. NUREG/CR-2124. BNL-NUREG-51383. 10.2172/5063889.
Nriagu JO. 1989. A global assessment of natural sources of atmospheric trace metals. Nature 338:47–49. 10.1038/338047a0.
Nriagu JO. 1992. Toxic metal pollution in Africa. Sci Total Environ 121:1–37. 10.1016/0048-9697(92)90304-b.1439723
Nriagu JO, Coker RD. 1980. Trace metals in humic and fulvic acids from Lake Ontario sediments. Environ Sci Technol 14(4):443–446. 10.1021/es60164a001.22288632
NTP. 1991. NTP report on the toxicity studies of cobalt sulfate heptahydrate in F344/N rats and B6C3F1 mice (inhalation studies). National Institutes of Health, National Toxicology Program. NIH Publication No. 91–3124. https://ntp.niehs.nih.gov/sites/default/files/2023-08/tox05_508.pdf.October 3, 2023.
NTP. 1998. Toxicology and carcinogenesis studies of cobalt sulfate heptahydrate (CAS No. 10026–24-1) in F344/N rats and B6C3F mice (inhalation studies). National Institutes of Health, National Toxicology Program. NIH Publication No. 471. https://ntp.niehs.nih.gov/publications/reports/tr/400s/tr471. December 8, 2023.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments – February 2013. National Toxicology Program, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. May 9, 2022.
NTP. 2014. NTP technical report on the toxicology studies of cobalt metal (CASRN 7440–48-4) in F344/N rats and B6C3F1/N mice and toxicology and carcinogenesis studies of cobalt metal in F344/NTac rats and B6C3F1/N mice (inhalation studies). Research Triangle Park, NC: National Toxicology Program. https://www.ncbi.nlm.nih.gov/books/NBK567171/. December 6, 2023.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2016. Cobalt and cobalt compounds that release cobalt ions in vivo. Report on carcinogens. 14th ed. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/whatwestudy/assessments/cancer/roc/index.html. December 6, 2023.
NTP. 2018. Cobalt naphthenate (61789–51-3): Genetic toxicology - bacterial mutagenicity. Chemical effects in biological systems (CEBS). Research Triangle Park, NC: National Toxicology Program. https://cebs.niehs.nih.gov/cebs/get_file/accno/13503_16910/file/A28503_G06_Ames_Summary_Data.pdf. February 3, 2024.
NTP. 2021. Cobalt-related exposures. Cobalt and cobalt compounds that release cobalt ions in vivo. In: Report on carcinogens. 15th ed. National Toxicology Program, 1–8. https://ntp.niehs.nih.gov/sites/default/files/ntp/roc/content/profiles/cobalt.pdf. November 22, 2023.
NTP. 2023. Addendum to the report. In: NTP report on the toxicity studies of cobalt sulfate heptahydrate in F344/N rats and B6C3F1 mice (inhalation studies). National Institutes of Health, National Toxicology Program. NIH Publication No. 91–3124. https://ntp.niehs.nih.gov/sites/default/files/2023-08/tox05_508.pdf. February 6, 2024.
Oberdörster G. 1993. Lung dosimetry: Pulmonary clearance of inhaled particles. Aerosol Sci Technol 18(3):279–289. 10.1080/02786829308959605.
OECD. 2018. OECD guideline for the testing of chemicals: repeated dose 90-day oral toxicity study in rodent. Organization for Economic Cooperation and Development. https://www.oecd.org/env/ehs/testing/Revision%20TG%20408%202018.pdf. December 5, 2023.
Ogawa HI, Sakata K, Inouye T, 1986. Combined mutagenicity of cobalt(II) salt and heteroaromatic compounds in Salmonella typhimurium. Mutat Res 172(2):97–104. 10.1016/0165-1218(86)90068-6.3531840
Olivero S, Viallani P, Botta A. 1995. Genotoxic effects of cobalt chloride, sulfate and nitrate on cultured human lymphocytes. Med Sci Res 23:339–341.
Oller AR, Oberdorster G, Seilkop SK. 2014. Derivation of PM10 size-selected human equivalent concentrations of inhaled nickel based on cancer and non-cancer effects on the respiratory tract. Inhal Toxicol 26(9):559–578. 10.3109/08958378.2014.932034.25055843
Omolaoye JA, Uzairu A, Gimba CE. 2010. Heavy metal assessment of some eye shadow products imported into Nigeria from China. Arch Appl Sci Res 2(5):76–84.
Onat B, Caliskan NS, Sahin UA, 2020. Assessment of the health risk related to exposure to ultrafine, fine, and total particulates and metals in a metal finishing plant. Environ Sci Pollut Res Int 27(4):4058–4066. 10.1007/s11356-019-06891-4.31823257
Ondov JM, Zoller WH, Gordon GE. 1982. Trace element emissions on aerosols from motor vehicles. Environ Sci Technol 16:318–328. 10.1021/es00100a004.
O'Neil MJ. 2013. Cobalt. In: The Merck index - An encyclopedia of chemicals, drugs, and biologicals. Cambridge, UK: Royal Society of Chemistry, 434.
Onkelinx C. 1976. Compartment analysis of cobalt (II) metabolism in rats of various ages. Toxicol Appl Pharmacol 38:425–438. 10.1016/0041-008x(76)90149-6.996872
Onwordi C, Orizu CO, Wusu A, 2011. Potentially toxic metals exposure from body creams sold in Lagos. Researcher 3(1):30–37.
Oria RS, Ben RB, Esomonu UG, 2022. Cobalt exposure triggers impairments in cognitive and anxiety-like behaviors, brain oxidative stress and inflammation, and hippocampo-amygdala histomorphological alterations: Protective role of aqueous Prosopis africana seed extract. Iran J Basic Med Sci 25(12):1528–1536. 10.22038/IJBMS.2022.65689.14456.36544532
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910–1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915–1000.pdf (https://www.govinfo.gov/content/pkg/CFR-2021). August 28, 2022.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-55.pdf (https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926). August 28, 2022.
Osman D, Cooke A, Young TR, 2021. The requirement for cobalt in vitamin B(12): A paradigm for protein metalation. Biochim Biophys Acta Mol Cell Res 1868(1):118896. 10.1016/j.bbamcr.2020.118896.33096143
Ostapczuk P, Froning M, Stoeppler M, 1985. Square wave voltammetry: A new approach for the sensitive determination of nickel and cobalt in human samples. In: Brown SS, Sunderman FWJ, eds. Progress in nickel toxicology. Oxford: Blackwell Scientific Publications, 129–132.
Ou R, Huang H, He X, 2023. Ecotoxicology of polymetallic nodule seabed mining: The effects of cobalt and nickel on phytoplankton growth and pigment concentration. Toxics 11(12):1005. 10.3390/toxics11121005.38133406
Outridge PM, Noller BN. 1991. Accumulation of toxic trace elements by freshwater vascular plants. Rev Environ Contam Toxicol 121:1–63. 10.1007/978-1-4612-3196-7_1.
Oyagbemi AA, Akinrinde AS, Adebiyi OE, 2020. Luteolin supplementation ameliorates cobalt-induced oxidative stress and inflammation by suppressing NF-кB/Kim-1 signaling in the heart and kidney of rats. Environ Toxicol Pharmacol 80:103488. 10.1016/j.etap.2020.103488.
Pagano DA, Zeiger E. 1992. Conditions for detecting the mutagenicity of divalent metals in Salmonella typhimurium. Environ Mol Mutagen 19(2):139–146. 10.1002/em.2850190208.1541255
Painter RB, Howard R. 1982. The HeLa DNA-synthesis inhibition test as a rapid screen for mutagenic carcinogens. Mutat Res 92:427–437. 10.1016/0027-5107(82)90241-X.7088012
Paley KR, Sobel ES, Yalow RS. 1958. Effect of oral and intravenous cobaltous chloride on thyroid function. J Clin Endocrinol Metab 18(8):850–859. 10.1210/jcem-18-8-850.13563611
Palit S, Ghosh AK, Sharma A, 1991a. Modification of the clastogenic effects of cobalt by calcium in bone marrow cells of mice in vivo. Cytologia (Tokyo) 56:373–377.30260327
Palit S, Sen S, Sharma A, 1991b. Protection by chlorophyllin against induction of chromosomal aberrations by cobalt in bone marrow cells of mice in vivo. Fitoterapia 62(5):425–428.
Palit S, Sharma A, Talukder G. 1991c. Cytotoxic effects of cobalt chloride on mouse bone marrow cells in vivo. Cytobios 68(273):85–89.1807927
Palit S, Sharma A, Talukder G. 1991d. Chromosomal aberrations induced by cobaltous chloride in mice in vivo. Biol Trace Elem Res 29(2):139–145. 10.1007/BF03032691.1713470
Palmes ED, Nelson N, Laskin S, 1959. Inhalation toxicity of cobalt hydrocarbonyl. Am Ind Hyg Assoc J 20:453–468. 10.1080/00028895909343751.14430014
Pappas RS, Stanfill SB, Watson CH, 2008. Analysis of toxic metals in commercial moist snuff and Alaskan Iqmik. J Anal Toxicol 32(4):281–291. 10.1093/jat/32.4.281.18430295
Paternain JL, Domingo JL. 1988. Developmental toxicity of cobalt in the rat. J Toxicol Environ Health 24:193–200. 10.1080/15287398809531153.3385796
Paton GR, Allison AC. 1972. Chromosome damage in human cell cultures induced by metal salts. Mutat Res 16(3):332–336. 10.1016/0027-5107(72)90166-2.5078138
Patrick G, Batchelor AL, Stirling C. 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles- Part VI: Lung clearance of inhaled cobalt oxide particles in SPF Fischer rats. J Aerosol Sci 20(2):249–255. 10.1016/0021-8502(89)90047-5.
Paustenbach DJ, Tvermoes BE, Unice KM, 2013. A review of the health hazards posed by cobalt. Crit Rev Toxicol 43(4):316–362. 10.3109/10408444.2013.779633.23656559
Pazzaglia UE, Apostoli P, Congiu T, 2011. Cobalt, chromium and molybdenum ions kinetics in the human body: data gained from a total hip replacement with massive third body wear of the head and neuropathy by cobalt intoxication. Arch Orthop Trauma Surg 131(9):1299–1308. 10.1007/s00402-011-1268-7.21298277
Pedigo NG, Vernon MW. 1993. Embryonic losses after 10-week administration of cobalt to male mice. Reprod Toxicol 7(2):111–116. 10.1016/0890-6238(93)90244-2.8499661
Pedigo NG, George WJ, Anderson MB. 1988. Effects of acute and chronic exposure to cobalt on male reproduction in mice. Reprod Toxicol 2(1):45–53. 10.1016/s0890-6238(88)80008-x.2980401
Pehrsson SK, Hatori N, Clyne N, 1991. The effect of chronic cobalt exposure on cardiac function in rats. Trace Elem Med 8(4):195–198.
Pereira PSC, Mendes LC, Dias ML, 2007. Influence of cobalt complex on thermal properties of poly(ethylene terephthalate)/polycarbonate blend. J Therm Anal Calorim 87(3):667–671. 10.1007/s10973-006-7873-y.
Persson B, Carlenor E, Clyne N, 1992. Binding of dietary cobalt to sarcoplasmic reticulum proteins. Scand J Clin Lab Invest 52(2):137–140. 10.3109/00365519209088777.1534182
Petrova E, Pavlova E, Tinkov AA, 2020. Cobalt accumulation and iron-regulatory protein profile expression in immature mouse brain after perinatal exposure to cobalt chloride. Chem Biol Interact 329:109217. 10.1016/j.cbi.2020.109217.32750324
Ponti J, Sabbioni E, Munaro B, 2009. Genotoxicity and morphological transformation induced by cobalt nanoparticles and cobalt chloride: an in vitro study in Balb/3T3 mouse fibroblasts. Mutagenesis 24(5):439–445. 10.1093/mutage/gep027.19605413
Potolicchio I, Mosconi G, Forni A, 1997. Susceptibility to hard metal lung disease is strongly associated with the presence of glutamate 69 in HLA-DPbeta chain. Eur J Immunol 27:2741–2743. 10.1002/eji.1830271039.9368635
Potolicchio I, Festucci A, Hausler P, 1999. HLA-DP molecules bind cobalt: a possible explanation for the genetic association with hard metal disease. Eur J Immunol 29(7):2140–2147. 10.1002/(SICI)1521–4141(199907)29:07<2140::AID-IMMU2140>3.0.CO;2-Q.10427976
Prazmo W, Balbin E, Baranowska H, 1975. Manganese mutagenesis in yeast. II. Conditions of induction and characteristics of mitochondrial respiratory deficient Saccharomyces cerevisiae mutants induced with manganese and cobalt. Genet Res 26(1):21–29. 10.1017/s0016672300015810.767216
Prentice JR, Blackwell CS, Raoof N, 2014. Auditory and visual health after ten years of exposure to metal-on-metal hip prostheses: a cross-sectional study follow up. PLoS One 9(3):e90838. 10.1371/journal.pone.0090838.24621561
Prescott E, Netterstrom B, Faber J, 1992. Effect of occupational exposure to cobalt blue dyes on the thyroid volume and function of female plate painters. Scand J Work Environ Health 18(2):101–104. 10.5271/sjweh.1605.
Procter and Gamble. 1995. TSCA Section 8(e) submission for several NTP test substances. The Procter & Gamble Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. 8EHQ-0895–13500. 88950000284. https://chemview.epa.gov/proxy?filename=8e%2F88950000284_No%20CAS%20Number_7996CA6C3194739685256930004D6688.pdf. December 6, 2023.
Raffin E, Mikkelsen S, Altman DG, 1988. Health effects due to occupational exposure to cobalt blue dye among plate painters in a porcelain factory in Denmark. Scand J Work Environ Health 14:378–384. 10.5271/sjweh.1903.3264937
Rasgele PG, Kekecoglu M, Muranli FDG. 2013. Induction of micronuclei in mice bone marrow cells by cobalt and copper chlorides. Arch Environ Protect 39(1):75–82. 10.2478/aep-2013-0007.
Redhammer GJ, Koll L, Bernroider M, 2007. Co^2+^-Cu^2+^ substitution in bieberite solid-solution series, (Co_1_-_x_Cu_x_)SO4·7H_2_O, 0.00 ≤ x ≤ 0.46: Synthesis, single-crystal structure analysis, and optical spectroscopy. Am Mineral 92(4):532–545. 10.2138/am.2007.2229.
Rehfisch P, Anderson M, Berg P, 2012. Lung function and respiratory symptoms in hard metal workers exposed to cobalt. J Occup Environ Med 54(4):409–413. 10.1097/JOM.0b013e31824d2d7e.22446572
Reimann C, de Caritat P, Halleraker JH, 1997. Rainwater composition in eight arctic catchments in northern Europe (Finland, Norway, and Russia). Atmos Environ 31(2):159–170. 10.1016/1352-2310(96)00197-5.
Ren M, Yan L, Pang Y, 2020. External interference from ambient air pollution on using hair metal(loid)s for biomarker-based exposure assessment. Environ Int 137:105584. 10.1016/j.envint.2020.105584.32106049
RePORTER. 2023. Cobalt. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. January 19, 2023.
Reuber S, Kreuzer M, Kirchgessner M. 1994. Interactions of cobalt and iron in absorption and retention. J Trace Elem Electrolytes Health Dis 8(3–4):151–158.7599505
Richardson JB, Dancy BCR, Horton CL, 2018. Exposure to toxic metals triggers unique responses from the rat gut microbiota. Sci Rep 8(1):6578. 10.1038/s41598-018-24931-w.29700420
Richter B, Lohle E, Knapp B, 2002. Harmful substances on the opera stage: possible negative effects on singers' respiratory tracts. J Voice 16(1):72–80. 10.1016/s0892-1997(02)00074-7.12002889
Roche M, Layrisse M. 1956. Effect of cobalt on thyroidal uptake of I131. J Clin Endocrinol Metabol 16(6):831–833. 10.1210/jcem-16-6-831.
Rogkotis K, Matsia S, Likotrafiti E, 2022. Selective antimicrobial food packaging of composite poly(lactic acid) cobalt-citrate films. Food Packag Shelf Life 34 10.1016/j.fpsl.2022.100959.
Romaguera C, Vilaplana J. 1998. Contact dermatitis in children: 6 years experience (1992–1997). Contact Dermatitis 39(6):277–280. 10.1111/j.1600-0536.1998.tb05941.x.
Rooney AA, Boyles AL, Wolfe MS, 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rosenberg DW. 1993. Pharmacokinetics of cobalt chloride and cobalt-protoporphyrin. Drug Metab Dispos 21(5):846–849.7902247
Rossman TG, Molina M, Meyer LW. 1984. The genetic toxicology of metal compounds: I. Induction of λ prophage in E coli WP2s(λ). Environ Mutagen 6(1):59–69. 10.1002/em.2860060108.6229401
Roto P. 1980. Asthma, symptoms of chronic bronchitis and ventilatory capacity among cobalt and zinc production workers. Scand J Work Environ Health 6(Suppl 1):1–49. 10.5271/sjweh.2641.
Ruiz P, Ray M, Fisher J, 2011. Development of a human physiologically based pharmacokinetic (PBPK) toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Rystedt I, Fisher T. 1983. Relationship between nickel and cobalt sensitization in hard metal workers. Contact Dermatitis 9:195–200. 10.1111/j.1600-0536.1983.tb04357.x.6222874
Sainio EL, Jolanki R, Hakala E, 2000. Metals and arsenic in eye shadows. Contact Dermatitis 42(1):5–10. 10.1034/j.1600-0536.2000.042001005.x.10644018
Saker F, Ybarra J, Leahy P, 1998. Glycemia-lowering effect of cobalt chloride in the diabetic rat: role of decreased gluconeogenesis. Am J Physiol 274(6):E984–991. 10.1152/ajpendo.1998.274.6.E984.9611146
Salami AT, Oyagbemi AA, Alabi MV, 2023. Naringenin modulates cobalt activities on gut motility through mechanosensors and serotonin signalling. Biomarkers 28(1):11–23. 10.1080/1354750x.2022.2137235.36250715
Sauni R, Linna A, Oksa P, 2010. Cobalt asthma-a case series from a cobalt plant. Occup Med (Lond) 60(4):301–306. 10.1093/occmed/kqq023.20308255
Sauni R, Oksa P, Uitti J, 2017. Cancer incidence among Finnish male cobalt production workers in 1969–2013: a cohort study. BMC Cancer 17(1):340. 10.1186/s12885-017-3333-2.28521771
Scansetti G, Lamon S, Talarico S, 1985. Urinary cobalt as a measure of exposure in the hard metal industry. Int Arch Occup Environ Health 57:19–26. 10.1007/BF00383542.4077278
Scansetti G, Botta GC, Spinelli P, 1994. Absorption and excretion of cobalt in the hard metal industry. Sci Total Environ 150(1–3):141–144. 10.1016/0048-9697(94)90141-4.7939587
Schade SG, Felsher BF, Bernier GM, 1970. Interrelationship of cobalt and iron absorption. J Lab Clin Med 75(3):435–441. 10.5555/uri:pii:0022214370901162.4906743
Schnitzer M. 1969. Reactions between fulvic acid, a soil humic compound and inorganic soil constituents. Soil Sci Soc Am J 33(1):75–81. 10.2136/sssaj1969.03615995003300010022x.
Schroeder WH, Dobson M, Kane DM, 1987. Toxic trace elements associated with airborne particulate matter: a review. JAPCA 37(11):1267–1285. 10.1080/08940630.1987.10466321.3327920
Sederholm T, Kouvalainen K, Lamberg B- A. 1968. Cobalt-induced hypothyroidism and polycythemia in lipoid nephrosis. Acta Med Scand 184(4):301–306. 10.1111/j.0954-6820.1968.tb02462.x.5710037
Seidenberg JM, Anderson DG, Becker RA. 1986. Validation of an in vivo developmental toxicity screen in the mouse. Teratog Carcinog Mutagen 6(5):361–374. 10.1002/tcm.1770060503.2878502
Selden AI, Norberg C, Karlson-Stiber C, 2007. Cobalt release from glazed earthenware: Observations in a case of lead poisoning. Environ Toxicol Pharmacol 23(1):129–131. 10.1016/j.etap.2006.07.002.21783747
Sesana G, Cortona G, Baj A, 1994. Cobalt exposure in wet grinding of hard metal tools for wood manufacture. Sci Total Environ 150(1–3):117–119. 10.1016/0048-9697(94)90137-6.7939583
Sheets RW. 1998. Release of heavy metals from European and Asian porcelain dinnerware. Sci Total Environ 212(2–3):107–113. 10.1016/s0048-9697(97)00315-x.9573626
Sheline GE, Chaikoff IL, Montgomery ML. 1946. The elimination of administered cobalt in pancreatic juice and bile of the dog, as measured with its radioactive isotopes. Am J Physiol 145:285–290. 10.1152/ajplegacy.1946.145.3.285.21012579
Shen M, Ren M, Wang Y, 2021. Identifying dust as the dominant source of exposure to heavy metals for residents around battery factories in the Battery Industrial Capital of China. Sci Total Environ 765:144375. 10.1016/j.scitotenv.2020.144375.33385815
Shine JP, Ika RV, Ford TE. 1995. Multivariate statistical examination of spatial and temporal patterns of heavy metal contamination in New Bedford Harbor marine sediments. Environ Sci Technol 29(7):1781–1788. 10.1021/es00007a014.22176450
Shirakawa T, Kusaka Y, Fujimura N, 1988. The existence of specific antibodies to cobalt in hard metal asthma. Clin Allergy 18(5):451–460. 10.1111/j.1365-2222.1988.tb02895.x.3233723
Shirakawa T, Kusaka Y, Fujimura N, 1989. Occupational asthma from cobalt sensitivity in workers exposed to hard metal dust. Chest 95(1):29–37. 10.1378/chest.95.1.29.2909353
Shiue I, Bramley G. 2015. Environmental chemicals mediated the effect of old housing on adult health problems: US NHANES, 2009–2010. Environ Sci Pollut Res Int 22(2):1299–1308. 10.1007/s11356-014-3468-5.25138559
Shrivastava VK, David CV, Khare N, 1996. Cobalt chloride induced histopathological changes in thyroid gland of female mice, Mus musculus (p.). Pollut Res 15(3):307–309.
Shrivastava K, Ram MS, Bansal A, 2008. Cobalt supplementation promotes hypoxic tolerance and facilitates acclimatization to hypobaric hypoxia in rat brain. High Alt Med Biol 9(1):63–75. 10.1089/ham.2008.1046.18331222
Shrivastava K, Bansal A, Singh B, 2010. Sub-chronic oral toxicity study in Sprague-Dawley rats with hypoxia mimetic cobalt chloride towards the development of promising neutraceutical for oxygen deprivation. Exp Toxicol Pathol 62(5):489–496. 10.1016/j.etp.2009.06.012.19619993
Simesen M. 1939. The fate of cobalt after oral administration of metallic cobalt and subcutaneous injection of carbonatotetraminecobalt chloride, with remarks on the quantitative estimation of cobalt in organic materials. Arch Int Pharmacodyn 62:347–356.
Singh I. 1983. Induction of reverse mutation and mitotic gene conversion by some metal compounds in Saccharomyces cerevisiae. Mutat Res 117:149–152. 10.1016/0165-1218(83)90162-3.6339905
Singh PP, Junnarkar AY. 1991. Behavioural and toxic profile of some essential trace metal salts in mice and rats. Indian J Pharmacol 23:153–159.
Skalny AV, Gluhcheva Y, Ajsuvakova OP, 2021. Perinatal and early-life cobalt exposure impairs essential metal metabolism in immature ICR mice. Food Chem Toxicol 149:111973. 10.1016/j.fct.2021.111973.33421458
Smith IC, Carson BL. 1981. Volume 6 - cobalt: An appraisal of environmental exposure. In: Trace metals in the environment. Ann Arbor, MI: Ann Arbor Science Publishers, 1–62, 85–88, 383, 389, 394–395, 406–491, 531–562, 777–924.
Smith T, Edmonds CJ, Barnaby CF. 1972. Absorption and retention of cobalt in man by whole-body counting. Health Phys 22(4):359–367. 10.1097/00004032-197204000-00007.4625611
Smith LJ, Holmes AL, Kandpal SK, 2014. The cytotoxicity and genotoxicity of soluble and particulate cobalt in human lung fibroblast cells. Toxicol Appl Pharmacol 278(3):259–265. 10.1016/j.taap.2014.05.002.24823294
Sneyers L, Verheyen L, Vermaercke P, 2009. Trace element determination in beauty products by k0-instrumental neutron activation analysis. J Radioanal Nucl Chem 281(2):259–263. 10.1007/s10967-009-0105-8.
Sorbie J, Olatunbosun D, Corbett WE, 1971. Cobalt excretion test for the assessment of body iron stores. Can Med Assoc J 104(9):777–782.5578125
Sovacool BK, Ali SH, Bazilian M, 2020. Sustainable minerals and metals for a low-carbon future. Science 367(6473):30–33. 10.1126/science.aaz6003.31896708
Speijers GJ, Krajnc EI, Berkvens JM, 1982. Acute oral toxicity of inorganic cobalt compounds in rats. Food Chem Toxicol 20(3):311–314. 10.1016/s0278-6915(82)80298-6.7201957
Sprince NL, Oliver LC, Eisen EA, 1988. Cobalt exposure and lung disease in tungsten carbide production. A cross-sectional study of current workers. Am Rev Respir Dis 138(5):1220–1226. 10.1164/ajrccm/138.5.1220.3264482
Stanley AJ, Hopps HC, Shideler AM. 1947. Cobalt polycythemia. II. Relative effects of oral and subcutaneous administration of cobaltous chloride. Proc Soc Exp Biol Med 66:19–20. 10.3181/00379727-66-15968.20270659
Stebbins AI, Horstman SW, Daniell WE, 1992. Cobalt exposure in a carbide tip grinding process. Am Ind Hyg Assoc J 53(3):186–192. 10.1080/15298669291359492.1642171
Suh M, Casteel S, Dunsmore M, 2019. Bioaccessibility and relative oral bioavailability of cobalt and nickel in residential soil and dust affected by metal grinding operations. Sci Total Environ 660:677–689. 10.1016/j.scitotenv.2018.12.317.30641396
Sullivan JF, Egan JD, George RP. 1969. A distinctive myocardiopathy occurring in Omaha, Nebraska: clinical aspects. Ann N Y Acad Sci 156(1):526–543. 10.1111/j.1749-6632.1969.tb16749.x.5291147
Sun W, Feng L, Zhang J, 2022. Amidoxime group-anchored single cobalt atoms for anti-biofouling during uranium extraction from seawater. Adv Sci (Weinh) 9(10):e2105008. 10.1002/advs.202105008.35064758
Sundaram P, Agrawal K, Mandke JV, 2001. Giant cell pneumonitis induced by cobalt. Indian J Chest Dis Allied Sci 43(1):47–49.11370507
Sunderman FW, Hopfer SM, Swift T, 1989. Cobalt, chromium, and nickel concentrations in body fluids of patients with porous-coated knee or hip prostheses. J Orthop Res 7(3):307–315. 10.1002/jor.1100070302.2649648
Suzuki Y, Shimizu H, Nagae Y, 1993. Micronucleus test and erythropoiesis: effect of cobalt on the induction of micronuclei by mutagens. Environ Mol Mutagen 22(2):101–106. 10.1002/em.2850220208.8359151
Svartengren M, Bryngelsson IL, Marsh G, 2017. Cancer incidence among hardmetal production workers: The Swedish cohort. J Occup Environ Med 59(12):e365–e373. 10.1097/JOM.0000000000001185.29215488
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press: 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Swennen B, Buchet JP, Stanescu D, 1993. Epidemiological survey of workers exposed to cobalt oxides, cobalt salts, and cobalt metal. Br J Ind Med 50(9):835–842. 10.1136/oem.50.9.835.8398878
Szakmary E, Ungvary G, Hudak A, 2001. Effects of cobalt sulfate on prenatal development of mice, rats, and rabbits, and on early postnatal development of rats. J Toxicol Environ Health A 62(5):367–386. 10.1080/152873901300018110.11261899
Szefer P, Pempkowiak J, Skwarzec B, 1993. Concentration of selected metals in penguins and other representative fauna of the Antarctica. Sci Total Environ 138(1–3):281–288. 10.1016/0048-9697(93)90421-2.8259492
Szefer P, Szefer K, Glasby GP, 1996. Heavy-metal pollution in surficial sediments from the Southern Baltic Sea off Poland. J Environ Sci Health A31(10):2723–2754. 10.1080/10934529609376520.
Takaya Y, Kuwaba S, Tsujimura Y, 2023. Chemical speciation changes of an all-solid-state lithium-ion battery caused by roasting determined by sequential acid leaching. Waste Manag 166:122–132. 10.1016/j.wasman.2023.04.042.37172513
Talbot RJ, Morgan A. 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles-Part VIII: Lung clearance of inhaled cobalt oxide particles in mice. J Aerosol Sci 20(2):261–265.
Tan YM, Chan M, Chukwudebe A, 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Tanoğlu C, Ersoy A, Coban TA, 2022. The effect of taxifolin on oxidative sciatic nerve damage induced by cobalt chloride in rats: a biochemical and histopathological evaluation. Acta Neurobiol Exp (Wars) 82(3):254–262. 10.55782/ane-2022-024.36214708
Taylor DM. 1962. The absorption of cobalt from the gastro-intestinal tract of the rat. Phys Med Biol 6:445–451. 10.1088/0031-9155/6/3/308.13919937
Taylor A, Marks V, Shabaan AA, . 1977. Cobalt induced lipaemia and erythropoiesis. Dev Toxicol Environ Sci 1:105–108.
Teraoka H. 1981. Distribution of 24 elements in the internal organs of normal males and the metallic workers in Japan. Arch Environ Health 36(4):155–165. 10.1080/00039896.1981.10667620.7271320
Thomas RG, Furchner JE, London JE, 1976. Comparative metabolism of radionuclides in mammals-X. Retention of tracer-level cobalt in the mouse, rat, monkey and dog. Health Phys 31(4):323–333. 10.1097/00004032-197610000-00003.825483
Thomson AB, Valberg LS, Sinclair DG. 1971. Competitive nature of the intestinal transport mechanism for cobalt and iron in the rat. J Clin Invest 50(11):2384–2394. 10.1172/JCI106737.5096521
Thyssen JP, Menne T, Johansen JD, 2010. A spot test for detection of cobalt release - early experience and findings. Contact Dermatitis 63(2):63–69. 10.1111/j.1600-0536.2010.01749.x.20573165
Thyssen JP, Menne T, Liden C, 2011. Cobalt release from implants and consumer items and characteristics of cobalt sensitized patients with dermatitis. Contact Dermatitis 66(3):113–122. 10.1111/j.1600-0536.2011.02001.x.22175308
Thyssen JP, Johansen JD, Jellesen MS, 2013. Consumer leather exposure: an unrecognized cause of cobalt sensitization. Contact Dermatitis 69(5):276–279. 10.1111/cod.12101.24117739
Tipping E, Lofts S, Lawlor AJ. 1998. Modelling the chemical speciation of trace metals in the surface waters of the Humber system. Sci Total Environ 210–211(1–6):63–77. 10.1016/s0048-9697(98)00045-x.
Toste AP, Kirby LJ, Pahl TR. 1984. Role of organics in the subsurface migration of radionuclides in groundwater. In: Barney GS, Navratil JD, Schulz WW, eds. Geochemical behavior of disposed radioactive waste. Washington, DC: American Chemical Society, 251–270.
TRI22. 2024. Cobalt. TRI explorer: release reports. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. https://enviro.epa.gov/triexplorer/tri_release.chemical. May 29, 2024.
Tso WW, Fung WP. 1981. Mutagenicity of metallic cations. Toxicol Lett 8(4–5):195–200. 10.1016/0378-4274(81)90100-4.7022752
Tüchsen F, Jensen MV, Villadsen E, 1996. Incidence of lung cancer among cobalt-exposed women. Scand J Work Environ Health 22(6):444–450. 10.5271/sjweh.166.9000312
Tvermoes BE, Finley BL, Unice KM, 2013. Cobalt whole blood concentrations in healthy adult male volunteers following two-weeks of ingesting a cobalt supplement. Food Chem Toxicol 53:432–439. 10.1016/j.fct.2012.11.033.23207477
Tvermoes BE, Unice KM, Paustenbach DJ, 2014. Effects and blood concentrations of cobalt after ingestion of 1 mg/d by human volunteers for 90 d. Am J Clin Nutr 99(3):632–646. 10.3945/ajcn.113.071449.24500148
Tvermoes BE, Paustenbach DJ, Kerger BD, 2015. Review of cobalt toxicokinetics following oral dosing: Implications for health risk assessments and metal-on-metal hip implant patients. Crit Rev Toxicol 45(5):367–387. 10.3109/10408444.2014.985818.25629922
Uboldi C, Orsiere T, Darolles C, 2016. Poorly soluble cobalt oxide particles trigger genotoxicity via multiple pathways. Part Fibre Toxicol 13:5. 10.1186/s12989-016-0118-8.26843362
Ude CC, Schmidt SJ, Laurencin S, 2023. Hyaluronic acid-British anti-Lewisite as a safer chelation therapy for the treatment of arthroplasty-related metallosis. Proc Natl Acad Sci U S A 120(45):e2309156120. 10.1073/pnas.2309156120.37903261
Umar AH, Suleiman I, Muhammad H. 2016. Effect of low dose lead (Pb) administration on tail immersion test and formalin-induced pain in Wistar rats: Possible modulatory role of cobalt (II) chloride. Niger J Physiol Sci 31(2):161–164.
Unice KM, Monnot AD, Gaffney SH, 2012. Inorganic cobalt supplementation: prediction of cobalt levels in whole blood and urine using a biokinetic model. Food Chem Toxicol 50(7):2456–2461. 10.1016/j.fct.2012.04.009.22538081
Unice KM, Kerger BD, Paustenbach DJ, 2014a. Refined biokinetic model for humans exposed to cobalt dietary supplements and other sources of systemic cobalt exposure. Chem Biol Interact 216:53–74. 10.1016/j.cbi.2014.04.001.24726710
Unice KM, Kerger BD, Paustenbach DJ, 2014b. Supplemental material: Refined biokinetic model for humans exposed to cobalt dietary supplements and other sources of systemic cobalt exposure. Chem Biol Interact 216 10.1016/j.cbi.2014.04.001.
Unice KM, Kovochich M, Monnot AD. 2020a. Cobalt-containing dust exposures: Prediction of whole blood and tissue concentrations using a biokinetic model. Sci Total Environ 723:137968. 10.1016/j.scitotenv.2020.137968.32217403
Unice KM, Kovochich M, Monnot AD. 2020b. Supplemental material: Cobalt-containing dust exposures: Prediction of whole blood and tissue concentrations using a biokinetic model. Sci Total Environ 723 10.1016/j.scitotenv.2020.137968.
UNSCEAR. 2011. Sources and effects of ionizing radiation: Volume II: Annexes C: Radiation exposure in accidents. New York, NY: United Nations Scientific Committee on the Effects of Atomic Radiation. 1–44. https://www.unscear.org/unscear/uploads/documents/unscear-reports/UNSCEAR_2008_Report_Vol.II.pdf (https://www.unscear.org/unscear/uploads/documents/unscear). December 5, 2023.
USC. 2011. The public health and welfare. Hazardous air pollutants. United States Code. 42 USC 7412. https://www.govinfo.gov/app/details/USCODE-2011-title42/USCODE-2011-title42-chap85-subchapI-partA-sec7412 (https://www.govinfo.gov/app/details/USCODE-2011-title42/USCODE-2011-title42-chap85). February 15, 2024.
USGS. 2006. Determination of elements in natural-water, biota, sediment, and soil samples using collision/reaction cell inductively coupled plasma-mass spectrometry. Chapter 1. Section B, methods of the National Water Quality Laboratory. Book 5, laboratory analysis. Reston, VA: U.S. Geological Survey. Techniques and Methods 5-B1. https://pubs.usgs.gov/tm/2006/tm5b1/https://pubs.usgs.gov/tm/2006/tm5b1/. December 8, 2023.
USGS. 2011. Cobalt - for strength and color. U.S. Geological Survey. Fact sheet 2011–3081. https://pubs.usgs.gov/fs/2011/3081/pdf/fs2011-3081.pdf. December 6, 2023.
USGS. 2017. Cobalt. Chapter F of critical mineral resources of the United States - Economic and environmental geology and prospects for future supply. Reston, VA: U.S. Geological Survey. Professional paper 1802-F. 10.3133/pp1802.
USGS. 2019. 2016 Minerals yearbook: Cobalt [advance release]. U.S. Geological Survey. https://www.usgs.gov/centers/national-minerals-information-center/cobalt-statistics-and-information. December 8, 2023.
USGS. 2020. Cobalt. Mineral commodity summary. U.S. Geological Survey. https://pubs.usgs.gov/periodicals/mcs2022/mcs2022-cobalt.pdf. December 6, 2023.
USGS. 2023. Cobalt. Mineral commodity summaries 2023. U.S. Geological Survey. https://pubs.usgs.gov/periodicals/mcs2023/mcs2023-cobalt.pdf. December 6, 2023.
Valberg LS, Ludwig J, Olatunbosun D. 1969. Alteration in cobalt absorption in patients with disorders of iron metabolism. Gastroenterology 56(2):241–251. 10.1016/S0016-5085(69)80123-X.5764593
Van Bruwaene R, Gerber GB, Kirchmann R, 1984. Metabolism of ^51^Cr, ^54^Mn, ^59^Fe and ^60^Co in lactating dairy cows. Health Phys 46(5):1069–1082. 10.1097/00004032-198405000-00007.6539319
Van Campenhout E. 1955. The cytotoxic effect of cobalt salts on the alpha cells of the Islands of Langerhans. J Exp Zool 124:535–559. 10.1002/jez.1401290306.
van den Brule S, Ibouraadaten S, Brombin L, 2022. A tiered approach to investigate the inhalation toxicity of cobalt substances. Tier 2a: Grouping cobalt compounds based on their capacity to stabilize HIF-1α in human alveolar epithelial cells in vitro. Regul Toxicol Pharmacol 130:105121. 10.1016/j.yrtph.2022.105121.35063568
Van Goethem F, Lison D, Kirsch-Volders M. 1997. Comparative evaluation of the in vitro micronucleus test and the alkaline single cell gel electrophoresis assay for the detection of DNA damaging agents: genotoxic effects of cobalt powder, tungsten carbide and cobalt-tungsten carbide. Mutat Res 392(1–2):31–43. 10.1016/s0165-1218(97)00043-8.
Vassilev PP, Venkova K, Pencheva N, 1993. Changes in the contractile responses to carbachol and in the inhibitory effects of verapamil and nitrendipine on isolated smooth muscle preparations from rats subchronically exposed to Co 2+ and Ni 2+. Arch Toxicol 67:330–337. 10.1007/BF01973704.8368943
Veien NK, Hattel T, Justesen O, 1987. Oral challenge with nickel and cobalt in patients with positive patch tests to nickel and/or cobalt. Acta Derm Venereol 67:321–325. 10.2340/0001555567321325.2445151
Verougstraete V, Mallants A, Buchet JP, 2004. Lung function changes in workers exposed to cobalt compounds: a 13-year follow-up. Am J Respir Crit Care Med 170(2):162–166. 10.1164/rccm.200310-1357OC.15070822
Verougstraete V, Danzeisen R, Viegas V, 2022. A tiered approach to investigate the inhalation toxicity of cobalt substances. Tier 1: Bioaccessibility testing. Regul Toxicol Pharmacol 129:105124. 10.1016/j.yrtph.2022.105124.35093462
Viegas V. 2023. Additional information in support of Danzeisen 2020a, doi: 10.1093/toxsci/kfz249. Written communication (September 1) between V. Viegas, Cobalt Institute and K. Zaccaria, SRC, Inc.
Viegas V. 2024. Additional information in support of Viegas 2022a, doi: 10.1016/j.yrtph.2022.105127. Written communication (January 28) between V. Viegas, Cobalt Institute and K. Zaccaria, SRC, Inc.
Viegas V, Burzlaff A, Brock TO, 2022a. A tiered approach to investigate the inhalation toxicity of cobalt substances. Tier 3: Inflammatory response following acute inhalation exposure correlates with lower tier data. Regul Toxicol Pharmacol 130:105127. 10.1016/j.yrtph.2022.105127.35124137
Viegas V, Burzlaff A, Brock TO, 2022b. Supplemental material: A tiered approach to investigate the inhalation toxicity of cobalt substances. Tier 3: Inflammatory response following acute inhalation exposure correlates with lower tier data. Regul Toxicol Pharmacol 130 10.1016/j.yrtph.2022.105127.
Vilaplana J, Grimalt F, Romaguera C, 1987. Cobalt content of household cleaning products. Contact Dermatitis 16(3):139–141. 10.1111/j.1600-0536.1987.tb01407.x.2953550
Wahlberg JE, Liden C. 2000. Cross-reactivity patterns of cobalt and nickel studied with repeated open applications (ROATS) to the skin of guinea pigs. Am J Contact Dermat 11(1):42–48. 10.1016/s1046-199x(00)90031-9.10684388
Wahlqvist F, Bryngelsson IL, Westberg H, 2020. Dermal and inhalable cobalt exposure-Uptake of cobalt for workers at Swedish hard metal plants. PLoS One 15(8):e0237100. 10.1371/journal.pone.0237100.32760159
Wallner P, Kundi M, Moshammer H, 2017. Mortality among hardmetal production workers: A retrospective cohort study in the Austrian hardmetal industry. J Occup Environ Med 59(12):e282–e287. 10.1097/JOM.0000000000001046.28665836
Walters GI, Moore VC, Robertson AS, 2012. An outbreak of occupational asthma due to chromium and cobalt. Occup Med (Lond) 62(7):533–540. 10.1093/occmed/kqs111.22826555
Walters GI, Robertson AS, Moore VC, 2014. Cobalt asthma in metalworkers from an automotive engine valve manufacturer. Occup Med (Lond) 64(5):358–364. 10.1093/occmed/kqu043.24727564
Wan R, Mo Y, Zhang Z, 2017. Cobalt nanoparticles induce lung injury, DNA damage and mutations in mice. Part Fibre Toxicol 14(1):38. 10.1186/s12989-017-0219-z.28923112
Wang Z, Chen Z, Zuo Q, 2013. Reproductive toxicity in adult male rats following intra-articular injection of cobalt-chromium nanoparticles. J Orthop Sci 18(6):1020–1026. 10.1007/s00776-013-0458-2.24085379
Wang B, Su Y, Tian L, 2020. Heavy metals in face paints: Assessment of the health risks to Chinese opera actors. Sci Total Environ 724:138163. 10.1016/j.scitotenv.2020.138163.32408442
Wang X, Hedberg YS, Odnevall I. 2022a. Presence of impurities of nickel and cobalt in facial cosmetic pigments and their dissolution into artificial sweat. Contact Dermatitis 87(6):550–553. 10.1111/cod.14212.36062388
Wang N, Li X, Hu M, 2022b. Ordered macroporous superstructure of bifunctional cobalt phosphide with heteroatomic modification for paired hydrogen production and polyethylene terephthalate plastic recycling. Appl Catal B Environ 316 10.1016/j.apcatb.2022.121667.
Washburn TC, Kaplan E. 1964. Cobalt therapy and goiter. Clin Pediatr (Phila) 3:89–92. 10.1177/000992286400300207.14119402
Watanabe T, Kataoka Y, Hayashi K, 2022. Dietary exposure of the Japanese general population to elements: Total diet study 2013–2018. Food Saf (Tokyo) 10(3):83–101. 10.14252/foodsafetyfscj.D-22-00003.36237396
Watanabe CH, Gontijo ESJ, Domingues MT, 2023. Impact of aquatic humic substances on speciation and toxicity of arsenic and cobalt to Ceriodaphnia dubia. Environ Sci Pollut Res Int 30(31):77238–77245. 10.1007/s11356-023-27994-z.37253909
Weakly JN. 1973. The action of cobalt ions on neuromuscular transmission in the frog. J Physiol 234(3):597–612. 10.1113/jphysiol.1973.sp010363.4357999
Weber K, Bruer G, Krueger N, 2023. Regenerative and progressing lesions in lungs and lung-associated lymph nodes from fourteen 90-day inhalation studies with chemically different particulate materials. Toxicol Lett (online ahead of print) 10.1016/j.toxlet.2023.12.011.
Wehner AP, Craig DK. 1972. Toxicology of inhaled NiO and CoO in Syrian golden hamsters. Am Ind Hyg Assoc J 33(3):146–155. 10.1080/0002889728506624.5074671
Wehner AP, Busch RH, Olson RJ, 1977. Chronic inhalation of cobalt oxide and cigarette smoke by hamsters. Am Ind Hyg Assoc J 38(7):338–346. 10.1080/0002889778507627.900017
Wellman PJ, Watkins PA, Nation JR, 1984. Conditioned taste aversion in the adult rat induced by dietary ingestion of cadmium or cobalt. Neurotoxicology 5(2):81–90.6542191
Westberg H, Bryngelsson IL, Marsh G, 2017a. Mortality among hardmetal production workers: The Swedish cohort. J Occup Environ Med 59(12):e263–e274. 10.1097/JOM.0000000000001054.29215483
Westberg H, Bryngelsson IL, Marsh G, 2017b. Mortality among hardmetal production workers: Swedish measurement data and exposure assessment. J Occup Environ Med 59(12):e327–e341. 10.1097/JOM.0000000000001147.29215486
WH. 2021a. Fact sheet: President Biden signs executive order catalyzing America’s clean energy economy through federal sustainability. Washington, DC: The White House. https://www.whitehouse.gov/briefing-room/statements-releases/2021/12/08/fact-sheet-president-biden-signs-executive-order-catalyzing-americas-clean-energy-economy-through-federal-sustainability/ (https://www.whitehouse.gov/briefing-room/statements-releases/2021/12/08/fact-sheet-president). February 12, 2024.
WH. 2021b. Executive Order 14057-Catalyzing clean energy industries and jobs through federal sustainability. The White House. Fed Regist 86(236):70935–70943. https://www.govinfo.gov/content/pkg/FR-2021-12-13/html/2021-27114.htm. February 12, 2024.
WHO. 2010. WHO guidelines for indoor air quality: Selected pollutants. World Health Organization. https://www.who.int/publications/i/item/9789289002134. April 25, 2012.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. Geneva: World Health Organization. https://www.who.int/publications/i/item/9789240045064. September 18, 2023.
Wild P, Perdrix A, Romazini S, 2000. Lung cancer mortality in a site producing hard metals. Occup Environ Med 57(8):568–573. 10.1136/oem.57.8.568.10896965
Williams DE, Vlamis J, Pukite AH, 1985. Metal movement in sludge-treated soils after six years of sludge addition: 2. Nickel, cobalt, iron, manganese, chromium, and mercury. Soil Science 140(2):120–125.
Windom HL, Schropp SJ, Calder FD, 1989. Natural trace metal concentrations in estuarine and coastal marine sediments of the southeastern United States. Environ Sci Technol 23(3):314–320. 10.1021/es00180a008.
Winger PV, Schultz DP, Johnson WW. 1990. Environmental contaminant concentrations in biota from the lower Savannah River, Georgia and South Carolina. Arch Environ Contam Toxicol 19(1):101–117. 10.1007/BF01059818.2331144
Wojcik KM, Holle AV, O'Brien KM, 2024. Seasonal patterns in trace elements assessed in toenails. Environ Adv 15:100496. 10.1016/j.envadv.2024.100496.38405619
Wong PK. 1988. Mutagenicity of heavy metals. Bull Environ Contam Toxicol 40(4):597–603. 10.1007/BF01688386.3285919
WQP. 2023. Water quality portal data: Cobalt. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/. August 30, 2023.
Wu P, Lu G, Cai C. 2021. Cobalt–molybdenum synergistic catalysis for the hydrogenolysis of terephthalate-based polyesters. Green Chem 23(21):8666–8672. 10.1039/d1gc02929k.
Wu CJ, Ho AC, Chen SY, 2023a. Exposure to heavy metals and serum adiponectin levels among workers: A 2-year follow-up study. Metabolites 13(2):158. 10.3390/metabo13020158.36837777
Wu L, Cui F, Zhang S, 2023b. Associations between multiple heavy metals exposure and neural damage biomarkers in welders: A cross-sectional study. Sci Total Environ 869:161812. 10.1016/j.scitotenv.2023.161812.36706997
Xie H, Smith LJ, Holmes AL, 2016. The cytotoxicity and genotoxicity of soluble and particulate cobalt in human lung epithelial cells. Environ Mol Mutagen 57(4):282–287. 10.1002/em.22009.27040722
Yamagata N, Murata S, Torii T. 1962. The cobalt content of human body. J Radiat Res 3(1):4–8. 10.1269/jrr.3.4. 2/3/2021.14040358
Yamatani K, Saito K, Ikezawa Y, 1998. Relative contribution of Ca2+-dependent mechanism in glucagon-induced glucose output from the liver. Arch Biochem Biophys 355(2):175–180. 10.1006/abbi.1998.0710.9675024
Yokota K, Johyama Y, Kunitani Y, 2007. Urinary elimination of nickel and cobalt in relation to airborne nickel and cobalt exposures in a battery plant. Int Arch Occup Environ Health 80(6):527–531. 10.1007/s00420-006-0159-7.17136408
Yuan Y, Hilliard G, Ferguson T, 2003. Cobalt inhibits the interaction between hypoxia-inducible factor-alpha and von Hippel-Lindau protein by direct binding to hypoxia-inducible factor-alpha. J Biol Chem 278(18):15911–15916. 10.1074/jbc.M300463200.12606543
Yukawa M, Amano K, Suzuki-Yasumoto M, 1980. Distribution of trace elements in the human body determined by neutron activation analysis. Arch Environ Health 35(1):36–44. 10.1080/00039896.1980.10667459.7362268
Zaksas N, Gluhcheva Y, Sedykh S, 2013. Effect of CoCl2 treatment on major and trace elements metabolism and protein concentration in mice. J Trace Elem Med Biol 27(1):27–30. 10.1016/j.jtemb.2012.07.005.22944586
Zeiger E, Anderson B, Haworth S, 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 19(Suppl 21):2–141. 10.1002/em.2850190603.1541260
Zeng X, Liu D, Wu Y, 2023. Heavy metal risk of disposable food containers on human health. Ecotoxicol Environ Saf 255:114797. 10.1016/j.ecoenv.2023.114797.36933486
Zhang H, van den Berg CMG, Wollast R. 1990. The determination of interactions of cobalt (II) with organic compounds in seawater using cathodic stripping voltammetry. Mar Chem 28:285–300. 10.1016/0304-4203(90)90049-I.
Zhang S, Holy CE, Eichenbaum G, 2021. Carcinogenic assessment of cobalt-containing alloys in medical devices or cobalt in occupational settings: A systematic review and meta-analysis of overall cancer risk from published epidemiologic studies. Regul Toxicol Pharmacol 125:104987. 10.1016/j.yrtph.2021.104987.34229014
Zhang J, Wen Y, Wu X, 2022. Contamination and health risk assessment of heavy metals in toys. Asian J Ecotoxicol 17(4):345–353.
Zheng F, Luo Z, Zheng C, 2019. Comparison of the neurotoxicity associated with cobalt nanoparticles and cobalt chloride in Wistar rats. Toxicol Appl Pharmacol 369:90–99. 10.1016/j.taap.2019.03.003.30849457
Zylicz E, Zabloina R. 1976. Placental transfer of ^60^Co as a function of gestation age. Nukleonika 12:1204–1210.
Zylicz E, Zablotna R, Geisler J, 1975. Effects of DTPA on the deposition of 65Zn, 60Co and 144Ce in pregnant rat and in foetoplacental unit. Int J Radiat Biol Relat Stud Phys Chem Med 28(2):125–136. 10.1080/09553007514550861.1081501
Zywiel MG, Brandt JM, Overgaard CB, 2013. Fatal cardiomyopathy after revision total hip replacement for fracture of a ceramic liner. Bone Joint J 95-B(1):31–37. 10.1302/0301-620X.95B1.30060.