# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Sam Keith, M.S., C.H.P. (Lead)
  Obaid Faroon, D.V.M., Ph.D.
- ATSDR, Office of Innovation and Analytics,
  Toxicology Section, Atlanta, GA
- Rekha C. Balachandran, M.S, Ph.D.
  Adriana Antezana, M.P.H.
  Hannah Derrick, B.S.
  Kerry Diskin, Ph.D.
  Andrea Chiger, M.P.H.
  Meghan Lynch, Ph.D.
- Abt Associates, Cambridge, MA
- Kimberly Zaccaria, Ph.D., D.A.B.T.
  Frances Belmonte, Ph.D., D.A.B.T.
  Christina Coley, M.S.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

- Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

- ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Research and Development; EPA, Office of Water.

## PEER REVIEWERS

1. David Dorman, DVM, PhD, DABVT, DABT, Professor of Toxicology, Department of Molecular Biomedical Sciences, College of Veterinary Medicine, North Carolina State University, Raleigh, North Carolina
2. Katherine Zychowski, PhD, Assistant Professor, College of Pharmacy, The University of New Mexico, Albuquerque, New Mexico
3. Ruth Danzeisen, PhD, DABT, Advisor Toxicology, Albemarle, Germany-NI Langelsheim (LHM)
4. Benoit Nemery, MD, PhD; Emeritus Professor of Toxicology & Occupational Medicine; Centre for Environment and Health; Department of Public Health and Primary Care; Faculty of Medicine; KU Leuven
5. Arne Burzlaff, PhD; Arne Burzlaff, PhD; EBRC Consulting GmbH; Hannover, Germany

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile's final content. The responsibility for the content of this profile lies with ATSDR.