# VERSION HISTORY

Date | Description
October 2024 | Final toxicological profile released
January 2023 | Draft for public comment toxicological profile released
April 2004 | Final toxicological profile released
July 1992 | Final toxicological profile released