# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding cobalt in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for cobalt.

Table 7-1 Regulations and Guidelines Applicable to Cobalt

Agency | Description | Information | Reference
Air
EPA | RfC | No data | IRIS 2023
| Provisional peer reviewed toxicity values | | EPA 2008
| Cobalt
| Provisional subchronic RfC | 0.00002 mg/m^3^
| Provisional chronic RfC | 0.000006 mg/m^3^
WHO | Air quality guidelines | No data | WHO 2010
USC | HAP | | USC 2011
| Cobalt compounds | Included in the Clean Air Acts list of HAPs to be regulated by EPA
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018a
| National primary drinking water regulations | Not listed | EPA 2009
| RfD | No data | IRIS 2023
| Provisional peer reviewed toxicity values | | EPA 2008
| Cobalt
| Provisional subchronic RfD | 0.003 mg/kg/day
| Provisional chronic RfD | 0.0003 mg/kg/day
WHO | Drinking water quality guidelines | No data | WHO 2022
FDA | Substances added to food (formerly EAFUS)
| Cobalt sulfate (as catalyst) | Permitted as boiler water additive in preparation of food for human consumption | FDA 2023b
| Cobaltous salts and its derivatives | Prohibited from use in human food | FDA 2023a
Cancer
HHS | Carcinogenicity classification | | NTP 2021
| Cobalt and cobalt compounds that release cobalt ions in vivo | Reasonably anticipated to be human carcinogens
EPA | Carcinogenicity classification | No data | IRIS 2023
| Provisional peer reviewed toxicity values | | EPA 2008
| Cobalt
| Provisional carcinogenicity classification | Likely to be carcinogenic to humans by the inhalation route
| Provisional IUR | 9 (mg/m^3^)^−1^
IARC | Carcinogenicity classification
| Cobalt metal (without tungsten carbide or other metal alloys) | Group 2A^a^ | IARC 2023
| Soluble cobalt (II) salts (cobalt chloride, cobalt sulfide) | Group 2A^a^
| Cobalt (II) oxide | Group 2B^b^
| Cobalt (II, III) oxide | Group 3^c^
| Cobalt (II) sulfide | Group 3^c^
| Other cobalt (II) compounds | Group 3^c^
| Weapons-grade tungsten (with nickel and cobalt) | Group 2B^b^
| Cobalt metal with tungsten carbide | Group 2A^a^ | IARC 2006
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | | OSHA 2021a, 2021b, 2021c
| Cobalt metal, dust, and fume (as Co) | 0.1 mg/m^3^
NIOSH | REL (up to 10-hour TWA)
| Cobalt metal, dust, and fume (as Co) | 0.05 mg/m^3^ | NIOSH 2019c
| Cobalt carbonyl (as Co) | 0.1 mg/m^3^ | NIOSH 2019a
| Cobalt hydrocarbonyl (as Co) | 0.1 mg/m^3^ | NIOSH 2019b
Emergency Criteria
AIHA | ERPGs | | AIHA 2016
| Cobalt hydrocarbonyl^d^
| ERPG-1 | Insufficient data
| ERPG-2 | 0.9 mg/m^3^
| ERPG-3 | 3 mg/m^3^
NIOSH | IDLH
| Cobalt metal, dust, and fume (as Co) | 20 mg/m^3^ | NIOSH 1994
EPA | AEGLs-air | Not listed | EPA 2018b
DOE | PACs-air | | DOE 2018a
| Cobalt
| PAC-1^d^ | 0.18 mg/m^3^
| PAC-2^d^ | 2 mg/m^3^
| PAC-3^d^ | 20 mg/m^3^
| Cobalt acetate tetrahydrate
| PAC-1^d^ | 2.1 mg/m^3^
| PAC-2^d^ | 23 mg/m^3^
| PAC-3^d^ | 140 mg/m^3^
| Cobalt carbonyl
| PAC-1^d^ | 0.3 mg/m^3^
| PAC-2^d^ | 3.3 mg/m^3^
| PAC-3^d^ | 20 mg/m^3^
| Cobalt chloride
| PAC-1^d^ | 0.13 mg/m^3^
| PAC-2^d^ | 18 mg/m^3^
| PAC-3^d^ | 83 mg/m^3^
| Cobalt (II) chloride hexahydrate
| PAC-1^d^ | 0.24 mg/m^3^
| PAC-2^d^ | 25 mg/m^3^
| PAC-3^d^ | 150 mg/m^3^
| Cobalt hydrocarbonyl
| PAC-1^d^ | 0.3 mg/m^3^
| PAC-2^d^ | 0.9 mg/m^3^
| PAC-3^d^ | 3 mg/m^3^
| Cobalt hydroxide
| PAC-1^d^ | 0.095 mg/m^3^
| PAC-2^d^ | 1.1 mg/m^3^
| PAC-3^d^ | 6.3 mg/m^3^
| Cobalt nitrate
| PAC-1^d^ | 0.19 mg/m^3^
| PAC-2^d^ | 14 mg/m^3^
| PAC-3^d^ | 86 mg/m^3^
| Cobalt nitrate hexahydrate
| PAC-1^d^ | 0.3 mg/m^3^
| PAC-2^d^ | 23 mg/m^3^
| PAC-3^d^ | 140 mg/m^3^
| Cobalt (II) oxide
| PAC-1^d^ | 0.076 mg/m^3^
| PAC-2^d^ | 4.2 mg/m^3^
| PAC-3^d^ | 25 mg/m^3^
| Cobalt oxide [cobalt tetraoxide]
| PAC-1^d^ | 0.082 mg/m^3^
| PAC-2^d^ | 4.5 mg/m^3^
| PAC-3^d^ | 27 mg/m^3^
| Cobalt sulfate
| PAC-1^d^ | 0.16 mg/m^3^
| PAC-2^d^ | 14 mg/m^3^
| PAC-3^d^ | 84 mg/m^3^
| Cobalt sulfate heptahydrate
| PAC-1^d^ | 0.29 mg/m^3^
| PAC-2^d^ | 19 mg/m^3^
| PAC-3^d^ | 120 mg/m^3^
| Cobaltous carbonate
| PAC-1^d^ | 0.12 mg/m^3^
| PAC-2^d^ | 210 mg/m^3^
| PAC-3^d^ | 1,200 mg/m^3^

a Group 2A: probably carcinogenic to humans.

b Group 2B: possibly carcinogenic to humans.

c Group 3: not classifiable as to its carcinogenicity to humans.

d Values are given as cobalt.

e Definitions of PAC terminology are available from DOE (2018b).

AEGL = acute exposure guideline level; AIHA = American Industrial Hygiene Association; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = Emergency Response Planning Guideline; FDA = Food and Drug Administration; HAP = hazardous air pollutant; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; IUR = inhalation unit risk; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization