# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Cobalt is a naturally occurring element in the earth’s crust. It occurs in several minerals, often with nickel, silver, lead, copper, and iron ores (Haynes 2015). It is a member of Group 9 of the periodic table along with rhenium, iridium, and meitnerium, and adjacent to iron and nickel. There is only one stable isotope of cobalt, ^59^Co. The other known isotopes of cobalt are not naturally occurring. Most of the radioactive forms have masses of 47–58 and 60–77 (NNDC 2023). The radioactive properties of cobalt isotopes are maintained in the United States by the National Nuclear Data Center. ^60^Co, the most common radioisotope, is formed by the neutron activation of stable ^59^Co, has a 5.27-year half-life. ^60^Co is radioactive and emits beta particles (mean beta-energy 96.41 keV; total intensity 100%) and gamma radiation (1,173 keV 99.85%, 1,332 keV 99.98%) (NNDC 2023) forming a stable nickel isotope (^60^Ni). It is used as a source of high energy gamma radiation in cancer therapy (e.g., in a gamma knife), food irradiation, and industrial radiography of welds used to detect internal flaws in metals (Clark 2023; Gregersen 2023). The cobalt isotopes ^57^Co, ^58^Co, and ^60^Co are byproducts of nuclear reactor operations. Cobalt isotopes have half-lives that are specific to the isotope, and range from seconds to years (Clark 2023; NNDC 2023). Information regarding the chemical identity of cobalt and selected cobalt compounds is presented in Table 4-1.

Table 4-1 Chemical Identity of Cobalt and Selected Cobalt Compounds

Characteristic | Cobalt | Cobalt (II) chloride | Cobalt (II) nitrate | Cobalt (II) oxide | Cobalt tetraoxide | Cobalt (II) sulfate | Cobalt (II) sulfide | Cobalt arsenide | Cobalt (II) hydroxide | Cobalt (II) carbonate
Synonym(s) and Registered trade name(s) | CI 77320; kobalt; NCI-C60311; Aquacat; cobalt-59; Super Cobalt | Cobaltous chloride; cobalt dichloride; cobalt muriate; cobaltous dichloride; kobalt chloride | Cobaltous nitrate; cobalt bis(nitrate); cobalt dinitrate; cobalt (2+) nitrate; cobalt nitrate | Cobalt monoxide; Cobalt Black; Zaffre; Oxocobalt; cobaltous oxide; Mmonocobalt oxide; CI Pigment Black 13 | Cobalt oxide; UNII-USK772NS56; cobaltosic oxide; cobalt oxide black; tricobalt tetroxide; cobalto-cobaltic oxide; cobaltic-cobaltous oxide; cobalto-cobaltic tetroxide; cobalt (II, III) oxide | Cobaltous sulfate; cobalt (II) sulphate; cobalt (II) sulfate (1:1); cobalt (2+) sulfate; cobalt sulfate; sulfuric acid, cobalt (2+) salt (1:1) | Cobalt sulfide; sulfanylidenecobalt; cobalt sulphide; cobalto monosulfide; cobalt (2+) sulfide; cobaltous sulfide | Arsanylidynecobalt; cobalt monoarsenide; cobalt (III) arsenide | Cobaltous hydroxide; cobalt hydroxide; cobalt (2+) hydroxide | Cobalt carbonate; cobalt (2+) carbonate; cobalt carbonate (1:1); cobalt (II) carbonate hydrate; carbonic acid, cobalt (2+) salt; cobalt spar; cobalt monocarbonate; carbonic acid, cobalt salt
Chemical formula | Co | CoCl_2_ | Co(NO_3_)_2_ | CoO | Co_3_O_4_ | CoSO_4_ | CoS | CoAs | Co(OH)_2_ | CoCO_3_
SMILES | Co | Cl[Co]Cl | [N+](=O)([O−])[O−].[N+](=O)([O−])[O−].[Co+2] | O=[Co] | [O−2].[O−2].[O−2].[O−2].[Co+2].[Co+3].[Co+3] | [O−]S(=O)(=O)[O−].[Co+2] | S=[Co] | [Co]#[As] | [OH−].[OH−].[Co+2] | C(=O)([O−])[O−].[CO+2]
Chemical structure | Co | [image] | [image] | O=Co | [image] | [image] | S=Co | Co≡As | [image] | [image]
CAS registry number | 7440-48-4 | 7646-79-9 (anhydrous) | 10141-05-6 (anhydrous) | 1307-96-6 | 1308-06-1 | 10124-43-3 (anhydrous) | 1317-42-6 | 27016-73-5 | 21041-93-0 | 513-79-1

CAS = Chemical Abstracts Service; SMILES = simplified molecular-input line-entry system

Sources: NLM (2023a, 2023b, 2023c, 2023d, 2023e, 2023f, 2023g, 2023h, 2023i, 2023j)

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Cobalt is a magnetic, hard, gray metal that is resistant to oxidation (Haynes 2015; Lenntech 2023). While it can be brittle, it is also ductile and somewhat malleable, and its natural magnetic properties are enhanced by alloying with other metals. Cobalt’s physical and chemical properties make it ideal for a variety of applications. Cobalt exists in nature mainly as cobalt (II) with a +2 oxidation state and, to a lesser extent, cobalt (III) in the +3 oxidation state. Cobalt may also display oxidation states of +4, +1, and −1. The most common and stable ionic species is cobalt (II). Both cobalt (II) and cobalt (III) can form stable complexes (NTP 2016). Alloys containing cobalt can maintain their strength at high temperatures, making them useful in gas turbine engines, chemical and petroleum plants, and power plants (USGS 2011). Cobalt and cobalt compounds are nonvolatile and are emitted to the atmosphere in particulate form. Cobalt is also an essential trace element found in vitamin B_12_. In biological systems, the chemistry of cobalt is facilitated by various enzymes that can cycle cobalt ions between cobalt (III), cobalt (II), and cobalt (I) species (NTP 2016; Osman et al. 2021).

Cobalt (III) is a strong oxidizer and accepts electron easily in aqueous solutions to form cobalt (II) (ionization potentials: Co3^+^/2^+^=+1.8V; Co2^+^/Co_(s)_=−-0.28) (Haynes 2015; Lenntech 2023). Metallic cobalt does not react with water at room temperature; however, reactions with acids produce hydrogen gas (Clark 2023).

Information regarding physical and chemical properties of cobalt and cobalt compounds is presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of Cobalt and Selected Cobalt Compounds

Property | Cobalt | Cobalt (II) chloride | Cobalt (II) nitrate | Cobalt (II) oxide | Cobalt tetraoxide | Cobalt (II) sulfate | Cobalt (II) sulfide | Cobalt arsenide | Cobalt (II) hydroxide | Cobalt (II) carbonate
Molecular weight | 58.933^a^ | 129.8^a^ | 182.9^a^ | 74.932^a^ | 240.8^a^ | 155^a^ | 90.998^a^ | 133.855^a^ | 92.948^a^ | 118.942^a^
Color | Gray, silvery bluish-white^a,b^ | Blue^a^ | Pale red^a^ | Gray^a^ | Black^a^ | Red^a^ | Black^a^ | No data | Blue-green crystals^a^ | Pink crystals^a^
Physical state | Solid^c^ | Solid | Solid^g^ | Solid^a^ | Solid^a^ | Solid^h^ | Solid^a^ | Solid^a^ | Solid^a^ | Solid^a^
Melting point | 1,495°C^a^ | 737°C^a^ | Decomposes at 100–105°C^g^ | 1,830°C^a^ | Decomposes at 900°C^a^ | >700°C^a^ | 1,117°C^a^ | 1,180°C^a^ | ~160°C^a^ (decomposes)^a^ | 280°C (decomposes)^a^
Boiling point | 2,927°C^a^ | 1,049°C^a^ | No data | No data | No data | No data | No data | No data | No data | No data
Density at 20°C/4°C | 8.9 g/cm^3a^ | 3.36 g/cm^3a^ | 2.49 g/cm^3a^ | 4.63 g/cm^3a^ | 6.11 g/cm^3a^ | 3.71 g/cm^3a^ | 5.45 g/cm^3a^ | 8.22 g/cm^3a^ | 3.60 g/cm^3a^ | 4.2 g/cm^3a^
Odor | Odorless^c^ | Slight sharp odor^f^ | Odorless^g^ | No data | No data | Odorless^i^ | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Air | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Taste threshold | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Solubility:
Water | No data | Soluble in water^f^ | Soluble in water^g^ | Insoluble in water^a^ | Insoluble in water^a^ | 330 g/L at 20°C^h^ | Insoluble in water^a^ | No data | Slightly soluble in water^a^ | 0.00014 g/100g H_2_O at 20°C
Organic solvent(s) | Soluble in dilute acids; readily soluble in dilute nitric acid^a,d^ | Soluble in alcohols, acetone, ether, glycerol, and pyridine^f^ | No data | Soluble in acid solutions^a^ | Soluble in acid solutions and alkaline solutions^a^ | 1.04 g/11 mL methanol at 18°C^h^ | Soluble in acid solutions^a^ | No data | Soluble in acid solutions^a^ | Insoluble in ethanol
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Vapor pressure: | | | | No data | No data | No data | No data | No data | No data | No data
At 726 mmHg and 85°C | 2.09×10^−10^ mmHg^a^ | No data | No data
Approximately | 0 mmHg^c^ | No data | No data
Henry’s law constant | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Conversion factors | 1 ppm = 2.4 mg/m^3e^ | No data | No data | No data | No data | No data | No data | No data | No data | No data
Explosive limits | No data | Reacts violently with alkali metals such as potassium or sodium causing fire and explosion hazard^f^ | No data | No data | No data | No data | No data | No data | No data | No data

a Haynes 2015.

b Browning 1969.

c NIOSH 2019b.

d O’Neil 2013.

e EPA 2000.

f NLM 2023bc.

g NLM 2023c.

h NLM 2023f.

i NLM 2023f.