# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR COBALT

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to cobalt, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to cobalt:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to cobalt. The inclusion criteria used to identify relevant studies examining the health effects of cobalt are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer

Prioritization of Human Data. Numerous general population studies evaluated potential associations cobalt levels in the blood or urine and adverse health outcomes without assessment of potential sources of exposure. Since cobalt is a trace essential element (part of the vitamin B12 complex), these studies are of limited usefulness because cobalt levels are often detected at background levels. Therefore, epidemiology studies included in this profile were restricted to those with known exposure above background levels (e.g., occupational exposure). Additionally, individuals with durable medical implants containing cobalt, such as total joint replacement, may be exposed to cobalt from these devices. Since this profile is focused on environmental exposures via inhalation, oral, and dermal exposure routes, studies focused on the kinetics and/or toxicity associated with medical implants were not included.

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen were conducted to identify studies examining the health effects of cobalt. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the Draft Toxicological Profile for Cobalt released for public comment in 2023. See Appendix B for the databases searched and the search strategy.

A total of 2,321 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of cobalt.

Title and Abstract Screen. In the Title and Abstract Screen step, 2,321 records were reviewed; 26 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 147 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 147 documents (194 studies), 64 documents (86 studies) were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for Cobalt and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Sections 2.2–2.20 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-1, 2-2, and 2-3, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for cobalt identified in human and animal studies are presented in Tables C-3 and C-4, respectively. Available human studies evaluating noncancer effects include numerous occupational exposure studies and a limited number of and controlled exposure and case reports of healthy subjects and patients taking cobalt supplements. Occupational studies identify the respiratory tract as the primary target of cobalt toxicity following inhalation exposure. Controlled exposure and case report studies indicate that hematological, gastrointestinal, and endocrine (thyroid) effects are the most sensitive targets of oral toxicity. Based on effects noted in human and animal studies, studies examining respiratory endpoints following inhalation exposure and hematological, gastrointestinal, or thyroid endpoints following oral exposure were carried through to Steps 4–8 of the systematic review. There were 86 studies (published in 64 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Cobalt Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort | | 8% | 3 | | 2 | | | 1 | 1 | | 2 | 4% | | | | 1 | 14%
Cohort | | 5% | 1 | | 1 | | | 1 | 1 | | 0 | 0 | | | | 0 | 4%
Case control | | 1
Case control | | 1
Population | | 7% | | | 2 | | | | | | 2 | 1 | | | | 1
Population | | 5% | | | 1 | | | | | | 1 | 0 | | | | 0
Case series | | 5% | | | | | | | | | | 2
Case series | | 4% | | | | | | | | | | 2
Meta-analysis | | | | | | | | | | | | | | | | | 2
Meta-analysis | | | | | | | | | | | | | | | | | 0
Oral studies
Cohort
Case control | | | 1 | 4% | 9% | | 3 | 2 | | | 7% | 2 | 1 | | 1
Case control | | | 0 | 4% | 4% | | 0 | 0 | | | 4% | 0 | 0 | | 0
Population
Case series | | | | | | | | | | | 4%
Case series | | | | | | | | | | | 4%
Dermal studies
Cohort
Case control
Population | | | | | | | | | 1
Population | | | | | | | | | 1
Case series | | | | | | | | | 3
Case series | | | | | | | | | 3
Meta-analysis | | | | | | | | | | | | 1
Meta-analysis | | | | | | | | | | | | 1
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4% | 5–9% | ≥10%
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4% | 5–9% | ≥10%

Table C-4 Overview of the Health Outcomes for Cobalt Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 1 | 6
Acute-duration | 0 | 6
Intermediate-duration | 12 | 15 | 8 | 7 | 8 | 7 | 10 | 10 | 6 | 2 | 7 | 10 | 9 | 8 | | 4
Intermediate-duration | 9 | 14 | 1 | 0 | 6 | 0 | 5 | 3 | 0 | 0 | 1 | 4 | 4 | 8 | | 1
Chronic-duration | 5 | 5 | 4 | 4 | | 4 | 4 | 4 | 4 | 2 | 4 | 4 | 4 | 4 | | | 4
Chronic-duration | 4 | 5 | 0 | 0 | | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 | | | 4
Oral studies
Acute-duration | 4 | 1 | 7 | 3 | 4 | | 6 | 7 | | 1 | | 4 | 8 | 2 | 2 | 3
Acute-duration | 3 | 0 | 6 | 2 | 4 | | 4 | 6 | | 0 | | 3 | 7 | 1 | 0 | 3
Intermediate-duration | 20 | 4 | 9 | 4 | 14 | 3 | 11 | 7 | 2 | 2 | 5 | 8 | 10 | 19 | 7 | 7
Intermediate-duration | 7 | 0 | 4 | 0 | 9 | 0 | 3 | 2 | 0 | 0 | 1 | 3 | 4 | 13 | 6 | 6
Chronic-duration
Dermal studies
Acute-duration | | | | | | | | | | | | 6
Acute-duration | | | | | | | | | | | | 6
Intermediate-duration | 1 | | | | | | | | 1 | 2
Intermediate-duration | 0 | | | | | | | | 1 | 2
Chronic-duration
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (−−)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias
Were the comparison groups appropriate?
Confounding bias
Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Performance bias
Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Performance bias
Were experimental conditions identical across study groups?
Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of cobalt health effects studies (observational epidemiology, controlled-exposure human studies, and animal experimental studies) are presented in Tables C-8, C-9, and C-10, respectively.

Table C-8 Summary of Risk of Bias Assessment for Cobalt—Observational Epidemiology Studies

| Risk of bias criteria and ratings
| Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?^*^ | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?^*^ | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: respiratory effects (inhalation only)
Cohort studies
Al-Abcha et al. 2021 | + | − | − | + | − | + | Second
Andersson et al. 2020 | + | − | + | + | + | + | Second
Linna et al. 2003 | + | + | + | + | + | + | First
Gennart and Lauwerys 1990 | + | − | − | − | + | − | Second
Kusaka et al. 1986a | + | − | + | + | + | + | Second
Kusaka et al. 1986b | + | − | + | + | + | + | Second
Rehfisch et al. 2012 | + | − | + | − | − | + | Second
Verougstraete et al. 2004 | + | − | + | + | + | + | Second
Case-control
Roto 1980 | − | − | + | + | + | + | Second
Case-series
Al-Abcha et al. 2021 | −− | − | + | − | + | + | Second
Demedts et al. 1984 | −− | − | + | −− | ++ | ++ | Second
Sauni et al. 2010 | −− | − | + | − | + | + | Second
Walters et al. 2014 | −− | + | + | − | + | + | Second
Cross-sectional
Walters et al. 2012 | + | − | + | − | + | + | Second
Hamzah et al. 2014 | + | − | + | + | + | + | Second
Meyer-Bisch et al. 1989 | + | − | + | + | + | + | Second
Roto 1980 | + | − | + | + | + | + | Second
Swennen et al. 1993 | + | + | + | + | + | + | First
Nemery et al. 1992 | + | − | + | + | + | + | Second
Deng et al. 1991 | − | − | + | − | + | + | Second
Outcome: thyroid effects (oral only)
Case series
Chamberlain 1961 | − | − | − | + | + | − | Third
Little and Sunico 1958 | − | − | − | − | + | − | Third
Washburn and Kaplan 1964 | − | − | − | + | − | − | Third

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; −− = definitely high risk of bias

* Key question used to assign risk of bias tier

Table C-9 Summary of Risk of Bias Assessment for Cobalt—Human-Controlled Exposure Studies

| Risk of bias criteria and ratings
| Selection bias | | Performance bias | Attrition/exclusion bias | Detection bias | | Selective reporting bias
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: respiratory effects (inhalation)
Inhalation acute-duration exposure
Kusaka et al. 1986a | − | − | − | + | − | + | + | Second
Outcome: gastrointestinal effects (oral only)
Oral acute-duration exposure
Paley et al. 1958 | − | − | − | + | + | − | − | Third
Oral intermediate-duration exposure
Duckham and Lee 1976 | − | − | − | − | + | − | − | Third
Holly 1955 | − | − | − | + | − | − | − | Third
Paley et al. 1958 | − | − | − | + | + | − | − | Third
Outcome: hematological effects (oral only)
Oral acute-duration exposure
Davis and Fields 1958 | − | + | + | + | + | − | + | Second
Hoffmeister et al. 2018 | − | ++ | ++ | ++ | ++ | + | ++ | First
Oral intermediate-duration exposure
Davis and Fields 1958 | − | + | + | + | + | − | + | Second
Duckham and Lee 1976 | − | + | + | + | − | − | + | Second
Finley et al. 2013 | − | + | + | + | + | − | + | Second
Hoffmeister et al. 2018 | − | ++ | ++ | ++ | ++ | + | ++ | First
Holly 1955 | − | + | + | + | − | − | + | Second
Taylor et al. 1977 | − | + | + | + | − | − | − | Second
Tvermoes et al. 2014 | − | + | + | + | + | − | + | Second
Outcome: thyroid effects (oral only)
Oral acute-duration exposure
Roche and Layrisse 1956 | − | + | + | + | + | − | + | Second
Paley et al. 1958 | − | + | + | − | + | − | − | Third
Oral intermediate-duration exposure
Duckham and Lee 1976 | − | + | + | − | + | − | − | Second
Finley et al. 2013 | − | + | + | + | + | − | + | Second
Gross et al. 1955 | − | − | − | + | + | + | − | Second
Holly 1955 | − | + | + | + | − | − | − | Second
Kriss et al. 1955 | − | − | − | + | + | + | − | Second
Paley et al. 1958 | − | + | + | − | + | − | − | Third
Tvermoes et al. 2014 | − | + | + | + | + | − | + | Second

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; −− = definitely high risk of bias

* Key question used to assign risk of bias tier

Table C-10 Summary of Risk of Bias Assessment for Cobalt—Experimental Animal Studies

| Risk of bias criteria and ratings
| Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: respiratory effects (inhalation only)
Inhalation acute-duration exposure
Burzlaff et al. 2022a (rat) | ++ | + | ++ | + | ++ | ++ | + | ++ | First
Palmes et al. 1959 (rat) | − | + | + | − | + | − | − | + | Second
Viegas et al. 2022a, 2022b (rat) | + | + | + | + | + | − | − | + | Second
Inhalation intermediate-duration exposure
Keftoot 1974 (mini pig) | − | + | ++ | − | ++ | − | + | + | First
Johansson et al. 1987 (rabbit) | − | + | ++ | − | ++ | − | + | + | First
Johansson et al. 1991 (rabbit) | − | + | ++ | − | ++ | − | + | + | First
Johansson et al. 1992 (rabbit) | − | + | ++ | − | ++ | − | + | + | First
Burzlaff et al. 2022a, 2022b (rat) | ++ | + | ++ | + | ++ | ++ | + | ++ | First
NTP 2014 (rat, mouse) | + | + | ++ | + | ++ | ++ | + | ++ | First
Bucher et al. 1990; NTP 1991 (rat, mouse) | + | + | ++ | + | ++ | ++ | + | ++ | First
Palmes et al. 1959 (rat, guinea pig) | − | + | + | − | + | − | − | + | Second
Inhalation chronic-duration exposure
Behl et al. 2015; NTP 2014 (rat, mouse) | + | + | ++ | + | + | ++ | + | ++ | First
Behl et al. 2015; Bucher et al. 1999; NTP 1998 (rat, mouse) | + | + | ++ | + | ++ | ++ | + | ++ | First
Wehner et al. 1977 (hamster) | + | + | ++ | − | ++ | − | + | ++ | First
Outcome: gastrointestinal effects (oral only)
Oral acute-duration exposure
Akinrinde et al. 2016c (rat) | − | + | − | + | − | − | + | − | Second
Richardson et al. 2018 (rat) | − | + | + | + | + | − | − | + | Second
Salami et al. 2023 (rat) | − | + | + | + | − | − | + | + | Second
Oral intermediate-duration exposure
Danzeisen et al. 2020a (rat) | + | + | ++ | + | + | ++ | ++ | − | First
Domingo et al. 1984 | − | + | − | + | − | − | + | − | Second
Holly 1955 | − | + | − | + | − | − | + | − | Second
Outcome: hematological effects (oral only)
Oral acute-duration exposure
Shrivastava et al. 2008 (rat) | + | + | ++ | + | + | + | + | ++ | First
Shrivastava et al. 2010 (rat) | + | + | ++ | + | + | + | + | ++ | First
Domingo and Llobet 1984 (rat) | − | + | ++ | + | + | + | + | + | First
Paternain and Domingo 1988 (rat) | − | + | + | + | − | + | + | + | First
Oral intermediate-duration exposure
Chetty et al. 1979 (rat) | − | + | + | + | + | − | + | ++ | First
Corrier et al. 1985 (rat) | + | + | + | + | − | − | + | ++ | First
Domingo et al. 1984 (rat) | − | + | ++ | + | − | − | − | ++ | Second
Danzeisen et al. 2020a (rat) | + | + | ++ | + | + | ++ | + | ++ | First
Holly 1955 (rat) | − | + | − | + | − | − | + | − | Second
Krasovskii and Fridlyand 1971 (rat) | − | + | − | + | − | − | − | − | Third
Murdock 1959 (rat) | − | + | − | + | − | − | + | + | Second
Pedigo et al. 1988 (mouse) | − | + | + | + | + | − | + | + | First
Stanley et al. 1947 (rat) | − | + | − | + | + | − | + | + | First
Outcome: thyroid effects (oral only)
Oral intermediate-duration exposure
Danzeisen et al. 2020a (rat) | + | + | ++ | + | + | ++ | + | − | First
Holly 1955 | − | + | − | + | − | − | + | − | Second
Shrivastava et al. 1996 | − | + | + | + | − | − | + | − | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; −− = definitely high risk of bias

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to cobalt and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to cobalt and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-11, C-12, and C-13, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-11 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-12 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-13 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining studies examining respiratory effects from inhalation studies and hematological, gastrointestinal, and thyroid effects observed in the observational epidemiology, controlled-exposure human studies, and animal experimental studies are presented in Tables C-14, C-15, and C-16, respectively.

Table C-14 Presence of Key Features of Study Design for Cobalt—Observational Epidemiology Studies

| Key features
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Respiratory effects (inhalation only)
Cohort studies
Al-Abcha et al. 2021 | No | Yes | Yes | Yes | Moderate
Andersson et al. 2020 | No | Yes | Yes | Yes | Moderate
Linna et al. 2003 | No | Yes | Yes | Yes | Moderate
Gennart and Lauwerys 1990 | No | Yes | No | Yes | Low
Kusaka et al. 1986a | No | Yes | Yes | Yes | Moderate
Kusaka et al. 1986b | No | Yes | Yes | Yes | Moderate
Rehfisch et al. 2012 | No | Yes | Yes | Yes | Moderate
Verougstraete et al. 2004 | No | Yes | Yes | Yes | Moderate
Case-control
Roto 1980 | No | No | Yes | Yes | Low
Case series
Al-Abcha et al. 2021 | No | Yes | Yes | No | Low
Demedts et al. 1984 | No | Yes | Yes | No | Low
Sauni et al. 2010 | No | Yes | Yes | No | Low
Walters et al. 2014 | No | Yes | Yes | No | Low
Cross-sectional studies
Walters et al. 2012 | No | No | Yes | Yes | Low
Hamzah et al. 2014 | No | No | Yes | Yes | Low
Meyer-Bisch et al. 1989 | No | No | Yes | Yes | Low
Roto 1980 | No | No | Yes | Yes | Low
Swennen et al. 1993 | No | No | Yes | Yes | Low
Nemery et al. 1992 | No | No | Yes | Yes | Low
Deng et al. 1991 | No | No | Yes | Yes | Low
Outcome: Thyroid effects (oral only)
Case series
Chamberlain 1961 | No | Yes | Yes | No | Low
Little and Sunico 1958 | No | Yes | Yes | No | Low
Washburn and Kaplan 1964 | No | Yes | Yes | No | Low

Table C-15 Presence of Key Features of Study Design for Cobalt—Human-Controlled Exposure Studies

| Key features
Reference | Concurrent control group | Sufficient number of subjects | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory effects (inhalation only)
Inhalation acute-duration exposure
Kusaka et al. 1986a | Yes | No | Yes | Yes | Moderate
Outcome: Gastrointestinal effects (oral only)
Oral acute-duration exposure
Paley et al. 1958 | Yes | No | No | No | Very Low
Oral intermediate-duration exposure
Duckham and Lee 1976 | Yes | No | No | No | Very Low
Holly 1955 | Yes | No | No | No | Very Low
Paley et al. 1958 | Yes | No | No | No | Very Low
Outcome: Hematological effects (oral only)
Oral acute-duration exposure
Davis and Fields 1958 | Yes | No | Yes | Yes | Moderate
Hoffmeister et al. 2018 | Yes | No | Yes | Yes | Moderate
Oral intermediate-duration exposure
Davis and Fields 1958 | Yes | No | Yes | No | Low
Duckham and Lee 1976 | Yes | No | Yes | Yes | Moderate
Finley et al. 2013 | Yes | No | Yes | Yes | Moderate
Hoffmeister et al. 2018 | Yes | No | Yes | Yes | Moderate
Holly 1955 | Yes | No | Yes | Yes | Moderate
Taylor et al. 1977 | Yes | No | No | Yes | Low
Tvermoes et al. 2014 | Yes | No | Yes | Yes | Moderate
Outcome: Thyroid effects (oral only)
Oral acute-duration exposure
Roche and Layrisse 1956 | Yes | No | Yes | Yes | Moderate
Paley et al. 1958 | Yes | No | Yes | Yes | Moderate
Oral intermediate-duration exposure
Duckham and Lee 1976 | Yes | No | Yes 1 | No | Low
Finley et al. 2013 | Yes | No | Yes | Yes | Moderate
Gross et al. 1955 | Yes | No | Yes | No | Low
Holly 1955 | Yes | No | No | No | Very Low
Kriss et al. 1955 | Yes | No | Yes | No | Low
Paley et al. 1958 | Yes | No | Yes | No | Low
Tvermoes et al. 2014 | Yes | No | Yes | Yes | Moderate

Table C-16 Presence of Key Features of Study Design for Cobalt—Experimental Animal Studies

| Key feature
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory effects (inhalation only)
Inhalation acute-duration exposure
Burzlaff et al. 2022a (rat) | Yes | Yes | Yes | No | Moderate
Palmes et al. 1959 (rat) | Yes | Yes | No | No | Low
Viegas et al. 2022a, 2022b (rat) | Yes | Yes | Yes | No | Moderate
Inhalation intermediate-duration exposure
Kerfoot 1974 (mini pig) | Yes | No | Yes | Yes | Moderate
Johansson et al. 1987 (rabbit) | Yes | No | Yes | Yes | Moderate
Johansson et al. 1991 (rabbit) | Yes | No | Yes | Yes | Moderate
Johansson et al. 1992 (rabbit) | Yes | No | Yes | Yes | Moderate
Burzlaff et al. 2022a, 2022b (rat) | Yes | Yes | Yes | No | Moderate
NTP 2014 (rat, mouse) | Yes | Yes | Yes | Yes | High
Bucher et al. 1990; NTP 1991 (rat, mouse) | Yes | Yes | Yes | Yes | High
Palmes et al. 1959 (rat, guinea pig) | Yes | Yes | Yes | No | Moderate
Inhalation chronic-duration exposure
Behl et al. 2015; NTP 2014 (rat, mouse) | Yes | Yes | Yes | Yes | High
Behl et al. 2015; Bucher et al. 1999; NTP 1998 (rat, mouse) | Yes | Yes | Yes | Yes | High
Wehner et al. 1977 (hamster) | Yes | Yes | Yes | Yes | High
Outcome: Gastrointestinal effects (oral only)
Oral acute-duration exposure
Akinrinde et al. 2016c | No | Yes | Yes | No | Low
Richardson et al. 2018 (rat) | Yes | Yes | No | Yes | Moderate
Salami et al. 2023 | Yes | Yes | Yes | Yes | High
Oral intermediate-duration exposure
Danzeisen et al. 2020a | Yes | Yes | Yes | No | Moderate
Domingo et al. 1984 | Yes | No | Yes | No | Low
Holly 1955 | No | Yes | Yes | No | Low
Outcome: Hematological effects (oral only)
Oral acute-duration exposure
Shrivastava et al. 2008 (rat) | Yes | Yes | Yes | Yes | High
Shrivastava et al. 2010 (rat) | Yes | Yes | Yes | Yes | High
Domingo and Llobet 1984 (rat) | Yes | Yes | Yes | Yes | High
Paternain and Domingo 1988 (rat) | Yes | Yes | Yes | Yes | High
Oral intermediate-duration exposure
Chetty et al. 1979 (rat) | Yes | Yes | Yes | Yes | High
Corrier et al. 1985 (rat) | Yes | No | Yes | Yes | Moderate
Domingo et al. 1984 (rat) | Yes | No | Yes | Yes | Moderate
Danzeisen et al. 2020a (rat) | Yes | Yes | Yes | Yes | High
Holly 1955 (rat) | Yes | No | Yes | No | Low
Krasovskii and Fridlyand 1971 (rat) | Yes | No | Yes | No | Low
Murdock 1959 (rat) | Yes | No | Yes | No | Low
Pedigo et al. 1988 (mouse) | Yes | Yes | Yes | Yes | High
Stanley et al. 1947 (rat) | Yes | No | Yes | No | Low
Outcome: Thyroid effects (oral only)
Oral intermediate-duration exposure
Danzeisen et al. 2020a | Yes | Yes | Yes | No | Moderate
Holly 1955 | No | Yes | Yes | No | Low
Shrivastava et al. 1996 | Yes | Yes | Yes | No | Moderate

A summary of the initial confidence ratings for each outcome is presented in Table C-17. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-17.

Table C-17 Initial Confidence Rating for Cobalt Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Respiratory effects (inhalation only)
Inhalation acute-duration exposure
Animal studies
Burzlaff et al. 2022a (rat) | Moderate | Moderate
Palmes et al. 1959 (rat) | Low | Moderate
Viegas et al. 2022a, 2022b (rat) | Moderate | Moderate
Human studies
Kusaka et al. 1986a | Moderate | Moderate
Inhalation intermediate-duration exposure
Animal studies
Kerfoot 1974 (mini pig) | Moderate | High
Johansson et al. 1987 (rabbit) | Moderate | High
Johansson et al. 1991 (rabbit) | Moderate | High
Johansson et al. 1992 (rabbit) | Moderate | High
Burzlaff et al. 2022a, 2022b (rat) | Moderate | High
NTP 2014 (rat, mouse) | High | High
Bucher et al. 1990; NTP 1991 (rat, mouse) | High | High
Palmes et al. 1959 (rat, guinea pig) | Moderate | High
Inhalation chronic-duration exposure
Animal studies
Behl et al. 2015; NTP 2014 (rat, mouse) | High | High
Behl et al. 2015; Bucher et al. 1999; NTP 1998 (rat, mouse) | High | High
Wehner et al. 1977 (hamster) | High | High
Human studies | | High
Al-Abcha et al. 2021 (cohort) | Moderate | Moderate
Al-Abcha et al. 2021 (case-series) | Low | Moderate
Andersson et al. 2020 | Moderate | Moderate
Linna et al. 2003 | Moderate | Moderate
Deng et al. 1991 | Low | Moderate
Gennart and Lauwerys 1990 | Low | Moderate
Kusaka et al. 1986a | Moderate | Moderate
Kusaka et al. 1986b | Moderate | Moderate
Rehfisch et al. 2012 | Moderate | Moderate
Verougstraete et al. 2004 | Moderate | Moderate
Roto 1980 (case-control) | Low | Moderate
Demedts et al. 1984 | Low | Moderate
Sauni et al. 2010 | Low | Moderate
Walters et al. 2012 | Low | Moderate
Walters et al. 2014 | Low | Moderate
Hamzah et al. 2014 | Low | Moderate
Meyer-Bisch et al. 1989 | Low | Moderate
Roto 1980 (cross-sectional) | Low | Moderate
Swennen et al. 1993 | Low | Moderate
Nemery et al. 1992 | Low | Moderate
Outcome: Gastrointestinal effects (oral only)
Oral acute-duration exposure
Animal studies
Akinrinde et al. 2016c | Low | High
Richardson et al. 2018 (rat) | Moderate | High
Salami et al. 2023 | High | High
Human studies
Paley et al. 1958 | Very Low | Very Low
Oral intermediate-duration exposure
Animal studies
Danzeisen et al. 2020a | Moderate | Moderate
Domingo et al. 1984 | Low | Moderate
Holly 1955 | Low | Moderate
Human studies
Duckham and Lee 1976 | Very Low | Very Low
Holly 1955 | Very Low | Very Low
Paley et al. 1958 | Very Low | Very Low
Outcome: Hematological effects (oral only)
Oral acute-duration exposure
Animal studies
Shrivastava et al. 2008 (rat) | High | High
Shrivastava et al. 2010 (rat) | High | High
Domingo and Llobet 1984 (rat) | High | High
Paternain and Domingo 1988 (rat) | High | High
Human studies
Davis and Fields 1958 | Moderate | Moderate
Hoffmeister et al. 2018 | Moderate | Moderate
Oral intermediate-duration exposure
Animal studies
Chetty et al. 1979 (rat) | High
Corrier et al. 1985 (rat) | Moderate
Domingo et al. 1984 (rat) | High
Danzeisen et al. 2020a (rat) | Moderate
Holly 1955 (rat) | Low
Krasovskii and Fridlyand 1971 (rat) | Low
Murdock 1959 (rat) | Low
Pedigo et al. 1988 (mouse) | High
Stanley et al. 1947 (rat) | Low
Human studies
Davis and Fields 1958 | Moderate | Moderate
Duckham and Lee 1976 | Low | Moderate
Finley et al. 2013 | Moderate | Moderate
Hoffmeister et al. 2018 | Moderate | Moderate
Holly 1955 | Low | Moderate
Taylor et al. 1977 | Low | Moderate
Tvermoes et al. 2014 | Moderate | Moderate
Outcome: Thyroid effects (oral only)
Oral acute-duration exposure
Human studies
Roche and Layrisse 1956 | Moderate | Moderate
Paley et al. 1958 | Moderate | Moderate
Oral intermediate-duration exposure
Animal studies
Danzeisen et al. 2020a | Moderate | Moderate
Holly 1955 | Low | Moderate
Shrivastava et al. 1996 | Moderate | Moderate
Human studies
Chamberlain 1961 | Low | Moderate
Duckham and Lee 1976 | Low | Moderate
Finley et al. 2013 | Moderate | Moderate
Gross et al. 1955 | Low | Moderate
Holly 1955 | Very Low | Moderate
Kriss et al. 1955 | Low | Moderate
Little and Sunico 1958 | Low | Moderate
Paley et al. 1958 | Low | Moderate
Tvermoes et al. 2014 | Moderate | Moderate
Washburn and Kaplan 1964 | Low | Moderate

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for respiratory effects following inhalation exposure and hematological, gastrointestinal, and thyroid effects following oral exposure are presented in Table C-18. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with cobalt exposure is presented in Table C-19.

Table C-18 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Respiratory effects (inhalation only)
Human studies | Moderate | +1 Consistency in body of evidence | High
Animal studies | High | +1 Consistency in body of evidence | High
Outcome: Gastrointestinal effects (oral only)
Human studies | Very low | −2 Risk of bias | Very low
Animal studies | High | −1 Risk of bias | Low
| | −1 Unexplained inconsistency
Outcome: Hematological effects (oral only)
Human studies | Moderate | −1 Risk of bias | Moderate
| | +1 Consistency in body of evidence
Animal studies | High | −1 Risk of bias | High
| | +1 Consistency in body of evidence
Outcome: Thyroid effects (oral only)
Human studies | Moderate | −1 Risk of bias | Low
| | −1 Imprecision
| | +1 Consistency in body of evidence
Animal studies | Moderate | | Moderate

Table C-19 Confidence in the Body of Evidence for Cobalt

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Respiratory effects (inhalation only) | High | High
Gastrointestinal effects (oral only) | Very low | Low
Hematological effects (oral only) | Moderate | High
Thyroid effects (oral only) | Low | Moderate

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-5, C-6, and C-7). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for cobalt, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for cobalt is presented in Table C-20.

Table C-20 Level of Evidence of Health Effects for Cobalt

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Respiratory effects (inhalation) | High | Health effect | High
Gastrointestinal effects (oral) | Very low | Health effect | Inadequate
Hematological effects (oral) | Moderate | Health effect | Moderate
Thyroid effects (oral) | Low | Health effect | Low
Animal studies
Respiratory effects (inhalation) | Moderate | Health effect | Moderate
Gastrointestinal effects (oral) | Low | Health effect | Low
Hematological effects (oral) | High | Health effect | High
Thyroid effects (oral) | Moderate | Health effect | Moderate

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Figure C-1 Hazard Identification Scheme

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for cobalt are listed below and summarized in Table C-21.

Known Health Effects

- Respiratory effects following inhalation exposure
  ○ High level of evidence in epidemiological studies of humans occupationally exposed to cobalt by inhalation.
    ► Exposed workers showed altered spirometry and increased evidence of pulmonary irritation and dyspnea (Gennart and Lauwerys 1990; Hamzah et al. 2014; Kusaka et al. 1986a; Linna et al. 2003; Meyer-Bisch et al. 1989; Nemery et al. 1992; Swennen et al. 1993; Verougstraete et al. 2004).
    ► Some occupational studies reported increased risk of asthma in cobalt-exposed workers (Kusaka et al. 1986b; Linna et al. 2003; Roto 1980; Walters et al. 2012).
    ► There is also limited evidence of impaired lung function after acute-duration inhalation exposure in humans (Kusaka et al. 1986a).
  ○ High level of evidence in studies of rodents exposed to cobalt and its compounds by inhalation.
    ► Acute-duration exposure is associated with inflammatory responses at low concentrations (Burzlaff et al. 2022a; Viegas et al. 2022a) and severe lung damage at lethal concentrations (Palmes et al. 1959; Viegas et al. 2022a).
    ► Widespread respiratory damage was consistently observed in rats and mice following intermittent intermediate- or chronic-duration inhalation exposure, with severity of lesions increasing in a dose- and duration-dependent manner (Burzlaff et al. 2022a; NTP 1991, 1998, 2014).
    ► In other species, intermediate-duration inhalation exposure resulted in inflammatory changes in rabbit lungs (Johansson et al. 1987) and decreased respiratory compliance, a metric of mechanical ventilation, in pigs (Kerfoot 1974).
  ○ Based on high evidence from human and animal studies, respiratory effects following inhalation exposure to cobalt and cobalt compounds are classified as known health effects.

Presumed Health Effects

- Hematological effects following oral exposure
  ○ Moderate level of evidence in human studies that showed polycythemia after acute- and intermediate-duration oral exposure to cobalt in healthy individuals (Davis and Fields 1958). Cobalt supplementation has also been shown to elevate red blood cell count when given to anemic patients (Duckham and Lee 1976; Taylor et al. 1977).
  ○ High level of evidence in animal studies after oral exposure to cobalt and its compounds. Increased erythrocytes, hematocrit, and/or hemoglobin were observed in rats following acute-duration exposure (Domingo and Llobet 1984; Paternain and Domingo 1988; Shrivastava et al. 2008, 2010) and intermediate-duration oral exposure (Corrier et al. 1985; Danzeisen et al. 2020a; Domingo et al. 1984; Holly 1955; Murdock 1959; Stanley et al. 1947).
  ○ Mechanistic data indicate that cobalt can mimic hypoxic conditions via interference with HIF-1α, which would stimulate erythropoiesis (Hoffmeister et al. 2018; Yuan et al. 2003).
  ○ Based on moderate level of evidence from human studies and high level of evidence from animal studies, with support from a plausible mechanism of action, an increase in erythrocytes is classified as a presumed health effect following oral exposure.

Suspected Health Effects

- Thyroid effects following oral exposure
  ○ Low level evidence in human studies.
    ► There is limited evidence from case reports of goiter or impaired thyroid function in some patients taking cobalt as a treatment for anemia associated with sickle-cell anemia, pregnancy, or chronic renal disease (Chamberlain 1961; Duckham and Lee 1976; Gross et al. 1955; Kriss et al. 1955; Little and Sunico 1958; Washburn and Kaplan 1964).
    ► Transient impairments in thyroid function were observed following acute- or intermediate-duration oral exposure to cobalt in some controlled human studies (Paley et al. 1958; Roche and Layrisse 1956). Other studies at similar or lower doses showed no effects (Finley et al. 2013; Holly 1955; Tvermoes et al. 2014).
  ○ Data from animal studies are limited but provide a moderate level of evidence based on severity of histopathological changes in the thyroid of mice following intermediate-duration exposure to high cobalt doses (Shrivastava et al. 1996).
  ○ A proposed mechanism for thyroid effects is decreased iodine uptake resulting from cobalt blocking the organic binding of iodine (Paley et al. 1958).
  ○ Based on low level of evidence from human studies and moderate level of evidence from animal studies, with support from a plausible mechanism of action, impaired thyroid function is classified as a suspected health effect following oral exposure.

Not Classifiable Effects

- Gastrointestinal effects following oral exposure
  ○ Data in humans pertaining to gastrointestinal effects are considered inadequate. While reported at low administered doses, evidence is restricted to subjective reports of gastrointestinal intolerance in humans following oral exposure to cobalt as a potential treatment for anemia or hyperthyroidism (Duckham and Lee 1976; Holly 1955; Paley et al. 1958).
  ○ A low level of evidence in animals is provided by a studies reporting alterations to the structure of the walls of the small intestine and delays in gastric emptying time in rats following acute-duration exposure to cobalt (Akinrinde et al. 2016c; Salami et al. 2023). However, intermediate-duration studies did not report any damage to the gastrointestinal tract in rats following oral exposure to cobalt (Danzeisen et al. 2020a; Domingo et al. 1984; Holly 1955).
  ○ Based on inadequate data in humans and a low level of evidence from animals, gastrointestinal effects are not classifiable as toxic effects following oral exposure to cobalt.

Table C-21 Hazard Identification Conclusions for Cobalt

Outcome | Hazard identification
Respiratory effects (inhalation exposure) | Known
Gastrointestinal effects (oral exposure) | Not classifiable
Hematological effects (oral exposure) | Presumed
Thyroid effects (oral exposure) | Suspected