# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR COBALT

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to cobalt.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for cobalt. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of cobalt have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of cobalt are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen^a^

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
In vitro (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

a Physical-chemical properties are not generally obtained from literature searches, but rather from curated governmental databases such as PubChem.

### B.1.1 Literature Search

The current literature search was intended to update the Draft Toxicological Profile for Cobalt released for public comment in 2023. All literature cited in the previous (2023) toxicological profile were considered for inclusion in the updated profile; thus, the literature search was restricted to studies published between September 2020 and June 2023. The following main databases were searched in June 2023:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for cobalt. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to cobalt were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
06/2023 | (((Cobalt[mh] OR 7440-48-4[rn] OR 10026-22-9[rn] OR 10124-43-3[rn] OR 10141-05-6[rn] OR 10210-68-1[rn] OR 1307-96-6[rn] OR 1308-04-9[rn] OR 1308-06-1[rn] OR 1317-42-6[rn] OR 21041-93-0[rn] OR 27016-73-5[rn] OR 513-79-1[rn] OR 61789-51-3[rn] OR 71-48-7[rn] OR 7646-79-9[rn] OR 917-69-1[rn] OR “cobalt tetraoxide”[nm] OR “cobalt(M) acetate”[nm] OR 10026-17-2[rn] OR 10026-18-3[rn] OR 13817-37-3[rn] OR 33485-99-3[rn]) AND ((“Cobalt/toxicity”[mh] OR “Cobalt/adverse effects”[mh] OR “Cobalt/poisoning”[mh] OR “Cobalt/pharmacokinetics”[mh]) OR (“Cobalt”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Cobalt”[mh] AND toxicokinetics[mh:noexp]) OR (“Cobalt/blood”[mh] OR “Cobalt/cerebrospinal fluid”[mh] OR “Cobalt/urine”[mh]) OR (“Cobalt”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Cobalt”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Cobalt/antagonists and inhibitors”[mh]) OR (“Cobalt/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Cobalt/pharmacology”[majr]) OR (“Cobalt”[mh] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))))) OR 21158-51-0[rn]) AND (2020/09/01:3000[mhda] OR 2020/09/01:3000[crdt] OR 2020/09/01:3000[edat] OR 2020:3000[dp])
| (((Cobalt[mh] AND 2022/04/01:3000[mhda]) OR ((“(Sulfido)cobalt”[tw] OR “Acetic acid, cobalt(2+) salt”[tw] OR “Acetic acid, cobalt(3+) salt”[tw] OR “Aquacat”[tw] OR “Arsanylidynecobalt”[tw] OR “C.I. Pigment Black 13”[tw] OR “Carbonic acid, cobalt(2+) salt”[tw] OR “CI Pigment Black 13”[tw] OR “Co mesoporphyrin”[tw] OR “Cobalt (2+) sulfate”[tw] OR “cobalt (II) acetate”[tw] OR “cobalt (II) carbonate”[tw] OR “cobalt (Ii) chloride”[tw] OR “cobalt (II) hydroxide”[tw] OR “cobalt (II) meso-porphyrin”[tw] OR “cobalt (II) napthenate”[tw] OR “cobalt (II) naphthenate”[tw] OR “cobalt (II) nitrate”[tw] OR “cobalt (II) oxide”[tw] OR “cobalt (II) sulfate”[tw] OR “cobalt (II,III) oxide”[tw] OR “cobalt (III) acetate”[tw] OR “cobalt (III) oxide”[tw] OR “Cobalt 59”[tw] OR “Cobalt acetate”[tw] OR “Cobalt arsenide”[tw] OR “Cobalt bis(nitrate)”[tw] OR “Cobalt Black”[tw] OR “Cobalt Brown”[tw] OR “Cobalt carbonate”[tw] OR “cobalt carbonyl”[tw] OR “Cobalt chloride”[tw] OR “Cobalt di(acetate)”[tw] OR “Cobalt diacetate”[tw] OR “Cobalt dichloride”[tw] OR “Cobalt dihydride”[tw] OR “Cobalt dihydroxide”[tw] OR “Cobalt dinitrate”[tw] OR “Cobalt dinitrate hexahydrate”[tw] OR “Cobalt fume”[tw] OR “Cobalt hydroxide”[tw] OR “Cobalt I, (dihydrogen 7,12-diethyl-3,8,13,17-tetramethyl-2,18-porphinedipropionato(2-))-”[tw] OR “Cobalt mesoporphyrin”[tw] OR “Cobalt mesoporphyrin IX”[tw] OR “Cobalt Metal”[tw] OR “Cobalt metal powder”[tw] OR “Cobalt metal, dust and fume”[tw] OR “Cobalt monoarsenide”[tw] OR “Cobalt monocarbonate”[tw] OR “Cobalt monooxide”[tw] OR “Cobalt monosulfate”[tw] OR “Cobalt monosulfide”[tw] OR “Cobalt monoxide”[tw] OR “Cobalt muriate”[tw] OR “Cobalt naphthenate”[tw] OR “Cobalt naphthenates”[tw] OR “Cobalt nitrate”[tw] OR “Cobalt octacarbonyl”[tw] OR “Cobalt oxide”[tw] OR “Cobalt peroxide”[tw] OR “Cobalt sesqioxide”[tw] OR “Cobalt sesquioxide”[tw] OR “Cobalt spar”[tw] OR “Cobalt sulfate”[tw] OR “Cobalt sulfide”[tw] OR “Cobalt sulphate”[tw] OR “cobalt sulphide”[tw] OR “Cobalt tetracarbonyl dimer”[tw] OR “Cobalt tetraoxide”[tw] OR “Cobalt triacetate”[tw] OR “Cobalt trioxide”[tw] OR “Cobalt(2+) acetate”[tw] OR “Cobalt(2+) carbonate”[tw] OR “Cobalt(2+) diacetate”[tw] OR “Cobalt(2+) dichloride”[tw] OR “Cobalt(2+) dihydroxide”[tw] OR “Cobalt(2+) dinitrate”[tw] OR “Cobalt(2+) hydroxide”[tw] OR “Cobalt(2+) nitrate”[tw] OR “Cobalt(2+) oxide”[tw] OR “Cobalt(2+) sulfate”[tw] OR “Cobalt(2+) sulfide”[tw] OR “Cobalt(3+) acetate”[tw] OR “Cobalt(3+) oxide”[tw] OR “Cobalt(3+) triacetate”[tw] OR “Cobalt(II) acetate”[tw] OR “Cobalt(II) carbonate”[tw] OR “Cobalt(II) chloride”[tw] OR “Cobalt(II) hydroxide”[tw] OR “Cobalt(II) mesoporphyrin”[tw] OR “Cobalt(II) naphthenate”[tw] OR “Cobalt(II) nitrate”[tw] OR “Cobalt(II) oxide”[tw] OR “Cobalt(II) sulfate”[tw] OR “Cobalt(II) sulfide”[tw] OR “Cobalt(II) sulphate”[tw] OR “Cobalt(II,III) oxide”[tw] OR “Cobalt(III) acetate”[tw] OR “Cobalt(III) oxide”[tw] OR “Cobalt, (sulfido)-”[tw] OR “Cobalt, [dihydrogen 7,12-diethyl-3,8,13,17-tetramethyl-2,18-porphinedipropionato(2-)]-”[tw] OR “Cobalt, [dihydrogen mesoporphyrin IX-ato(2-)]-”[tw] OR “Cobalt, arsinidyne-”[tw] OR “Cobalt, di-mu-carbonylhexacarbonyldi-”[tw] OR “Cobalt, elemental”[tw] OR “Cobalt-59”[tw] OR “Cobaltate(2-), [7,12-diethyl-3,8,13,17-tetramethyl-21H,23H-porphine-2,18-dipropanoato(4-)-κN21,κN22,κN23,κN24]-, hydrogen (1:2), (SP-4-2)-”[tw] OR “Cobalti protoporphyrin”[tw] OR “Cobaltic acetate”[tw] OR “Cobaltic oxide”[tw] OR “Cobaltic-cobaltous oxide”[tw] OR “Cobalto-cobaltic oxide”[tw] OR “Cobalto-cobaltic tetroxide”[tw] OR “Cobaltosic oxide”[tw] OR “Cobaltous acetate”[tw] OR “Cobaltous carbonate”[tw] OR “Cobaltous chloride”[tw] OR “Cobaltous diacetate”[tw] OR “Cobaltous dichloride”[tw] OR “Cobaltous hydroxide”[tw] OR “Cobaltous naphthenate”[tw] OR “Cobaltous nitrate”[tw] OR “Cobaltous oxide”[tw] OR “Cobaltous sulfate”[tw] OR “Cobaltous sulfide”[tw] OR “Di-mu-carbonylhexacarbonyldicobalt”[tw] OR “Dichlorocobalt”[tw] OR “Dicobalt carbonyl”[tw] OR “Dicobalt octacarbonyl”[tw] OR “Dicobalt oxide”[tw] OR “dicobalt trioxide”[tw] OR “Monocobalt oxide”[tw] OR “Naftolite”[tw] OR “Naphthenic acid, cobalt salt”[tw] OR “Naphthenic acids, cobalt salt”[tw] OR “Naphthenic acids, cobalt salts”[tw] OR “Nitric acid, cobalt(2+) salt”[tw] OR “Octacarbonyldicobalt”[tw] OR “Sphaerocobaltite”[tw] OR “Sulfuric acid, cobalt(2+) salt”[tw] OR “Super cobalt”[tw] OR “Sycoporite”[tw] OR “Tricobalt tetraoxide”[tw] OR “Tricobalt tetroxide”[tw] OR “Zaffre”[tw] OR “cobalt hydride”[tw] OR “cobalt(II) hydride”[tw] OR “cobalt(2+) hydride”[tw] OR “cobalt dihydride”[tw] OR “cobaltous hydride”[tw] OR “cobalt nitride”[tw] OR “glucosaminic acid cobalt”[tw] OR “cobalt fluoride”[tw] OR “cobalt difluoride”[tw] OR “cobalt trifluoride”[tw] OR “cobalt(2+) difluoride”[tw] OR “cobalt(3+) trifluoride”[tw] OR “cobalt(II) fluoride”[tw] OR “cobalt(III) fluoride”[tw] OR “cobaltic fluoride”[tw] OR “cobaltous fluoride”[tw]) NOT medline[sb])) AND (toxicity[ti] OR death OR lethal OR fatal OR fatality OR necrosis OR LC50* OR LD50* OR “body weight” OR “weight loss” OR “weight gain” OR weight-change* OR overweight OR obesity OR inhal* OR respiratory OR “pulmonary edema” OR “pulmonary effect” OR “pulmonary system” OR “pulmonary function” OR “pulmonary organ” OR “pulmonary toxicity” OR airway OR trachea OR tracheobronchial OR lung OR lungs OR nose OR nasal OR nasopharyngeal OR larynx OR laryngeal OR pharynx OR bronchial OR bronchi OR bronchioles OR bronchitis OR hemothorax OR alveolar OR alveoli OR irritation OR irritant OR sensitization OR sensitizer OR cilia OR mucocilliary OR cvd OR cardio OR vascular OR cardiovascular OR “circulatory system” OR “circulatory function” OR “circulatory effect” OR “circulatory organ” OR “circulatory toxicity” OR “cardiac arrest” OR “cardiac palpitation” OR “cardiac arrhythmia” OR “cardiac edema” OR “heart rate” OR “heart failure” OR “heart attack” OR “heart muscle” OR “heart beat” OR “myocardial-infarction” OR “chest pain” OR artery OR arteries OR veins OR venules OR cardiotox* OR “gastrointestinal” OR gastrointestinal OR “digestive system” OR “digestive function” OR “digestive effect” OR “digestive organ” OR “Intestinal system” OR “intestinal function” OR “intestinal microbiota” OR “intestinal effect” OR “intestinal organ” OR “gi tract” OR “gi disorder” OR abdominal OR esophagus OR stomach OR intestine OR pancreas OR pancreatic OR diarrhea OR nausea OR vomit OR ulcer OR constipation OR emesis OR “gut microbes” OR “gut flora” OR “gut microflora” OR anorexia OR hematological OR hematology OR hemato OR haemato OR blood OR anemia OR cyanosis OR erythrocytopenia OR leukopenia OR thrombocytopenia OR hemoglobin OR erythrocyte OR hematocrit OR “bone marrow” OR reticulocyte OR methemoglobin OR red-blood-cell OR musculoskeletal OR skeletal OR muscle OR muscular OR arthritis OR “altered bone” OR “joint pain” OR “joint-ache” OR “limb pain” OR “limb ache” OR hepatic OR “liver system” OR “liver function” OR “liver effect” OR “liver organ” OR “Liver enzyme” OR “liver weight” OR “liver congestion” OR “liver changes” OR “liver biochemical changes” OR “liver toxicity” OR hepatocytes OR gallbladder OR cirrhosis OR jaundice OR “hepatocellular degeneration” OR “hepatocellular hypertrophy” OR hepatomegaly OR hepatotox* OR renal OR “kidney system” OR “kidney function” OR “Kidney effect” OR “kidney toxicity” OR “urinary system” OR “urinary function” OR “urinary effect” OR “Urinary toxicity” OR “bladder system” OR “bladder effect” OR “bladder function” OR “bladder toxicity” OR “Urine volume” OR “blood urea nitrogen” OR bun OR nephropathy OR nephrotox* OR dermal OR “skin rash” OR “skin itch” OR “skin irritation” OR “skin redness” OR “skin effect” OR “skin necrosis” OR “skin exposure” OR “skin contact” OR acanthosis OR dermatitis OR psoriasis OR edema OR ulceration OR acne OR ocular OR “eye function” OR “eye effect” OR “eye irritation” OR “eye drainage” OR “eye tearing” OR blindness OR myopia OR cataracts OR endocrine OR “hormone changes” OR “hormone excess” OR “hormone deficiency” OR “hormone gland” OR “hormone secretion” OR “hormone toxicity” OR “sella turcica” OR thyroid OR adrenal OR pituitary OR immunological OR immunologic OR immune OR lymphoreticular OR lymph-node OR spleen OR thymus OR macrophage OR leukocyte* OR white-blood-cell OR immunotox* OR neurological OR neurologic OR neurotoxic OR neurotoxicity OR neurodegenerat* OR “nervous system” OR brain OR neurotoxicant OR neurochemistry OR neurophysiology OR neuropathology OR “motor activity” OR motor change* OR behavior-change* OR behavioral-change* OR sensory-change* OR cognitive OR vertigo OR drowsiness OR headache OR ataxia OR reproductive OR “reproduction system” OR “reproduction function” OR “reproduction effect” OR “reproduction toxicity” OR fertility OR “maternal toxicity” OR developmental OR “in utero” OR terata* OR terato* OR embryo* OR fetus* OR foetus* OR fetal* OR foetal* OR prenatal* OR “pre-natal” OR perinatal* OR “post-natal” OR postnatal* OR neonat* OR newborn* OR zygote* OR child OR children OR infant* OR offspring OR elderly OR “altered food consumption” OR “altered water consumption” OR “metabolic effect” OR “metabolic toxicity” OR fever OR cancer OR cancerous OR neoplas* OR tumor OR tumors OR tumour* OR malignan* OR carcinoma OR carcinogen OR carcinogen* OR angiosarcoma OR blastoma OR fibrosarcoma OR glioma OR leukemia OR leukaemia OR lymphoma OR melanoma OR meningioma OR mesothelioma OR myeloma OR neuroblastoma OR osteosarcoma OR sarcoma OR mutation OR mutations OR genotoxicity OR genotoxic OR mutagenicity OR mutagenic OR “mechanism of action”[tiab:~0] OR “mechanism of absorption”[tiab:~0] OR “mechanism of distribution”[tiab:~0] OR “mechanism of excretion”[tiab:~0] OR “mechanism of metabolism”[tiab:~0] OR “mechanism of toxic effect”[tiab:~0] OR “mechanism of toxicity” OR “adverse effect” OR “adverse effects” OR “health effects” OR noncancer OR poisoning OR morbidity OR inflammation OR antagonist OR inhibitor OR metabolism OR “environmental exposure” OR toxicokinetics OR pharmacokinetics OR “gene expression” OR “population health” OR epidemiology OR epidemiological OR case-control* OR case-referent OR case-report OR case-series OR cohort* OR correlation-stud* OR crosssectional-stud* OR ecological-studies OR ecological-study OR follow-up-stud* OR longitudinal-stud* OR metaanalyses OR metaanalysis OR meta-analysis OR prospective-stud* OR record-link* OR retrospective-stud* OR seroepidemiologic-stud* OR occupation* OR worker* OR workmen* OR workplace* OR “human health” OR “oral intake” OR “oral feed” OR “oral ingestion” OR “oral exposure” OR “oral administration” OR ingest* OR gavage* OR “drinking-water” OR NHANES OR “National Health and Nutrition Examination Survey” OR (human AND (risk OR toxic* OR safety)) OR mammal* OR ape OR apes OR baboon* OR balb OR beagle* OR boar OR boars OR bonobo* OR bovine OR C57 OR C57bl OR callithrix OR canine OR canis OR capra OR capuchin* OR cats OR cattle OR cavia OR chicken OR chickens OR chimpanzee* OR chinchilla* OR cow OR cows OR cricetinae OR dog OR dogs OR equus OR feline OR felis OR ferret OR ferrets OR flying-fox OR Fruit-bat OR gerbil* OR gibbon* OR goat OR goats OR guinea-pig* OR guppy OR hamster OR hamsters OR horse OR horses OR jird OR jirds OR lagomorph* OR leontopithecus OR longevans OR macaque* OR marmoset* OR medaka OR merione OR meriones OR mice OR monkey OR monkeys OR mouse OR muridae OR murinae OR murine OR mustela-putorius OR nomascus OR non-human-primate* OR orangutan* OR pan-paniscus OR pan-troglodytes OR pig OR piglet* OR pigs OR polecat* OR pongopygmaeus OR quail OR rabbit OR rabbits OR rat OR rats OR rhesus OR rodent OR rodentia OR rodents OR saguinus OR sheep OR sheeps OR siamang* OR sow OR sows OR Sprague-Dawley OR swine OR swines OR symphalangus OR tamarin* OR vervet* OR wistar OR wood-mouse OR zebra-fish OR zebrafish)) AND (2020/09/01:3000[mhda] OR 2020/09/01:3000[crdt] OR 2020/09/01:3000[edat] OR 2020:3000[dp])
NTRL
06/2023 | Date limit 2020-2023
| Search Titles OR Keywords;
| “cobalt” OR “cobaltic” OR “cobalto” OR “cobaltosic” OR “cobaltous” OR “dicobalt” OR “monocobalt” OR “tricobalt” OR “dichlorocobalt”
Toxcenter
06/2023 | FILE ‘TOXCENTER’ ENTERED AT 13:13:40 ON 02 JUN 2023
| L1 102164 SEA FILE=TOXCENTER 7440-48-4 OR 10026-17-2 OR 10026-18-3 OR 10026-22-9 OR 10124-43-3 OR 10141-05-6 OR 10210-68-1 OR 1307-96-6 OR 1308-04-9 OR 1308-06-1 OR 1317-42-6 OR 13817-37-3 OR 21041-93-0 OR 21158-51-0 OR 27016-73-5 OR 513-79-1 OR 61789-51 -3 OR 71 -48-7 OR 7646-79-9 OR 917-69-1
| L2 102098 SEA FILE=TOXCENTER L1 NOT TSCATS/FS
| L3 83010 SEA FILE=TOXCENTER L2 NOT PATENT/DT
| L4 15967 SEA FILE=TOXCENTER L3 AND PY>2019 ACT TOXQUERY/Q ---------
| L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?)
| L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,IT)
| L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50)
| L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT
| L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?)
| L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?)
| L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?)
| L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE))
| L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?)
| L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?)
| L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?)
| L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?)
| L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?)
| L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?)
| L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?)
| L20 QUE (ENDOCRIN? AND DISRUPT?)
| L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?)
| L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?)
| L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?)
| L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?)
| L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?)
| L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?)
| L27 QUE (NEPHROTOX? OR HEPATOTOX?)
| L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?)
| L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?)
| L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29
| L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?)
| L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE)
| L33 QUE L30 OR L31 OR L32
| L34 QUE (NONHUMAN MAMMALS)/ORGN
| L35 QUE L33 OR L34
| L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?)
| L37 QUE L35 OR L36 ---------
| L38 7202 SEA FILE=TOXCENTER L4 AND L37
| L39 545 SEA FILE=TOXCENTER L38 AND MEDLINE/FS
| L40 1156 SEA FILE=TOXCENTER L38 AND BIOSIS/FS
| L41 1628 DUP REM L39 L40 (73 DUPLICATES REMOVED)
| L*** DEL 545 S L38 AND MEDLINE/FS
| L*** DEL 545 S L38 AND MEDLINE/FS
| L42 545 SEA FILE=TOXCENTER L41
| L*** DEL 1156 S L38 AND BIOSIS/FS
| L*** DEL 1156 S L38 AND BIOSIS/FS
| L43 1083 SEA FILE=TOXCENTER L41
| L44 1083 SEA FILE=TOXCENTER (L42 OR L43) AND BIOSIS/FS D SCAN L44

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
06/2023 | 7440-48-4; 10026-22-9; 10124-43-3; 10141-05-6; 10210-68-1; 1307-96-6; 1308-04-9; 1308-06-1; 1317-42-6; 21041-93-0; 21158-51-0; 27016-73-5; 513-79-1; 61789-51-3; 71-48-7; 7646-79-9; 917-69-1; 33485-99-3; 10026-17-2; 10026-18-3; 13817-37-3
NTP
06/2023 | Date limit: 2020-2023 or not dated; Content types Reports & Publications; Systematic Reviews; ROC Profiles, Reviews, or Candidates
| “7440-48-4” “cobalt” “10124-43-3” “7646-79-9”
| “cobaltous” “dicobalt” “tricobalt” “dichlorocobalt”
| “10026-22-9” “10141-05-6” “0210-68-1” “1307-96-6”
| “1308-04-9” “1308-06-1” “1317-42-6” “21041-93-0”
| “21158-51-0” “27016-73-5” “513-79-1” “61789-51-3”
| “71-48-7” “917-69-1” “33485-99-3” “10026-17-2”
| “10026-18-3” “13817-37-3”
Regulations.gov
06/2023 | Dockets, no date limit
| Document, limited to notices, limited to EPA or FDA), and limited to posted date 2020-01-01 to 2023-05-31
| cobalt
| “cobaltous”
| “dicobalt”
| “tricobalt”
| “dichlorocobalt”
| “7440-48-4”
| “10026-22-9”
| “10124-43-3”
| “10141-05-6”
| “10210-68-1”
| “1307-96-6”
| “1308-04-9”
| “1308-06-1”
| “1317-42-6”
| “21041-93-0”
| “21158-51-0”
| “27016-73-5”
| “513-79-1”
| “61789-51-3”
| “71-48-7”
| “7646-79-9”
| “917-69-1”
| “33485-99-3”
| “10026-17-2”
| “10026-18-3”
| “13817-37-3”
NPIRS
06/2023 | Active Ingredient: Cobalt naphthenate (CAS #: 61789-51-3) (PC Code: 25101), Naphthenic acids, cobalt salts (CAS #: 61789-51-3) (PC Code: 25101)
NIH RePORTER
11/2023 | Search Criteria
| Fiscal Year: Active Projects Text Search: “cobalt” OR “cobaltic” OR “cobalto” OR “cobaltosic” OR “cobaltous” OR “dicobalt” OR “monocobalt” OR “tricobalt” OR “dichlorocobalt” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2023 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 2,098
- Number of records identified from other strategies: 223
- Total number of records to undergo literature screening: 2,321

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on cobalt:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 2,321
- Number of studies considered relevant and moved to the next step: 406

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 406
- Number of studies cited in the pre-public draft of the toxicological profile: 560
- Total number of studies cited in the profile: 751

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 June 2023 Literature Search Results and Screen for Cobalt