# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substances than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106–5, Atlanta, Georgia 30329–4027.

This section only discusses the MRLs for cobalt. ATSDR has derived MRLs for external exposure to ionizing radiation, which are applicable to external exposures to cobalt radiation, so additional data for the derivation of MRLs for radioactive cobalt are not needed. The MRLs for ionizing radiation are discussed in the Toxicological Profile for Ionizing Radiation (ATSDR 1999).

## Cobalt and compounds Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cobalt and compounds
CAS Numbers: | 7440-48-8
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 0.0003 mg Co/m^3^ (3×10^−4^ mg Co/m^3^)
Critical Effect: | Increased neutrophils in bronchoalveolar lavage fluid
Reference: | Viegas et al. 2022a, 2022b
Point of Departure: | NOAEL of 0.2 mg Co/m^3^ (NOAEL_HEC_ of 0.01 mg Co/m^3^)
Uncertainty Factor: | 30
LSE Graph Key: | 9
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 0.0003 mg Co/m^3^ ppm was derived for cobalt based on an increased percent neutrophils in BALF in rats exposed to concentrations of 2.2 mg Co/m^3^ as cobalt sulfate heptahydrate for 4 hours (Viegas et al. 2022a, 2022b). The MRL is based on a NOAEL of 0.2 mg Co/m^3^, which was converted to a human equivalent concentration NOAEL (NOAEL_HEC_) of 0.01 mg Co/m^3^ and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans after dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: Endpoints evaluated in the available acute-duration inhalation studies were limited to acute lethality and respiratory endpoints. Available NOAELs and LOAELs for respiratory effects are shown in Table A-1. The lowest concentration associated with lethality was 32 mg Co/m^3^ (Viegas et al. 2022a). Although the acute-duration inhalation database is limited, systematic review (Appendix C) determined that respiratory effects are a known target of cobalt toxicity in humans following inhalation exposure. Therefore, respiratory toxicity was selected as the critical effect for the acute-duration inhalation MRL.

Table A-1 Summary of NOAEL and LOAEL Values for Respiratory Effects Following Acute-Duration Inhalation Exposure to Cobalt and Compounds

Species (strain)/number | Duration/frequency | NOAEL (mg Co/m^3^) | LOAEL (mg Co/m^3^) | Effect | Compound | Reference
Human; 15 M | 6 hours | ND | 0.038 | Subjective complaints of respiratory irritation; unspecified decrease in FVC | Hard metal dust | Kusaka et al. 1986a
Rat (SD); 5 F | 4 hours | 0.2 | 2.2 | Increased BALF neutrophils, decreased BALF cell viability | Cobalt sulfate heptahydrate^a^ | Viegas et al. 2022a, 2022b
Rat (Albino); 1–33 M | 30 minutes | 7 | 26 | Gross lung lesions, pulmonary edema | Cobalt hydrocarbonyl^b^ | Palmes et al. 1959
Rat (Wistar); 5 M, 5 F | 14 days; 6 hours/day | 9.86 | 33.87 | Increased BALF levels of LDH and polymorphonuclear neutrophils | Cobalt tetraoxide | Burzlaff et al. 2022a

a Test substance was likely converted to cobalt sulfate hexahydrate in the inhalation chamber due to relative humidity <70% (Redhammer et al. 2007; Viegas 2024).

b Exposure to cobalt hydrocarbonyl plus oxide/carbonate decomposition products due to instability of test substance in oxygen.

Selected study for the acute-duration inhalation MRL derivation.

BALF = bronchoalveolar lavage fluid; F = females; FVC = forced vital capacity; LDH = lactate dehydrogenase; M = males; ND = not determined; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: One human study and three animal studies were identified that evaluated respiratory effects following acute-duration inhalation exposure to cobalt and cobalt compounds. In the human study, a group of 15 young men were exposed to hard metal dust containing mean cobalt concentrations of 0.038 mg Co/m^3^ (range 0.004–0.076 mg Co/m^3^ (Kusaka et al. 1986a). While all subjects reported respiratory irritation, including coughing, expectoration, or a sore throat, and the study authors reported a significant decrease in FVC after the 6-hour exposure, quantitative data were not provided. Additionally, the study authors did indicate that “no dose-effect relation” could be discerned; however, this claim is unsubstantiated by the available data, and it is unclear how this would be ascertained based on the exposure paradigm. While previous case studies by Harding (1950) and Davison et al. (1983) indicated that cobalt is a potentially toxic substance in hard metal exposure, hard metal is composed of a combination of cobalt, tungsten, and/or tungsten carbide. Due to these study limitations, this study is not considered adequate to serve as the basis for an MRL.

Three studies in rats reported respiratory effects characterized by inflammatory changes in the lungs following acute-duration inhalation exposure to cobalt compounds (Burzlaff et al. 2022a; Palmes et al. 1959; Viegas et al. 2022a, 2022b). Of these, the most sensitive is the study exposing rats to cobalt sulfate heptahydrate, which reported elevated neutrophils in BALF at ≥2.2 mg Co/m^3^ (Viegas et al. 2022a, 2022b). The study by Burzlaff et al. (2022a) also reported BALF alterations following exposure to cobalt tetraoxide at a higher concentration. The differences in adverse effect level between Viegas et al. (2022a) and Burzlaff et al. (2022a) is attributable to differences in bioaccessibility of cobalt in the administered compound. A series of studies by this group of researchers suggests two groupings of compounds based on high acute toxicity (cobalt metal power, cobalt dihydroxide, cobalt monoxide, and cobalt sulfate heptahydrate) and low acute toxicity (cobalt tetraoxide, cobalt sulfide) (Danzeisen et al. 2022a, 2022b; Derr et al. 2022; van den Brule et al. 2022; Verougstraete et al. 2022; Viegas et al. 2022a). Toxicity findings in these studies are correlated with bioaccessibility of cobalt in the various compounds.

Regarding the LOAEL endpoint of elevated neutrophils in BALF identified in the study by Viegas et al. (2022a, 2022b), neutrophil-mediated inflammation is considered a key event in particle-induced lung inflammation and toxicity (Lam et al. 2023). In support, Viegas et al. (2022a, 2022b) reported that inflammatory changes at the LOAEL (2.2 mg Co/m^3^) progressed to histopathological changes at the next tested concentration (6.7 mg Co/m^3^). Furthermore, data from several other inhalation studies with particulates support that increased neutrophils in BALF correlated well with histological changes in the alveoli in 90-day studies in rats (Weber et al. 2023). Weber et al. (2023) proposed that progressive inflammatory changes were associated with macrophage destruction, which decreased particle clearance from the lungs.

Based on these findings, the study by Viegas et al. (2022a, 2022b), which identified an early key event for respiratory toxicity following exposure to a cobalt compound belonging to the “high acute toxicity” group (cobalt sulfate heptahydrate), appears to be an appropriate, health-protective study on which to base the acute-duration inhalation MRL. While the administered NOAEL is higher than the LOAEL identified by Kusaka et al. (1986a), the NOAEL_HEC_ of 0.03 mg Co/m^3^ is below the human LOAEL (see Human Equivalent Concentration section for calculations below).

Summary of the Principal Study:

Viegas V, Burzlaff A, Brock TO, . 2022a. A tiered approach to investigate the inhalation toxicity of cobalt substances. Tier 3: Inflammatory response following acute inhalation exposure correlates with lower tier data. Regul Toxicol Pharmacol 130:105127. 10.1016/j.yrtph.2022.105127.35124137

Viegas V, Burzlaff A, Brock TO, . 2022b. Supplementary data: A tiered approach to investigate the inhalation toxicity of cobalt substances. Tier 3: Inflammatory response following acute inhalation exposure correlates with lower tier data. Regul Toxicol Pharmacol 130. 10.1016/j.yrtph.2022.105127.

Groups of female Crl:CD (SD) rats were exposed to cobalt sulfate heptahydrate at 0, 0.1, 0.3, 1, 10, or 30 mg/m^3^ via whole-body inhalation for 4 hours and sacrificed at the following timepoints (five per timepoint): 4, 8, and 16 hours postexposure and 1, 7, 16, and 32 days postexposure. While the initial test compound was cobalt sulfate heptahydrate, this compound is unstable at room temperature at humidity levels <70%; at lower humidity levels, the compound is converted into cobalt sulfate hexahydrate (Redhammer et al. 2007). Based on personal communication with study authors (Viegas 2024), it is likely that the analytically verified concentrations were cobalt sulfate hexahydrate based on the temperature (20–23°C) and humidity (25–31% at lower concentrations, 46–51% at the highest concentration) of the inhalation chambers. Using the ratio of molecular weights for cobalt (58.933 g/mol) and cobalt sulfate hexahydrate (263.11 g/mol), cobalt concentrations were calculated to be 0, 0.02, 0.07, 0.2, 2.2, and 6.7 mg Co/m^3^.

BALF was collected for biochemical analysis. Histopathology was conducted on the lungs and upper respiratory system at 1 and 16 days postexposure only. Histopathology data were not reported as incidence data. Rather, the data were reported based on severity score (1–4) for four histopathological markers for inflammation (perivascular inflammatory edema, alveolar pulmonary edema, pneumonia) and upper respiratory tract reactivity (hyperplasia, metaplasia), adjusted by the number of animals affected as well as the spread of the effect (focal, multifocal, locally extensive, no modifier), and then normalized to 1,000 mg/m^3^ exposure (to be comparable across various concentrations utilized for eight cobalt compounds tested in this study). The normalized score was reported on a scale of 0–100.

The mass median aerodynamic diameter (MMAD) was 1.87 μM. No deaths occurred. The percentages of neutrophils in BALF were significantly increased by approximately 3.3- and 4.5-fold at 2.2 and 6.7 mg Co/m^3^, respectively, at 1-day postexposure. Increases were also observed at 6.7 mg Co/m^3^ at 8 hours postexposure and at 2.1 mg Co/m^3^ at 16 hours postexposure. Values returned to control levels at 7 days and beyond (data presented graphically). The study authors also noted decreased BALF cell viability at ≥2.2 mg Co/m^3^ at 4–16 hours postexposure. Particle-laden macrophages were occasionally noted at 6.7 mg Co/m^3^. No histopathological changes were observed the day after exposure; however, by 16 days postexposure, squamous cell metaplasia of the epiglottis in the larynx was observed in almost all rats tested at 6.7 mg Co/m^3^. The normalized severity score was approximately 20 based on this upper respiratory tract reactivity. The study authors stated that the 1 mg/m^3^ (0.2 mg Co/m^3^) level is a NOAEL for inhalation toxicity for this compound based on study results.

Selection of the Point of Departure for the MRL: The NOAEL of 0.2 mg Co/m^3^ for elevated neutrophils in BALF was selected as the point of departure (POD) for the acute-duration inhalation MRL.

Effects observed at the LOAEL include increased percentage of neutrophils in BALF and decreased BALF cell viability. Data were reported graphically for BALF neutrophils in the supplemental files (Viegas et al. 2022b); quantitative data were obtained via personal communication with study authors (Viegas 2024). Data for 1-day postexposure were selected for benchmark dose (BMD) modeling because it showed the best dose-response data (Table A-2). Data were fit to all available continuous models in EPA’s Benchmark Dose Software (BMDS) (version 3.3.2) using a benchmark response (BMR) of 1 standard deviation. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, benchmark concentration lower confidence limit (BMCL) that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Based on these criteria, none of the models tested adequately fit the data. Therefore, the NOAEL of 0.2 mg Co/m^3^ was selected as the POD for the acute-duration inhalation MRL.

Table A-2 Neutrophils in Bronchoalveolar Lavage Fluid in Female Rats 1 Day After a 4-Hour Inhalation Exposure to Cobalt Sulfate Heptahydrate

| Concentration in mg Co/m^3^
| 0 | 0.02 | 0.07 | 0.2 | 2.2 | 6.7
Neutrophils (%) | 4.6±3.31^a^ (5) | 1±0.61 (5) | 8.1±4.74 (5) | 3.9±2.3 (5) | 15.1±2.48^b^ (5) | 20.8±11.56^b^ (5)

a Mean±standard deviation (number of animals).

b p<0.01.

Source: Viegas 2024; Viegas et al. 2022b

Adjustment for Intermittent Exposure: The NOAEL of 0.2 mg Co/m^3^ was adjusted from intermittent exposure to continuous exposure using the following equation:

N O A E L_A D J_ = 0.2 m g C o / m^3^ × (4 hours)/(24 hours) = 0.03 m g C o / m^3^

Human Equivalent Concentration: While an inhalation PBPK model for cobalt is available (Unice et al. 2020a), this model was inadequate for interspecies extrapolation because model assumptions are based on human data for insoluble cobalt dust. There are no rat PBPK models to allow for interspecies extrapolation, and there are no models based on kinetics for soluble cobalt compounds. Therefore, a HEC was calculated using the following equation from Lee et al. (2019), adopted from NIOSH (2013):

N O A E L_H E C_ = N O A E L_A D J_ × (V R_R_)/(V R_H_) × (D F_R_)/(D F_H_) × ((1 - k_R_^n^)/(1 - k_R_))/((1 - k_H_^n^)/(1 - k_H_)) × (R H_R_)/(R H_H_) × (S A_H_)/(S A_R_)

where VR = ventilation rate, DF = deposition fraction, k = 1-clearance rate, RH = particle retention half-time, SA = alveolar surface area, n = exposure days, R = rat, and H = human.

For this equation, deposition fractions for rats and humans must be calculated. The regional deposited dose ratio (RDDR) for the pulmonary region is used to extrapolate deposited doses in rats to deposited doses in humans. The RDDR was calculated using the Multiple-Path Particle Dosimetry Model (MPPD version 3.04) developed by Applied Research Associates, Inc. (ARA) to first calculate the deposition fraction (DF) for rats and humans. The MPPD model parameters and results for the rat and human deposition fractions are presented in Table A-3. For breathing frequency and tidal volume parameter values in humans, a TWA of default values in males (ICRP 1994) was calculated based on the following activity pattern over a 24-hour exposure period: 8 hours sleeping (nasal breathing) + 8 hours at rest/sitting (nasal breathing) + 8 hours of light activity (oronasal-mouth breather). Default values in males were selected to be health protective, as males are predicted to have higher deposition fractions than females. The TWA values were then used in the calculation of the deposition fraction (to represent TWA deposition over a 24-hour period).

Table A-3 MPPD Model (Version 3.04) Inputs and Results for Rat and Human Models

Parameters | Rats | Humans
Deposition/clearance | Deposition only | Deposition only
Airway morphometry
Model | Asymmetric Multiple Path | Yem/Schum 5-Lobe
Functional residual capacity | 4 mL (default) | 3,300 mL (default)
Upper respiratory tract | 0.42 mL (default) | 50 mL (default)
Inhalant properties
Density^a^ | 1.95 g/cm^3^ | 1.95 g/cm^3^
Aspect ratio | 1 | 1
Diameter, MMAD^a^ | 1.87 μm | 1.87 μm
GSD^a^ | 2.49 | 2.49
Inhalability adjustment | On | On
Exposure conditions
Aerosol concentration (NOAEL_ADJ_) | 0.03 mg Co/m^3^ | 0.03 mg Co/m^3^
Breathing frequency | 102 breaths/minute (default) | 14.7 breaths/minute (calculated TWA)^b^
Tidal volume | 2.1 mL (default) | 875 mL (calculated TWA)^c^
Breathing scenario | Nose only | Nasal/oronasal-mouth breather^d^
Deposition/clearance | Deposition only | Deposition only
Results
Alveolar region deposition fraction (Total pulmonary deposition fraction) | 0.0363 | 0.1462

a Viegas et al. (2022b).

b Breathing frequency is 12 breaths/minute at sleep/rest and 20 breaths/minute with light activity (ICRP 1994).

c Tidal volumes are 625 mL at sleep, 750 mL at rest, and 1,250 mL with light activity (ICRP 1994).

d Breathing scenario is assumed nasal with sleep and at rest and oronasal-mouth with light activity.

ADJ = adjusted; GSD = geometric standard deviation; NOAEL = no-observed-adverse-effect level; MMAD = mass median aerodynamic diameter; MPPD = Multiple-Path Particle Dosimetry; TWA = time-weighted average

The deposition fractions calculated by the MPPD model and the daily ventilation rates were then used to calculate the NOAEL_HEC_. Table A-4 lists the values used within the equation and the source of these values. The exposure days (n) are 1 day to represent 24 hours of continuous exposure since the exposure concentration was adjusted from an intermittent to continuous exposure. Since clearance data are not available for cobalt sulfate heptahydrate, clearance data for nickel sulfate were used to approximate clearance in humans and rats (Oller et al. 2014).

N O A E L_H E C_ = 0.03 m g / m^3^ × (0.22 (m^3^)/(d a y))/(20 (m^3^)/(d a y)) × (0.0363)/(0.1462) × ((1 - (1 - 0.289 d a y^- 1^)^1^)/(1 - (1 - 0.289 d a y^- 1^)))/((1 - (1 - 0.277 d a y^- 1^)^1^)/(1 - (1 - 0.277 d a y^- 1^))) × (1)/(1.04) × (54 m^2^)/(0.34 m^2^) N O A E L_H E C_ = 0.01 m g C o / m^3^

Table A-4 Values Used to Calculate the NOAEL_HEC_ for Cobalt

Variable | Rats value (R) | Human value (H) | Source
Ventilation rate (VR) | 0.22 m^3^/day | 20 m^3^/day | EPA (1994)
Deposition fraction (DF) | 0.0363 | 0.1462 | Calculated using MPPD software
Clearance rate | 0.289 day^−1^ | 0.277 day^−1^ | Calculated from retention half-times in Oller et al. (2014)^a^
Retention half-time | 2.4 days | 2.5 days | Oller et al. (2014)
Ratio of retention half-time (RH) (to rat half-time) | 1 | 1.04 | Calculated
Alveolar surface area (SA) | 0.34 m^2^ | 54 m^2^ | EPA (1994)
Exposure days (n) | 1 day | 1 day | Viegas et al. (2022a)

a Total clearance rate= ln2/retention half-time; example: 0.693/2.4 days = 0.289 day^−1^.

HEC = human equivalent concentration; ln = natural logarithm; MPPD = Multiple-Path Particle Dosimetry; NOAEL = no-observed-adverse-effect level

Uncertainty Factor: The following uncertainty factors were applied to the NOAEL_HEC_ to derive the MRL:

- Uncertainty factor of 3 for extrapolation from animals to humans with dosimetric adjustments
- Uncertainty factor of 10 for human variability

Subsequently, the MRL for acute-duration exposure to cobalt via inhalation is:

M R L = (N O A E L_H E C_)/(( U F )) = (0.01 m g C o / m^3^)/(3 × 10) M R L = 0.0003 m g C o / m^3^

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that the respiratory tract is a known target of cobalt toxicity in humans following inhalation exposure based on a high level of evidence in humans and laboratory animals (Appendix C).

Findings in occupational cohorts of workers exposed to cobalt include reports of adverse respiratory symptoms (e.g., cough, phlegm, wheezing), impaired lung function, and asthma (Gennart and Lauwerys 1990; Hamzah et al. 2014; Kusaka et al. 1986a, 1986b; Linna et al. 2003; Nemery et al. 1992; Swennen et al. 1993; Walters et al. 2012). In laboratory animals, acute-duration exposure is associated with inflammatory responses at low concentrations (Burzlaff et al. 2022a; Viegas et al. 2022a) and severe lung damage at lethal concentrations (Palmes et al. 1959; Viegas et al. 2022a). Dose- and duration-dependent damage throughout the respiratory tract is consistently observed in rodents following intermediate- or chronic-duration inhalation exposure (Burzlaff et al. 2022a; NTP 1991, 1998, 2014). Specifically, the critical effect of elevated neutrophils in BALF has also been observed in Wistar rats exposed to cobalt sulfate heptahydrate at concentrations ≥0.46 mg Co/m^3^ for 28 days (Burzlaff et al. 2022a, 2022b). Respiratory effects have also been noted in rabbits and pigs following intermediate-duration inhalation exposure (Johansson et al. 1987; Kerfoot 1974).

Agency Contact (Chemical Manager): Sam Keith, MS, CHP

## Cobalt and compounds Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cobalt and compounds
CAS Numbers: | 7440-48-8
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: The available intermediate-duration inhalation data are not considered adequate for derivation of an intermediate-duration inhalation MRL for cobalt. No human exposure studies for this duration were identified. While numerous laboratory animal studies are available, an MRL based on the available studies would result in an intermediate-duration inhalation MRL value lower than the chronic-duration inhalation MRL value based on human data. Due to the higher confidence in an MRL based on human data, no intermediate-duration inhalation MRL is proposed for cobalt.

Rationale for Not Deriving an MRL: No studies evaluating cobalt toxicity in humans following intermediate-duration inhalation exposure were identified. However, animal toxicity studies evaluating a comprehensive set of endpoints were available (Burzlaff et al. 2022a; NTP 1991, 2014). These studies consistently identify the respiratory system as the most sensitive target of toxicity for various cobalt compounds in both rats and mice. Additional studies confirm that the respiratory tract is a target of toxicity in rabbits and pigs following intermediate-duration inhalation exposure (Johansson et al. 1992; Kerfoot 1974).

The NOAELs and LOAELs for respiratory effects from intermediate-duration inhalation studies are presented in Table A-5. The lowest LOAEL identified for intermediate-duration inhalation exposure (0.114 mg Co/m^3^; NTP 1991) was identified as a potential POD for the intermediate-duration inhalation MRL. BMD modeling was attempted for all respiratory lesions in female rats and male and female mice reported at 0.114 mg Co/m^3^ by NTP (1991); male rat squamous metaplasia data were not amenable to modeling (incidence was 100% at all administered concentrations). Incidence data for these lesions are presented in Table A-6. The data amenable to modeling were fit to all available dichotomous models in EPA’s BMDS (version 3.3.2) using the extra risk option with a BMR of 10%. Adequate model fit was judged as described in the acute-duration section above. Model fits were obtained for squamous metaplasia in female rats only, resulting in benchmark concentration (BMC) and BMCL values of 0.029 and 0.021 mg Co/m^3^, respectively. That BMCL value of 0.021 mg Co/m^3^ provided the lowest candidate POD (Table A-7).

Table A-5 Summary of NOAEL and LOAEL Values for Respiratory Effects Following Intermediate-Duration Inhalation Exposure to Cobalt and Compounds

Species (strain)/number | Duration/frequency | NOAEL (mg Co/m^3^) | LOAEL (mg Co/m^3^) | Effect | Compound | Reference
Rat (F344/N); Mouse (B6C3F1); 10 M, 10 F | 13 weeks; 5 days/week; 6 hours + 12 minutes^a^/day | ND | 0.114 | Squamous metaplasia of the larynx in both sexes in rats and mice; histiocytic infiltrates in the lungs in male mice | Cobalt sulfate heptahydrate^b^ | NTP 1991
Pig; 5 NS | 3 months; 5 days/week; 6 hour/day | ND | 0.115 | Decreased lung compliance | Cobalt metal | Kerfoot 1974
Rabbit; (NS) 8 M | 17 weeks; 5 days/week 6 hours/day | ND | 0.4 | Moderate lung inflammation and accumulation of macrophages | Cobalt metal | Johansson et al. 1987
Rat (Wistar); 10 M, 10 F | 28 days; 6 hours/day | ND | 0.43 | Slight focal squamous metaplasia and inflammatory changes; increased BALF LDH levels and neutrophils in males | Cobalt sulfate heptahydrate^c^ | Burzlaff et al. 2022a, 2022b
Rabbit; (NS) 8 M | 4 months; 5 days/week; 6 hours/day | 0.5 | ND | | Cobalt chloride | Johansson et al. 1991
Rabbit; (NS) 8 M | 4 months; 5 days/week; 6 hours/day | ND | 0.6 | Inflammatory lesions in the lung; increased cellularity of BALF | Cobalt chloride | Johansson et al. 1992
Rat (F344/N); 10 M, 10 F | 14 weeks; 5 days/week; 6 hours + 12 minutes^a^/day | ND | 0.625 | Chronic active inflammation in lung, pulmonary alveolar proteinosis; increased relative lung weight | Cobalt metal | NTP 2014
Mouse (B6C3F1); 10 M, 9–10 F | 14 weeks; 5 days/week; 6 hours + 12 minutes^a^/day | ND | 0.625 | Squamous metaplasia of the larynx; cytoplasmic vacuolization of bronchiole epithelium and alveolar histiocytic cellular infiltration | Cobalt metal | NTP 2014
Mouse (B6C3F1); 5 M, 5 F | 16 days; 5 days/week; 6 hours + 12 minutes^a^/day | 0.19 | 1.8 (SLOAEL) | Inflammation and necrosis of respiratory epithelium (larynx, trachea, bronchioles, nasal turbinates); degeneration of olfactory epithelium | Cobalt sulfate heptahydrate^b^ | NTP 1991
Rat (F344/N); 5 M, 5 F | 16 days; 5 days/week; 6 hours + 12 minutes^a^/day | ND | 2.5 | Minimal cytoplasmic vacuolization of bronchiolar epithelium; minimal-to-mild atrophy and necrosis of olfactory epithelium | Cobalt metal | NTP 2014
Mouse (B6C3F1); 5 M, 5 F | 17 days; 5 days/week; 6 hours + 12 minutes^a^/day | ND | 2.5 | Minimal-to-mild nasal lesions; minimal cytoplasmic vacuolization of bronchiolar epithelium with histiocytic infiltrates in males | Cobalt metal | NTP 2014
Rat (Wistar); 10 M, 10 F | 28 days; 6 hours/day | 3.76 | 15.05 | Alveolar lipoproteinosis, increased LDH and polymorphonuclear neutrophils in BALF | Cobalt tetraoxide | Burzlaff et al. 2022a
Rat (F344/N); 5 M, 5 F | 16 days; 5 days/week; 6 hours + 12 minutes^a^/day | 1.8 | 19 (SLOAEL) | Respiratory tract lesions (inflammation, necrosis, hyperplasia, metaplasia, acanthosis, fibrosis, histiocytic infiltration) | Cobalt sulfate heptahydrate^b^ | NTP 1991

a Exposure was for 6 hours plus T_90_ time (12 minutes); T_90_ time = the time to reach 90% of the target chamber concentration.

b Exposure chamber analysis showed that aerosolization of the test substance (cobalt sulfate heptahydrate) resulted in exposure to cobalt sulfate hexahydrate (Behl et al. 2015).

c Cobalt sulfate heptahydrate is unstable at room temperature and humidity levels <70% (Redhammer et al. 2007), converting into cobalt sulfate hexahydrate. It is likely that the analytically determined concentrations were in terms of cobalt sulfate hexahydrate, consistent with Behl et al. (2015). While temperature and humidity were not reported for this study, humidity was <70% in the inhalation chamber in other studies by this laboratory (Viegas 2024).

BALF = bronchoalveolar lavage fluid; F = females; FVC = forced vital capacity; LDH = lactate dehydrogenase; M = males; ND = not determined; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; SLOAEL = serious LOAEL

Table A-6 Sensitive Respiratory Lesions Rats and Mice Following Intermittent Exposure to Cobalt Sulfate Heptahydrate for 13 Weeks

| Concentration (mg Co/m^3^)
| 0 | 0.114 | 0.346 | 1.11 | 3.78 | 11.4
Squamous metaplasia of the larynx
Male rats | 0/10^a^ | 9/9^b^ | 10/10^b^ | 10/10^b^ | 10/10^b^ | 10/10^b^
Female rats | 1/10 | 7/8^b^ | 10/10^b^ | 10/10^b^ | 10/10^b^ | 10/10^b^
Male mice | 0/10 | 7/10^b^ | 10/10^b^ | 5/9^c^ | 9/10^b^ | 10/10^b^
Female mice | 0/10 | 8/10^b^ | 8/10^b^ | 8/9^b^ | 9/10^b^ | 9/9^b^
Histiocytic infiltrates in the lungs
Male mice | 0/10 | 10/10^b^ | 9/10^b^ | 10/10^b^ | 10/10^b^ | 10/10^b^

a Affected animals/total animals.

b p<0.01.

c p<0.05.

Source: NTP 1991

Table A-7 Candidate PODs for Intermediate-Duration Inhalation MRL based on Respiratory Effects in Rodents Exposed to Cobalt Sulfate Heptahydrate for 13 Weeks

Effect (species, sex) | Effect level (mg Co/m^3^)
Effect (species, sex) | NOAEL | LOAEL | BMCL | BMC
Squamous metaplasia of the larynx (rat, male) | ND | 0.114 | ND | ND
Squamous metaplasia of the larynx (rat, female) | ND | 0.114 | 0.021 | 0.029
Squamous metaplasia of the larynx (mouse, male) | ND | 0.114 | NA | NA
Squamous metaplasia of the larynx (mouse, female) | ND | 0.114 | NA | NA
Histiocytic infiltrates in the lungs (mouse, male) | ND | 0.114 | NA | NA

BMC = benchmark concentration; BMCL = 95% lower confidence limit on the benchmark concentration; LOAEL = lowest-observed-adverse-effect level; NA = not applicable (modeling attempted; no adequate models); ND = not determined; NOAEL = no-observed-adverse-effect level; POD = point of departure

Source: NTP 1991

The BMCL of 0.021 mg Co/m^3^ was adjusted for continuous exposure (6.2 hours/24 hours; 5 days/7 days) to a BMCL_ADJ_ of 0.0039 mg Co/m^3^ and converted into a BMCL_HEC_ of 0.0023 mg Co/m^3^ using the methodology and equations shown in the acute-duration MRL section above and the values shown in Table A-8. Using the BMCL_HEC_ of 0.0023 mg Co/m^3^ as the final POD and a total uncertainty factor of 30 (3 for extrapolation from animals to humans and 10 for human variability) would result in an intermediate-duration inhalation MRL of 0.00008 mg Co/m^3^ (8×10^−5^ mg Co/m^3^). However, this value is not proposed for the intermediate-duration inhalation MRL because the value would be lower than the chronic-duration inhalation MRL based on respiratory effects in humans. The confidence in the chronic-duration MRL is much higher due to study population (human), which precludes the need for interspecies extrapolation and associated uncertainties.

Table A-8 Values Used to Calculate the BMCL_HEC_ for Cobalt

Variable | Rats value (R) | Human value (H) | Source
Ventilation rate (VR) | 0.17 m^3^/day | 20 m^3^/day | EPA (1994) ^a^
Deposition fraction (DF) | 0.0653 | 0.1370 | Calculated using MPPD software
Clearance rate | 0.289 day^−1^ | 0.277 day^−1^ | Calculated from retention half-times in Oller et al. (2014)^b^
Retention half-time | 2.4 days | 2.5 days | Oller et al. (2014)
Ratio of retention half-time (RH) (to rat half-time) | 1 | 1.04 | Calculated
Alveolar surface area (SA) | 0.34 m^2^ | 54 m^2^ | EPA (1994)
Exposure days (n) | 91 days | 91 days | NTP (1991)

a The average of the starting and final body weights from the dose groups above and below the BMCL (0.144 kg) from NTP (1991) was used to calculate the VR (instead of the default body weight of 0.124 kg provided in EPA 1994).

b Total clearance rate= ln2/retention half-time; example: 0.693/2.4 days = 0.289 day^−1^.

HEC = human equivalent concentration; ln = natural logarithm; MPPD = Multiple-Path Particle Dosimetry; NOAEL = no-observed-adverse-effect level

Agency Contact (Chemical Manager): Sam Keith, MS, CHP

## Cobalt and compounds Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cobalt and compounds
CAS Numbers: | 7440-48-8
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic
MRL: | 0.0001 mg Co/m^3^ (1×10^−4^ mg Co/m^3^)
Critical Effect: | Respiratory reduced spirometry parameter values
Reference: | Nemery et al. 1992
Point of Departure: | NOAEL of 0.0053 mg/m^3^ (NOAEL_ADJ_ of 0.0013 mg/m^3^)
Uncertainty Factor: | 10
LSE Graph Key: | 28
Species: | Human

MRL Summary: A chronic-duration inhalation MRL of 0.0001 mg Co/m^3^ was derived for cobalt based on reduced spirometry parameter values in workers exposed chronically to cobalt in air (Nemery et al. 1992). The MRL is based on a NOAEL of 0.0053 mg Co/m^3^, which was adjusted for intermittent exposure to a continuous exposure concentration of 0.0013 mg Co/m^3^ and divided by a total uncertainty factor of 10 for human variability.

Selection of the Critical Effect: Several occupational studies examining chronic-duration inhalation exposure to cobalt support respiratory toxicity as the critical effect (Gennart and Lauwerys 1990; Hamzah et al. 2014; Kusaka et al. 1986a; Linna et al. 2003; Nemery et al. 1992; Swennen et al. 1993). Chronic-duration inhalation studies in animals support that the respiratory system is the most sensitive target of cobalt toxicity in rodents (NTP 1998, 2014; Wehner et al. 1977). The lowest LOAEL for respiratory effects is 0.0151 mg Co/m^3^ for reduced spirometry parameters, coughing, wheezing, and upper airway irritation; this finding is associated with a NOAEL of 0.0053 mg Co/m^3^ (Nemery et al. 1992). Case studies show that the sensitization of lymphocytes by cobalt potentially plays a crucial role in some of the respiratory effects (e.g., wheezing, asthma) that are observed in the exposed workers (Krakowiak et al. 2005; Shirakawa et al. 1988, 1989). Limitations of Kusaka et al. (1986a) and Swennen et al. (1993) is the workers’ co-exposure to tungsten, carbide, and cobalt. A study by Gennart and Lauwerys (1990) measured the cobalt air concentrations from two rooms where the workers were moving between freely and no stay times were provided. The absence of this information did not allow estimation of the average exposure for the workers; therefore, a reliable exposure estimate cannot be determined and this study cannot be used to derive an MRL. Sauni et al. (2010) conducted a case study of occupational asthma in cobalt plant workers in Finland from 1967 to 2003 where the mean air concentrations of cobalt in different departments ranged from 0.03 to 0.15 mg/m^3^. Until 1987, cobalt was being produced from pyrite ore concentrate, which resulted in occupational co-exposures to sulphur dioxide (SO_2_) and ammonia (NH_3_). These gases are both known respiratory irritants (Andersson et al. 2006; ATSDR 1998; Huber and Loving 1991). After 1987, cobalt was produced using byproducts of metallurgic industry as raw material, which eliminated the co-exposure to the irritant gases, and the incidence of asthma reduced to only one case. Therefore, it is likely that the health effects observed in this study were due to the co-exposure to sulphur dioxide and ammonia and not cobalt alone. Due to this reason, Sauni et al. (2010) cannot be used to derive an MRL.

Rats, mice, and hamsters showed lethality, respiratory effects, and cancer effects after chronic-duration inhalation exposure to cobalt at concentrations higher than those in the human studies (NTP 1998, 2014; Wehner et al. 1977). Wehner et al. (1977) used a high concentration of 7.9 mg Co/m^3^ for a lifetime exposure in hamsters, resulting in lung inflammation and emphysema. In the NTP (1998) study, mice showed respiratory effects at the lowest exposure concentration in the chronic-duration inhalation database (0.06 mg Co/m^3^) in addition to cancer effects, which included hyperplasia of the squamous epithelium in the larynx. Although rats did not show serious respiratory health effects, the lowest concentration caused cancer effects in rats (alveolar/bronchiolar neoplasms along with metaplasia of the nose and epiglottis) (NTP 1998). In the NTP (2014) study, the concentration of 1.25 mg Co/m^3^ produced serious respiratory and cancer effects in both rats and mice; cancer effects included increased incidence of mononuclear cell leukemia in rats and increased rate of alveolar/bronchiolar carcinoma in mice. The NOAELs and LOAELs for chronic-duration inhalation exposure studies are presented below in Table A-9.

Table A-9 Summary of Respiratory NOAEL and LOAEL Values of Chronic-Duration Inhalation Exposure to Cobalt

Species (sex) | Frequency/duration | NOAEL (NOAEL_ADJ_) (mg/m^3^) | LOAEL (LOAEL_ADJ_) (mg/m^3^) | Effect | Compound | Reference
Human (M, F) | Current employees; duration of employment not reported (occupational) | 0.0053 (0.0013) | 0.0151 (0.0027) | Decreased FEV_1_ (5%) and FVC (5%); increased cough (11/91), wheezing (4/91), and upper airway irritation (40/91) in workers | Cobalt metal | Nemery et al. 1992
Human (M, F) | 21 years (occupational) | 0.0175 (0.004) | ND | | Cobalt metal | Deng et al. 1991
Human (M,F) | 8 years (occupational) | ND | 0.125 (0.03) | Dyspnea and wheezing | Hard metal | Swennen et al. 1993
Human (M, F) | 3 years (occupational) | ND | 0.126 (0.03) | 2.7% decrease in FEV_1_ in exposed workers | Hard metal | Kusaka et al. 1986b
Rat (M, F) | 105 weeks; 5 days/week; 6 hours/day | ND | 0.12 (0.02) (SLOAEL) | Hyperplasia and metaplasia of upper and lower respiratory tract tissues; pulmonary fibrosis; inflammatory changes in lungs | Cobalt sulfate heptahydrate^a^ | NTP 1998
Mice (M, F) | 105 weeks; 5 days/week; 6 hours/day | ND | 0.11 (0.02) (SLOAEL) | Squamous metaplasia of the larynx | Cobalt sulfate heptahydrate^a^ | NTP 1998
Rats (M, F) | 105 weeks; 5 days/week; 6 hours/day | ND | 1.25 (0.223) (SLOAEL) | Hyperplasic and metaplastic pulmonary and nasal lesions | Cobalt metal | NTP 2014
Mice (M, F) | 105 weeks; 5 days/week; 6 hours/day | ND | 1.25 (0.223) (SLOAEL) | Hyperplasic and metaplastic pulmonary and nasal lesions | Cobalt metal | NTP 2014
Hamster | Lifetime; 5 days/week; 7 hours/day | ND | 7.9 (1.4) (SLOAEL) | Lung Inflammation and emphysema | Cobalt oxide | Wehner et al. 1977

a Exposure chamber analysis showed that aerosolization of the test substance (cobalt sulfate heptahydrate) resulted in exposure to cobalt sulfate hexahydrate (Behl et al. 2015).

Selected study for the chronic-duration inhalation MRL derivation.

ADJ = adjusted; F = females; FEV_1_ = forced expiratory volume in 1 second; FVC = forced vital capacity; LOAEL = lowest-observed-adverse-effect level; M = males; ND = not determined; NOAEL = no-observed-adverse-effect level; SLOAEL = serious LOAEL

Selection of the Principal Study: The Nemery et al. (1992) study tested the lowest concentrations among all human and animal studies and demonstrated a dose-response relationship between reduced spirometry parameter values and cobalt exposure. Therefore, the Nemery et al. (1992) study was selected as the critical study because it identified the lowest NOAEL for chronic-duration inhalation exposure and a corresponding LOAEL.

While this study has limitations (discussed below in the Summary of the Principal Study), available data based on findings from the group analysis showing impaired lung function and increased subjective complaints of respiratory symptoms in the high-exposure group support identification of the low-exposure group mean (0.0053 mg Co/m^3^) as a NOAEL for respiratory effects. While causality cannot be determined in studies with cross-sectional design, findings from the systematic review presented in Appendix C (Respiratory effects are a known health effect for humans following inhalation exposure to cobalt) support that observed exposure-related effects are likely attributable to occupational exposure to cobalt.

Summary of the Principal Study:

Nemery B, Casier P, Roosels D, . 1992. Survey of cobalt exposure and respiratory health in diamond polishers. Am Rev Respir Dis 145:610–616. 10.1164/ajrccm/145.3.610.1312313

In a cross-sectional study, 194 diamond polishers from 10 different workshops were examined with 6–28 people from each workshop participating. In 8 out of 10 workshops, the polishing disks used were primarily cobalt-containing disks, while two workshops almost exclusively used cast iron polishing disks. Participation in the workshops varied from 56 to 100%, and low participation from some workshops reflects the fact that only workers who used cobalt disks were initially asked to be in the study, rather than a high refusal rate (only eight refusals were documented). A year later, three additional workshops with workers engaged in diamond sawing, cleaving, or jewelry drawing were studied as an unexposed control group (n=59 workers). All study subjects were administered questionnaires to report medical history and lifestyle factors, provided urine samples, and underwent clinical examination and lung function tests. Area and personal air samples were collected and analyzed for cobalt and iron. Other potential co-exposure substances (e.g., diamond dust and carbide) were not assessed. Sampling for area air determinations started 2 hours after work began and continued until 1 hour before the end of the workday.

Personal air samples were collected from the breathing zone of a few workers per workshop for four successive 1-hour periods. Air samples were not collected for one workshop; however, data from an identical workshop were used as a proxy since urinary cobalt levels between workers from both workshops were similar.

Nemery et al. (1992) showed a correlation (R=0.92) between the results of work area cobalt levels and personal cobalt air sampling, with area air sampling reporting lower concentrations than personal air samples in all workshops except one. The correlation between cobalt exposure, measured as urinary levels of cobalt, and air samples was significant (R=0.85–0.88) when one workshop with poor hygienic conditions was excluded. The study authors noted that the available methods used for air sampling may have underestimated the exposure levels. The polishing workshops were divided into two cobalt exposure groups: low (n=102) and high (n=91). Mean personal air sampling cobalt exposure concentrations were 0.0004, 0.0053, and 0.0151 mg/m^3^ in the control, low-exposure, and high-exposure groups, respectively. Other metals, such as copper and chromium, were detected, and some workers had previous occupational exposure to asbestos (use of asbestos containing glues), which was judged insufficient by the study authors to produce a functional impairment. The study authors noted that cobalt appears to be the only relevant exposure; however, details on the exposure duration were not provided.

Characteristics of the three groups were similar, with the exception that men in the referent group were slightly younger and taller than men in the exposed groups. The average respective ages in the control, low-, and high-exposure groups were 28.2, 32.1, and 32.8 years for men and 21.1, 25.9, and 25.4 years for women. The average respective heights in the control, low-, and high-exposure groups were 177.6, 175.9, and 174.2 cm for men and 163.6, 164.1, and 164.2 cm for women. For smoking status, 47, 41, and 37% of subjects had never smoked, 32, 41, and 50% were smokers, and 20, 18, and 13% were ex-smokers in the control, low-, and high-exposure groups, respectively.

Workers in the high-exposure groups were more likely to report eye, nose, and throat irritation and cough, compared to other groups. Cough was more frequently reported by female polishers than male polishers. No exposure-related difference was observed for other respiratory symptoms including dyspnea and wheezing. Reduced lung function in the high-exposure group was demonstrated by significantly lowered FVC and FEV_1_, even after consideration of smoking status. Additionally, maximal mid-expiratory flow and mean PEF rates were significantly lower in the high-exposure group compared to controls and the low-exposure group. The work-related upper airway effects were seen in 30% of controls, 26% of low dose individuals, and 43% of high dose individuals. Work-related cough was not observed in the control subjects but was observed in 4% of the low-dose exposure group and in 12% of the high-dose exposure group. There was no correlation between cobalt exposure and respiratory effects on an individual level within this group; correlations occurred only on a group level: low, high, and control. However, the higher rate of smokers in exposed workers, compared to control, confounds interpretation of the incidence of work-related cough; no group analyses with adjustment for smoking status were performed. Two-way analysis of variance showed that exposure-related effects on spirometric parameters in the high-dose exposure groups were present in men and women. Women appeared to be more affected than men, but the difference was not significant. Spirometric parameters did not differ significantly between the controls and the low-exposure dose group. Smoking did exert a strong effect on lung function, but lung function remained inversely correlated with exposure to cobalt, independent of smoking. The spirometric parameters for men and women and the combined unweighted values for FVC and FEV_1_ are presented in Table A-10.

Table A-10 FVC and FEV_1_ Values in Humans Exposed to Inhaled Cobalt in an Occupational Setting^a^

Dose (mg Co/m^3^) | | 0.0004 (control) | | 0.0053 (low exposure) | | 0.0151 (high exposure)
Number (total/men/women) | | 59/46/13 | | 102/93/9 | | 92/73/19
Parameter | | Mean | SD | Mean | SD | Mean | SD
FVC (mL) | Men | 5,648 | 936 | 5,445 | 754 | 5,184 | 799
| Women | 4,033 | 688 | 4,018 | 627 | 3,733 | 592
| Total (weighted) | 5,292 | 1,110.6 | 5,319 | 845.2 | 4,884 | 960.85
FEV_1_ (mL) | Men | 4,644 | 803 | 4,451 | 679 | 4,191 | 712
| Women | 3,416 | 634 | 3,468 | 384 | 3,123 | 599
| Total (weighted) | 4,373 | 920.31 | 4,364 | 714.24 | 3,970 | 813.04

a Means and standard deviations for men and women are raw data from Table 4 in Nemery et al. (1992). Total (weighted) combines data for men and women to calculate the weighted means and standard deviations of the data.

FEV_1_ = forced expiratory volume in 1 second; FVC = forced vital capacity; SD = standard deviation

Source: Nemery et al. (1992)

In addition to limitations described above (e.g., lack of control for other potential exposures, use of proxy exposure data), there are additional study limitations to consider. As with all cross-sectional studies, causality between cobalt exposure and observed outcomes cannot be definitively determined. Also, the statistical analysis for spirometry data did not adjust for known characteristics that can affect lung function in addition to smoking status, such as age and height. Lastly, the exposure duration for workers was not reported.

Selection of the Point of Departure for the MRL: The NOAEL of 0.0053 mg/m^3^ for reduced respiratory function in male and female workers was selected as the basis for the chronic-duration inhalation MRL. The weighted data for spirometric parameters in both males and females (presented in Table A-10) were amenable to BMD modeling. The weighted data for FVC and FEV_1_ were each modeled separately, and each dataset was fit to all available continuous models in EPA’s BMDS (version 3.3.2). Adequate model fit was judged as described in the acute-duration section above. A BMR of 1 standard deviation from the control mean was selected in the absence of a biologically based BMR.

Results of the BMD modeling for FVC and FEV_1_ are presented in Tables A-11 and A-12, respectively. Using the criteria listed above, only the Linear model provides an adequate fit to the FVC and the FEV_1_ data. However, for both endpoints, both the BMC and BMCL values were higher than the maximum concentration in the dataset, lending considerable uncertainty to the model. These results are due, in part, to the large variance in the control groups, which directly impacts the outcome of the default BMR of 1 standard deviation. Based on BMC and BMCL values outside the range of concentrations in the dataset, the extrapolated BMCL values were not considered suitable as the basis for the POD for the MRL. In the absence of a suitable BMD model, the NOAEL of 0.0053 mg/m^3^ for reduced respiratory function in male and female workers was selected as the POD for the chronic-duration inhalation MRL.

Table A-11 Model Predictions (Constant Variance) for FVC in Workers Exposed to Cobalt Chronically via Inhalation (Nemery et al. 1992)

Model | BMD_1SD_^a^ (mg/m^3^) | BMDL_1SD_^a^ (mg/m^3^) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/m^3^) | BMDL_1SD_^a^ (mg/m^3^) | Test 4 p-value^b^ | AIC
Model | BMD_1SD_^a^ (mg/m^3^) | BMDL_1SD_^a^ (mg/m^3^) | Test 4 p-value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential 3^d^ | | | NA | 4,194.69 | −9.07×10^−7^ | NA
Exponential 5^d^ | | | NA | 4,194.69 | −1.99×10^−7^ | NA
Hill^d^ | | | NA | 4,194.69 | −1.04×10^−6^ | NA
Polynomial Degree 2^d^ | | | 0.01 | 4,192.95 | 1.74 | NA
Power^d^ | | | NA | 4,194.69 | 4.16×10^−8^ | NA
Linear | 0.0294 | 0.0193 | 0.21 | 4,194.24 | −0.3210 | NA

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control); FVC = forced vital capacity; NA= not applicable, goodness-of-fit test could not be performed

Table A-12 Model Predictions (Constant Variance) for FEV_1_ in Workers Exposed to Cobalt Chronically via Inhalation (Nemery et al. 1992)

Model | BMD_1SD_^a^ (mg/m^3^) | BMDL_1SD_^a^ (mg/m^3^) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/m^3^) | BMDL_1SD_^a^ (mg/m^3^) | Test 4 p-value^b^ | AIC
Model | BMD_1SD_^a^ (mg/m^3^) | BMDL_1SD_^a^ (mg/m^3^) | Test 4 p-value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential 3^d^ | | | NA | 4,106.64 | −6.99×10^−7^ | NA
Exponential 5^c,d^ | | | NA | 4,108.64 | −4.67×10^−7^ | NA
Hill^d^ | | | NA | 4,108.64 | 5.73×10^−7^ | NA
Polynomial Degree 2^d^ | | | <0.0001 | 4,120.19 | −0.157 | 2.541
Power^d^ | | | NA | 4,106.64 | −6.60×10^−7^ | NA
Linear | 0.0258 | 0.0177 | 0.25 | 4,105.97 | −0.294 | NA

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control); FEV_1_ = forced expiratory volume in 1 second; NA = not applicable, goodness-of-fit test could not be performed

Adjustment for Intermittent Exposure: Assuming workers in Nemery et al. (1992) were exposed only at work, the NOAEL was adjusted to account for a continuous work-day exposure (0.0053 mg/m^3^, Table A-9). A typical workweek of 8 hours/day, 5 days/week was assumed:

N O A E L_A D J_ = 0.0053 m g / m^3^ × (8 hours)/(24 hours) × (5 days)/(7 days) = 0.0013 m g / m^3^

Uncertainty Factor: The NOAEL_ADJ_ is divided by a total uncertainty factor of 10:

- 10 for human variability

Subsequently, the MRL for chronic-duration exposure to cobalt via inhalation is:

M R L = (N O A E L)/(U F s) = (0.0013 m g C o / m^3^)/(10) M R L = 0.00013 m g C o / m^3^ ( rounded to 0.0001 m g C o / m^3^)

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that the respiratory tract is a known target of cobalt toxicity in humans following inhalation exposure based on a high level of evidence in humans and laboratory animals (Appendix C).

Findings in occupational cohorts of workers exposed to cobalt include reports of adverse respiratory symptoms (e.g., cough, phlegm, wheezing), impaired lung function, and asthma (Gennart and Lauwerys 1990; Hamzah et al. 2014; Kusaka et al. 1986a, 1986b; Linna et al. 2003; Nemery et al. 1992; Swennen et al. 1993; Walters et al. 2012). In laboratory animals, acute-duration exposure is associated with inflammatory responses at low concentrations (Burzlaff et al. 2022a; Viegas et al. 2022a) and severe lung damage at lethal concentrations (Viegas et al. 2022a; Palmes et al. 1959). Dose- and duration-dependent damage throughout the respiratory tract is consistently observed in rodents following intermediate- or chronic-duration inhalation exposure (Burzlaff et al. 2022a; NTP 1991, 1998, 2014). Respiratory effects have also been noted in rabbits and pigs following intermediate-duration inhalation exposure (Johansson et al. 1987; Kerfoot 1974).

Agency Contact (Chemical Manager): Sam Keith, MS, CHP

## Cobalt and compounds Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cobalt and compounds
CAS Numbers: | 7440-48-8
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.03 mg Co/kg/day
Critical Effect: | Transient polycythemia (clinically elevated red blood cell levels)
Reference: | Davis and Fields 1958
Point of Departure: | Minimal LOAEL of 1 mg Co/kg/day
Uncertainty Factor: | 30
LSE Graph Key: | 1
Species: | Human

MRL Summary: An acute-duration oral MRL of 0.03 mg Co/kg/day was derived for cobalt based on a hematological endpoint of transient production of polycythemia (clinically elevated red blood cell levels) in humans orally exposed to cobalt chloride for 7–14 days (Davis and Fields 1958). The MRL is based on a minimal LOAEL of 1 mg Co/kg/day, which was divided by a total uncertainty factor of 30 (10 for human variability and 3 for use of a minimal LOAEL).

Selection of the Critical Effect: The most sensitive effects in humans following acute-duration oral exposure to cobalt are gastrointestinal upset, impaired thyroid function, and hematological effects. However, based on systematic review (Appendix C), gastrointestinal effects are not classifiable as to their toxicity to humans following oral exposure to cobalt; therefore, they were not considered as a potential critical effect. The NOAELs and LOAELs for hematological and thyroid effects in humans and animals are shown in Table A-13. The lowest LOAELs for hematological and thyroid effects ranged from 0.54 to 1 mg Co/kg/day in humans (Davis and Fields 1958; Paley et al. 1958; Roche and Layrisse 1956). However, the study by Paley et al. (1958) was determined to be a third-tier study based on risk of bias evaluation (Appendix C). Due to high risk of bias associated with this study, it was not considered further for MRL development. Therefore, remaining candidate MRLs for thyroid and hematological effects had equivalent LOAELs of 1 mg Co/kg/day based on LOAELs. Based on systematic review of the entire oral database (Appendix C), evidence is stronger for hematological effects (presumed health effect based on a moderate level of evidence in humans and high level of evidence in animals) than thyroid effects (suspected health effect based on a low level of evidence in humans and a moderate level of evidence in animals). Since effects occur at the same exposure level, the health effect with a stronger weight-of-evidence (hematological effects) was selected as the critical effect.

Table A-13 Select NOAEL and LOAEL Values Following Acute-Duration Oral Exposure to Cobalt and Compounds

Species | Duration | NOAEL (mg Co/kg/day) | LOAEL (mg Co/kg/day) | Effect | Compound | Reference
Hematological effects
Human; 8–16 M | 7–14 days | 0.03 | ND | | Cobalt (II) | Hoffmeister et al. 2018
Human; 5 M | 7–14 days | ND | 1 | Polycythemia (14% increase in erythrocyte levels, compared to pre-exposure values) | Cobalt chloride | Davis and Fields 1958
Rat; 6 M | 7 days | ND | 12.5 | Increased hematocrit and hemoglobin levels | Cobalt chloride hexahydrate | Shrivastava et al. 2008
Rat; 8 M | 7 days | ND | 12.5 | Increased red blood cell count, hematocrit, and hemoglobin; increased percent granulocytes and monocytes | Cobalt chloride hexahydrate | Shrivastava et al. 2010
Rat; 8 M | 8 days | 12.4 | 24.8 | Increased hematocrit, hemoglobin, and reticulocytes | Cobalt chloride hexahydrate | Paternain and Domingo 1988
Rat; 20 M | Once | ND | 161 | Increased hematocrit | Cobalt chloride hexahydrate | Domingo and Llobet 1984
Thyroid effects
Human; 3 M | 10–14-days | ND | 0.54 | Impaired thyroid uptake of radioactive iodine-131 | Cobalt chloride | Paley et al. 1958
Human; 12 NS | 14 days | ND | 1 | Impaired thyroid uptake of radioactive iodine-131 | Cobalt chloride | Roche and Layrisse 1956

Selected study for the acute-duration oral MRL derivation.

M = males; ND = not determined; NS = not specified

Selection of the Principal Study: Davis and Fields (1958) was selected as the principal study because it identifies the lowest LOAEL for the critical effect (hematological effects).

Summary of the Principal Study:

Davis JE, Fields JP. 1958. Experimental production of polycythemia in humans by administration of cobalt chloride. Proc Soc Exp Biol Med 99:493–495. 10.3181/00379727-99-24395.13601915

Five apparently healthy men, ages 20–47 years, were administered a daily dose split equally across mealtimes of cobalt chloride, as a 2% solution diluted in either water or milk daily. The subjects were regularly dosed for 14 days with equally divided doses at mealtimes. It is noted that one of these subjects (subject 4) continued treatment past 14 days; these data are not included in this acute-duration analysis. In this study, each subject served as their own control, and blood samples were collected from each subject 7–14 days prior to the onset of oral administration. Each of the five subjects received 150 mg cobalt chloride per day for up to 14 days. Blood samples were obtained daily from free-flowing punctures of fingertips at least 2 hours after eating, and at least 15 hours after the last dosage of cobalt. Blood was analyzed for red blood cell count, hemoglobin percentage, leukocyte count, reticulocyte percentage, and thrombocyte count. A crucial limitation of this study was that there was only one dose used in this study, which all five participants received.

Exposure to cobalt resulted in the development of polycythemia (as reported by the study authors) in all five subjects. The erythrocyte data from the study were only presented graphically. In order to understand the magnitude of the effect, the graph (Figure 1 in the publication) was digitized using an open-source software, Curve Snap, to better inform the oral acute-duration MRL derivation. Digitized data are presented in Tables A-14 (baseline data) and A-15 (data during treatment period). At baseline, the red blood cell numbers averaged over subjects over 4 days prior to exposure were 5.6 million cells/mm^3^. At the end of exposure for 7–14 days, the average red blood cell number had increased to 6.4 million cells/mm^3^, an increase in 14%. For all five subjects, measured values at the end of the exposure were above the clinically normal red blood cell levels for adult male men of 4.7–6.1 million cells/mm^3^ (NLM 2022a). Erythrocyte counts returned to baseline levels (within medical norms) for all individuals 4–9 days after cessation of cobalt administration.

Table A-14 Data Extracted from Figure 1 in Davis and Fields (1958): Erythrocyte Levels Before Administered Cobalt Exposure (Red Blood Cells in Millions/mm^3^)

Person # | Symbol | Pretreatment day 1 | Pretreatment day 2 | Pretreatment day 3 | Pretreatment day 4 | Average
1 | • | 6.0 | 6.1 | 5.8 | 6.2 | 6.0
3 | · | 5.7 | 5.6 | 5.5 | 5.6 | 5.6
4 | □ | 5.6 | 5.6 | 5.5 | 5.5 | 5.6
5 | ○ | 5.5 | 5.5 | 5.6 | 5.7 | 5.6
6 | △ | 5.6 | 5.3 | 5.5 | 5.4 | 5.5
| | Average pretreatment erythrocytes levels (in millions/mm^3^): | | | | 5.6

Table A-15 Data Extracted from Figure 1 in Davis and Fields (1958): Erythrocyte Levels During Acute-Duration Cobalt Exposure for 7–14 days (Red Blood Cells in Millions/mm^3^)

Person # | Symbol | Days of acute cobalt exposure
Person # | Symbol | 0 | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12 | 13 | 14 | Average Days 7–14
1 | • | 6.0 | | | 6.2 | | 6.4 | | 6.5 | 6.6 | 7.2 | 6.7 | | | | | 6.8
3 | · | 5.6 | 5.8 | 5.9 | 6.1 | 6.4 | 6.5 | 6.5 | 6.3 | | | | | | | | 6.3
4 | □ | 5.6 | 5.6 | 5.7 | | 5.7 | 6.0 | 6.0 | 6.2 | | 6.4 | 6.5 | 6.5 | 6.4 | 6.3 | | 6.4
5 | ○ | 5.5 | 5.7 | 5.9 | | 5.8 | 6.0 | | 6.1 | | 6.3 | 6.5 | | 6.4 | 6.4 | | 6.3
6 | △ | 5.4 | 5.5 | 5.5 | | 5.6 | 5.9 | 6.0 | | 6.2 | | 6.2 | | 6.2 | 6.4 | 6.4 | 6.3
| | | | | | | Average erythrocytes after exposure for 7–14 days (in millions/mm^3^): | | | | | | | | | | 6.4
| | | | | | | Average erythrocytes on the final day of exposure (in millions/mm^3^): | | | | | | | | | | 6.4
Percent increase in erythrocyte levels after acute-duration exposure for 7–14 days, compared to pretreatment levels: | | | | | | | | | | | | | | | | | 14%

No conclusions can be made regarding other hematological findings from this study due to inadequate data reporting. All subjects in this study (including the four exposed for ≤14 days, the one exposed >14 days at 1 mg Co/kg/day, a sixth subject exposed for >14 days to a different exposure paradigm) showed increased reticulocyte counts ranging from 1.9 to 2.7% (normal range 0.5–2.5%; NLM 2022b), with all but one showing an increase of at least 2-fold. Based on data-reporting, it cannot be determined which subjects had values above the normal range of 0.5–2.5% (NLM 2022b), or which individual showed a mild change <2-fold. Similarly, increases in hemoglobin percentages were reported to a “lesser extent” in subjects, compared to observed increases in red blood cell levels. Increases in all subjects were reportedly 6–11%, compared to pre-exposure values; hemoglobin values per subject were not reported. No exposure-related changes in total leukocyte or thrombocyte counts were observed, compared to pre-exposure values.

Selection of the Point of Departure for the MRL: Davis and Fields (1958) identified a LOAEL of 1 mg Co/kg/day for polycythemia indicated by increased levels of erythrocytes in human males exposed daily for up to 14 days. Data from the study identified a minimal LOAEL of 1 mg Co/kg/day for this effect, which was used as the POD to derive an MRL. The study reported a daily high dose intake of 150 mg cobalt chloride/day, which was converted to a daily dose of cobalt using a reference body weight of 70 kg for adult humans:

150 m g C o C l_2_ / day = 150 × (58.9 (g)/(m o l) C o)/(128.8 (g)/(m o l) C o C l_2_) = 68.1 m g C o / day

Based on assuming a 70-kg body weight of the subjects in the study:

(68 m g Co/day)/(70 k g (body weight of an adult human male )) = ∼ 1 m g C o / k g / d a y

The available data in Davis and Fields (1958) are not amenable to BMD modeling as the study only tested one exposure dose.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The minimal LOAEL is divided by a total uncertainty factor of 30:

- 10 for human variability
- 3 for use of a minimal LOAEL; the finding was considered a minimal LOAEL based on transient nature of effect (hematological levels returned to baseline for all individuals 4–9 days after cessation of cobalt administration) as well as mild nature of the effect (average erythrocyte levels were just above the clinically normal range of 4.7–6.1 million cells/mm^3^ for adult male men)

Subsequently, the MRL for acute-duration exposure to cobalt via oral exposure is:

M R L = (L O A E L)/(U F s) = (1 m g C o / k g / d a y)/(10 × 3) M R L = 0.03 m g C o / k g / d a y

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that the hematological system is a presumed target of cobalt toxicity in humans following oral exposure based on a moderate level of evidence in humans and a high level of evidence laboratory animals (Appendix C).

Available animal studies corroborate the effects seen in the limited human database. Increased erythrocytes, hematocrit, and/or hemoglobin were observed in rats following acute-duration exposure (Domingo and Llobet 1984; Paternain and Domingo 1988; Shrivastava et al. 2008, 2010) and intermediate-duration oral exposure (Corrier et al. 1985; Danzeisen et al. 2020a; Domingo et al. 1984; Holly 1955; Murdock 1959; Stanley et al. 1947).

Based on limited available human data, the acute-duration oral MRL of 0.03 mg Co/kg/day should be protective of other side effects reported in controlled trials and/or case reports of cobalt supplementation (e.g., gastrointestinal distress, thyroid effects), reported at doses ≥0.54 mg Co/kg/day (Paley et al. 1958; Roche and Layrisse 1956).

Agency Contact (Chemical Managers): Sam Keith, MS, CHP

## Cobalt and compounds Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cobalt and compounds
CAS Numbers: | 7440-48-8
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.02 mg Co/kg/day
Critical Effect: | Elevated red blood cells
Reference: | Danzeisen et al. 2020a
Point of Departure: | BMDL_1SD_ of 1.95 mg Co/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 53
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.02 mg Co/kg/day was derived for cobalt based on elevated red blood cell counts in male rats exposed to cobalt chloride hexahydrate at concentrations ≥2.48 mg Co/kg/day for 90 days (Danzeisen et al. 2020a). The MRL is based on a BMDL_1SD_ of 1.9 mg Co/kg/day divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Endpoints identified as presumed (hematological) or suspected (thyroid) human health effects following oral exposure based on systematic review (Appendix C) were considered as candidate critical effects for the intermediate-duration inhalation MRL. The NOAELs and LOAELs identified for these endpoints in humans and animals are presented in Table A-16. Review of the available data indicate that hematological effects are the most sensitive effects; therefore, they are selected as the critical effect for derivation of the intermediate-duration oral MRL.

Table A-16 Select NOAEL and LOAEL Values Following Intermediate-Duration Oral Exposure to Cobalt and Compounds

Species | Duration | NOAEL (mg Co/kg/day) | LOAEL (mg Co/kg/day) | Effect | Compound | Reference
Hematological effects
Human; 5 M, 5 F | 31 days | 0.013 | ND | | Cobalt chloride | Finley et al. 2013
Human; 5 M, 5 F | 91 days | 0.013 | ND | | Cobalt chloride | Tvermoes et al. 2014
Human; 8–16 M | 21 days | 0.03 | ND | | Cobalt (II) | Hoffmeister et al. 2018
Rat; 10 M, 10 F | 90 days | 0.74 | 2.48 | Increased red blood cell count, hemoglobin, and hematocrit in males | Cobalt chloride hexahydrate | Danzeisen et al. 2020a
Rat; 4–6 M | 8 weeks | 0.62 | 2.5 | Increased red blood cell count and hemoglobin | Cobalt chloride hexahydrate | Stanley et al. 1947
Rat; 6–30 M | 150 days; 5 days/week | ND | 10 | Increased red blood cell count, hemoglobin, and hematocrit | Cobalt chloride | Murdock 1959
Rat; 8–15 M | 30 days | 8.99 | 13.8 | Decreased hemoglobin | Cobalt chloride | Chetty et al. 1979
Rat; 20 M | 13 weeks | ND | 16.5 | Increased hematocrit and hemoglobin | Cobalt chloride | Domingo et al. 1984
Rat; 3–8 M | 4 months | ND | 18 | Increased red blood cell count and hemoglobin levels | Cobalt chloride | Holly 1955
Rat; 3 M | 98 days | ND | 20 | Increased red blood cell count, hemoglobin level, and packed cell volume | Cobalt chloride hexahydrate | Corrier et al. 1985
Rat; 10 M, 10 F | 90 days | 73.4 | 220 | Increased red blood cell count, hemoglobin, and hematocrit in males | Cobalt tetroxide | Danzeisen et al. 2020a
Thyroid effects
Human; 5 M, 5 F | 31 days | 0.013 | ND | | Cobalt chloride | Finley et al. 2013
Human; 5 M, 5 F | 91 days | 0.013 | ND | | Cobalt chloride | Tvermoes et al. 2014
Human; 20–55 F | 13 weeks | 0.57 | ND | | Cobalt chloride | Holly 1955
Rat; 10 M, 10 F | 90 days | 7.44 | ND | | Cobalt chloride hexahydrate | Danzeisen et al. 2020a
Rat; 3–8 M | 4 months | 18 | ND | | Cobalt chloride | Holly 1955
Mouse; 6 F | 45 days | ND | 45 (SLOAEL) | Degeneration and necrotic changes in thyroid epithelial cells; lymphocytic infiltration | Cobalt chloride | Shrivastava et al. 1996
Rat; 10 M, 10 F | 90 days | 734 | | | Cobalt tetroxide | Danzeisen et al. 2020a

Selected study for the intermediate-duration oral MRL derivation.

F = females; LOAEL = lowest-observed-adverse-effect level; M = males; ND = not determined; NOAEL = no-observed-adverse-effect level; SLOAEL = serious LOAEL

Selection of the Principal Study: The Danzeisen et al. (2020a) in rats was selected as the principal study because it identifies the lowest LOAEL for the critical effect (hematological effects).

Available human studies do not identify adverse hematological effects following intermediate-duration oral exposure to cobalt supplements at doses up to 0.03 mg Co/kg/day (Finley et al. 2013; Hoffmeister et al. 2018; Tvermoes et al. 2014). The principal study for the acute-duration MRL (Davis and Fields 1958) also evaluated hematological effects in two subjects following intermediate-duration exposure. As described in the acute-duration MRL worksheet, graphically-presented data were digitized using an open-source software, Curve Snap, to estimate changes in red blood cell counts. One subject was exposed to 1.0 mg Co/kg/day for a total of 15 days, showing an approximate 18% increase in red blood cell count at the end of exposure, compared to pre-exposure levels. The second subject was exposed to 0.8 mg Co/kg/day for 15 days, at which point, no alterations in red blood cell counts were observed compared to pre-exposure values. The dose for the subject was increased to 1 mg Co/kg/day for an additional 7 days, at which point, red blood cell levels were increased by approximately 5%. These data suggest that the no adverse effect level may be around 0.8 mg Co/kg/day for intermediate-duration oral studies; however, with only a single subject per dose group, this study is of insufficient study design to make that determination. However, the comparability of that value (0.8 mg Co/kg/day) to the NOAEL value of 0.74 mg Co/kg/day from the rat study by Danzeisen et al. (2020a) lends support to the selection of the rat study as the principal study for derivation of the intermediate-duration oral MRL.

Summary of the Principal Study:

Danzeisen R, Williams DL, Viegas V, . 2020a. Bioelution, bioavailability, and toxicity of cobalt compounds correlate. Toxicol Sci 174(2): 311–325. 10.1093/toxsci/kfz249.32058562

In an OECD 408 guideline repeat-dose toxicity study, groups of male and female Crl:CD(SD) rats (10/sex/group) were exposed to 0, 3, 10, or 30 mg cobalt chloride hexahydrate/kg/day (0, 0.74, 2.48, and 7.44 mg Co/kg/day, as per the study authors) for 90 days via gavage in 0.5% hydroxypropyl methylcellulose. Animals were sacrificed immediately after exposure. Additional animals (5/sex/group) served as the recovery group; were similarly exposed to 0 or 30 mg cobalt chloride hexahydrate/kg/day, and were sacrificed 28 days after the end of exposure. Parameters monitored included clinical observations, body weight, food and water consumption, neurological and observational screening, functional tests, hematology and clinical biochemistry, ophthalmology, and reproductive endpoints (serum hormone levels, estrous cyclicity). At sacrifice, gross necropsy was conducted and selected organs were weighed and examined for a complete histopathological examination conducted as per OECD 408 guidelines.

All rats survived. No exposure-related clinical signs or alterations in neurobehavioral screening or functional testing were observed. No changes in food or water consumption were seen. Body weight effects were noted throughout exposure at the highest dose ranging from 5 to 14% decrease from day 8 onward; at necropsy, final body weights were reduced by 11% in males and 9% in females. Body weights remained reduced by 17% in males and 14% in females at the end of the recovery period, compared to controls. Adverse hematological effects were noted in male rats at ≥2.48 mg Co/kg/day and female rats at 7.44 mg Co/kg/day. In males, findings at 2.48 and 7.44 mg Co/kg/day included elevations in red blood cell counts (9.2 and 18.9%, respectively), hemoglobin levels (10.7 and 25.6%, respectively), and hematocrit (10.3 and 24.2%, respectively). In females, red blood cell counts, hemoglobin levels, and hematocrit were elevated by 9.8, 13.4, and 13.7%, respectively, at 7.44 mg Co/kg/day. Red blood cell parameters were comparable to control in both sexes at the end of the 28-day recovery period. No changes in urinalysis or ophthalmology were observed. No changes in hormone levels or estrous cyclicity were observed. At sacrifice, no gross pathological changes were noted and no exposure-related changes in organ weight were observed. The only organs specifically mentioned as having “no effect” were testes and prostate. Dose-depended increases in erythroid hyperplasia were observed in the bone marrow at 2.48 mg Co/kg/day (4/10 males, 7/10 females) and 7.44 mg Co/kg/day (7/10 males, 7/10 females), compared to control and 0.74 mg Co/kg/day (0/10 incidence for both sexes). This lesion was not observed at the end of the recovery period. The study authors specifically noted that there were no macroscopic or histopathological findings in the heart or thyroid at any dose. No other measured endpoints were explicitly discussed. In the methods section, the study authors stated: “Due to the wealth of parameters measured in these studies, only those endpoints that were affected by the treatment are reported." Based on this statement, it is assumed that all parameters set forth in the OECD 408 guidelines that are not discussed in the results section represented no adverse effect levels.

The study authors determined a systemic NOAEL of 0.74 mg Co/kg/day and LOAEL of 2.48 mg Co/kg/day based on hematological effects. The study authors determined a reproductive NOAEL of >7.44 mg Co/kg/day based on the complete absence of findings on any reproductive parameter.

Selection of the Point of Departure for the MRL: The BMDL_1SD_ of 1.95 mg Co/kg/day for elevated red blood cell counts in male rats was selected as the POD for the intermediate-duration oral MRL.

In order to identify the POD, BMD modeling was attempted for red blood cell parameters in male rats reported by Danzeisen et al. (2020a), with standard deviation data obtained via personal communication with the study author (Viegas 2023). The red blood cell parameters modeled are shown in Table A-17. Data were fit to all available continuous models in EPA’s BMDS (version 3.3.2) using a BMR of 1 standard deviation. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMDL that is not 10 times lower than the lowest nonzero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Based on these criteria, none of the models tested adequately fit the data for hemoglobin levels. Model outputs for red blood cell data are shown in Table A-18. Model fit for elevated red blood cells in male rats is shown in Figure A-1 (Linear model).

Table A-17 Red Blood Cell Parameters in Male Rats Exposed to Cobalt Chloride Hexahydrate for 90 Days via Gavage

| Concentration in mg/kg/day (mg Co/kg/day)
| 0 | 3 (0.74) | 10 (2.48) | 30 (7.44)
Red blood cells (×10e6/μL) | 9.455±0.461^a^ (10) | 9.325±0.580 (10) | 10.325±0.756^b^ (10) | 11.245±0.746^c^ (10)
Hemoglobin (mmol/L) | 10.35±0.34 (10) | 10.50±0.46 (10) | 11.46±0.89^b^ (10) | 13.00±0.61^c^ (10)

a Mean±SD (number of animals).

b p<0.01.

c <0.001.

Sources: Danzeisen et al. 2020a; Viegas 2023

Table A-18 Model Predictions (Constant Variance) for Red Blood Cell Count in Male Rats Exposed to Cobalt Chloride Hexahydrate for 90 Days Via Gavage (Danzeisen et al. 2020a; Viegas 2023)

Model | BMD_1SD_^a^ (mg Co/kg/day) | BMDL_1SD_^a^ (mg Co/kg/day) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg Co/kg/day) | BMDL_1SD_^a^ (mg Co/kg/day) | Test 4 p-value^b^ | AIC
Model | BMD_1SD_^a^ (mg Co/kg/day) | BMDL_1SD_^a^ (mg Co/kg/day) | Test 4 p-value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential 3^d^ | 2.71 | 2.13 | 0.11 | 84.92 | 1.51 | −0.33
Exponential 5^d^ | | | NA | 84.75 | −0.33 | 2.56×10^−8^
Hill^d^ | 2.38 | 1.24 | 0.64 | 82.75 | −0.33 | 1.85×10^−7^
Polynomial Degree 2^d^ | 2.52 | 1.95 | 0.13 | 84.57 | 1.39 | −0.32
Polynomial Degree 3^d^ | 2.52 | 1.95 | 0.13 | 84.57 | 1.39 | −0.34
Power^d^ | 2.52 | 1.95 | 0.13 | 84.57 | 1.39 | −0.33
Linear ^e^ | 2.52 | 1.95 | 0.13 | 84.57 | 1.39 | −0.33

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Selected model. All models except Exponential 5 provided adequate fit to the data. BMDLs were sufficiently close (differed by <3-fold). While the model with the lowest AIC is the Hill model, this model is overparameritized for the dataset (n=4 dose groups); therefore, the model with the next lowest AIC was selected (Linear; the polynomial 2-degree and power models converged on the linear model).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control); NA = not applicable, goodness-of-fit test could not be performed

Figure A-1 Fit of Linear Model to Red Blood Cell Count in Male Rats Following Oral Exposure to Cobalt Chloride Hexahydrate for 90 Days (Danzeisen et al. 2020a; Viegas 2023)

Adjustment for Intermittent Exposure: Not applicable.

Human Equivalent Concentration: While PBPK models are available for cobalt oral dosimetry (ICRP 1995; Legget 2008; Unice et al. 2014a), these models are inadequate for interspecies extrapolation because they are specific to humans.

Uncertainty Factor: The BMDL_1SD_ is divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

Subsequently, the MRL for intermediate-duration exposure to cobalt via oral exposure is:

M R L = (B M D L_1 S D_)/(U F s) = (1.95 m g / k g / d a y)/(10 × 10) M R L = 0.0195 m g C o / k g / d a y ( Rounded to 0.02 m g C o / k g / d a y )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that the hematological system is a presumed target of cobalt toxicity in humans following oral exposure based on a moderate level of evidence in humans and a high level of evidence laboratory animals (Appendix C).

Polycythemia has been reported in healthy human volunteers orally exposed to cobalt chloride at a dose of 1 mg Co/kg/day for 7–15 days (Davis and Fields 1958). However, no changes in hematological parameters were observed in humans exposed to low-dose cobalt supplements at mean doses of 0.03 mg Co/kg/day for 7–21 days (Hoffmeister et al. 2018) or 0.013 mg Co/kg/day for up to 91 days (Finley et al. 2013; Tvermoes et al. 2014). These findings in humans are consistent with the oral intermediate-duration MRL of 0.02 mg Co/kg/day based on hematological findings in rats in the 90-day study by Danzeisen et al. (2020a).

Available animal studies corroborated the effects seen in the limited human database. Increased erythrocytes, hematocrit, and/or hemoglobin were observed in rats following acute-duration exposure (Domingo and Llobet 1984; Paternain and Domingo 1988; Shrivastava et al. 2008, 2010) and intermediate-duration oral exposure (Corrier et al. 1985; Danzeisen et al. 2020a; Domingo et al. 1984; Holly 1955; Murdock 1959; Stanley et al. 1947).

Based on limited available human data, the intermediate-duration oral MRL of 0.02 mg Co/kg/day should be protective of gastrointestinal intolerance reported in some patients following intermediate-duration oral exposure to cobalt supplements at doses at or above doses 0.36 mg Co/kg/day (Duckham and Lee 1976; Holly 1955).

Agency Contact (Chemical Managers): Sam Keith, MS, CHP

## Cobalt and compounds Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Cobalt and compounds
CAS Numbers: | 7440-48-8
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL as no studies were identified that examined chronic-duration oral exposure to cobalt in either humans or animals.

Rationale for Not Deriving an MRL: No adequately conducted chronic-duration oral studies in humans or laboratory animals were identified that adhered to ATSDR guidelines and investigated health effects resulting from chronic-duration oral exposure to cobalt or its compounds.

Agency Contact (Chemical Manager): Sam Keith, MS, CHP