# 9 REFERENCES

*Not cited in text

Abd El-Aziz MI, Sahlab AM, Abd El-Khalik M. 1994. Influence of diazinon and deltamethrine on reproductive organs and fertility of male rats. Dtsch Tierarztl Wochenschr 101:230–232.8062636
Abdelsalam EB, Ford EJ. 1986. Effect of pretreatment with hepatic microsomal enzyme inducers on the toxicity of diazinon in calves. Res Vet Sci 41(3):336–339.3809724
*Abu-Qare AW, Abou-Donia MB. 2001. Inhibition and recovery of maternal and fetal cholinesterase enzyme activity following a single cutaneous dose of methyl parathion and diazinon, alone and in combination, in pregnant rats. J Appl Toxicol 21(4):307–316.11481665
ACGIH. 2007. Diazinon. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 23.
Adhya TK, Sudhakar-Barik, Sethunathan N. 1981. Hydrolysis of selected organophosphorus insecticides by two bacteria isolated from flooded soil. J Appl Bacteriol 50:167–172.7228819
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adlakha A, Philip PJ, Dhar KL. 1988. Organophosphorus and carbamate poisoning in Punjab. J Assoc Physicians India 36(3):210–212.3182665
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
*Agency for Toxic Substances and Disease Registry. 1996. Toxicological profile for diazinon. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/toxprofles/tp86.pdf. June 12, 2006.
Akturk O, Demirin H, Sutcu R, 2006. The effects of diazinon on lipid peroxidation and antioxidant enzymes in rat heart and ameliorating role of vitamin E and vitamin C. Cell Biol Toxicol 22(6):455–461.16964585
Alavanja MC R, Dosemeci M, Samanic C, 2004. Pesticides and lung cancer risk in the agricultural health study cohort. Am J Epidemiol 160(9):876–885.15496540
Alluwaimi AM, Hussein Y. 2007. Diazinon immunotoxicity in mice: Modulation of cytokines level and their gene expression. Toxicology 236(1–2):123–131.17499902
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Amato JR, Mount DI, Durhan EJ, 1992. An example of the identification of diazinon as a primary toxicant in an effluent. Environ Toxicol Chem 11:209–216.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ II I, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anthony J, Banister E, Oloffs PC. 1986. Effect of sublethal levels of diazinon: Histopathology of liver. Bull Environ Contam Toxicol 37(4):501–507.3768544
AOAC. 1990a. Method 968.24: Organophosphorus pesticide residues. Sweep codistillation method. In: Helrich K, ed. Official methods of analysis of the Association of Official Analytical Chemists. Arlington, VA: Association of Official Analytical Chemists, Inc., 287–289.
AOAC. 1990b. Method 970.52: Organochlorine and organophosphorus pesticide residues. In: Helrich K, ed. Official methods of analysis of the Association of Official Analytical Chemists. Arlington, VA: Association of Official Analytical Chemists, Inc., 274–281.
AOAC. 1990c. Method 970.53: Organophosphorus pesticide residues. Single sweep oscillographic polarographic confirmatory method. In: Helrich K, ed. Official methods of analysis of the Association of Official Analytical Chemists, 289–290.
Arienzo M, Crisanto T, Sánchez-Martín MJ, 1994. Effect of soil characteristics on adsorption and mobility of [^14^C] diazinon. J Agric Food Chem 42(8):1803–1808.
Arienzo M, Sanchez-Camazano M, Crisanto HT, 1993. Effect of organic cosolvents on adsorption of organophosphorus pesticides by soils. Chemosphere 27(8):1409–1417.
Balani SG, Fernandes SO, Lakhani RH, 1968. Diazinon poisoning. A report on 100 cases with particular reference to evaluation of treatment. J Assoc Physicians India 16(11):911–917.5713497
Banks KE, Hunter DH, Wachal DJ. 2005. Diazinon in surface waters before and after a federally-mandated ban. Sci Total Environ 350(1–3):86–93.16227075
Bardin PG, Van Eeden SF. 1990. Organophosphate poisoning: Grading the severity and comparing treatment between atropine and glycopyrrolate. Crit Care Med 18(9):956–960.2394119
Barik S, Munnecke DM. 1982. Enzymatic hydrolysis of concentrated diazinon in soil. Bull Environ Contam Toxicol 29(2):235–239.6289949
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. U.S. Environmental Protection Agency. Regul Toxicol Pharmacol 8:471–486.3222488
Barnes TB. 1988. 90-Day oral toxicity study in dogs. EPA guidelines no. 82–1. Laboratory study number 882012. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID40815004.
Barnett JB, Spyker-Cranmer JM, Avery DL, 1980. Immunocompetence over the lifespan of mice exposed in utero to carbofuran or diazinon: I. Changes in serum immunoglobulin concentrations. J Environ Pathol Toxicol 4:53–63.7217860
Bason CW, Colborn T. 1992. U.S. application and distribution of pesticides and industrial chemicals capable of disrupting endocrine and immune systems. In: Colburn T, Clement C eds. Chemically-induced alterations in sexual and functional development: The wildlife/human connection. Advances in modern environmental toxicology, Vol. XXI. Princeton, NJ: Princeton Scientific Publishing Co., Inc., 335–345.
Baum JJ, Datta S, Young TM. 2001. Trace organic contaminants in San Pablo Bay sediments and their bioavailability. Am Chem Soc Abstr Pap 41(2):162–166.
Beane Freeman LE, Bonner MR, Blair A, 2005. Cancer incidence among male pesticide applicators in the agricultural health study cohort exposed to diazinon. Am J Epidemiol 162(11):1070–1079.16236997
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bianchi-Santamaria A, Gobbi M, Cembran M, 1997. Human lymphocyte micronucleus genotoxicity test with mixtures of phytochemicals in environmental concentrations. Mutat Res 388(1):27–32.9025789
Bicchi C, D'Amato A, Balbo C. 1997. Multiresidue method for quantitative gas chromatographic determination of pesticide residues in sweet cherries. J AOAC Int 80(6):1281–1286.
Bichile LS, Kuloor PL, Hegde AV, 1983. Acute reversible cerebellar signs after diazinon poisoning [letter]. J Assoc Physicians India 31(11):745–746.
Bleakley P, Nichol AW, Collins AG. 1979. Diazinon and porphyria cutanea tarda. Med J Aust 1(8):314–315.449807
Bondarenko S, Gan J, Haver DL, 2004. Persistence of selected organophosphate and carbamate insecticides in waters from a coastal watershed. Environ Toxicol Chem 23(11):2649–2654.15559280
Boyd EM, Carsky E. 1969. Kwashiorkorigenic diet and diazinon toxicity. Acta Pharmacol Toxicol 27(4):284–294.
Boyd EM, Carsky E, Krijnen CJ. 1969. The effects of diets containing from 0 to 81 percent casein on the acute oral toxicity of diazinon. Clin Toxicol 2(3):295–302.
Bradman MA, Harnly ME, Draper W, 1997. Pesticide exposures to children from California's central valley: Results of a pilot study. J Expo Anal Environ Epidemiol 7(2):217–234.9185013
Braun HE, Frank R. 1980. Organochlorine and organophosphorus insecticides: Their use in eleven agricultural watersheds and their loss to stream waters in southern Ontario, Canada, 1975–1977. Sci Total Environ 15:169–192.
Brown RL, Farmer CN, Millar RG. 1987. Optimization of sweep codistillation apparatus for determination of coumaphos and other organophosphorus pesticide residues in animal fat. J Assoc Off Anal Chem 70(3):442–445.3610955
Brown RP, Delp MD, Lindstedt SL, 1997. Physiologicaly parameter values for physiologically based pharmacokinetic models. Toxicol Ind Health 13(4):407–484.9249929
Buratti FM, Volpe MT, Meneguz A, 2003. CYP-specific bioactivation of four organo-phosphorothioate pesticides by human liver microsomes. Toxicol Appl Pharmacol 186(3):143–154.12620367
Burkhard LP, Jenson JJ. 1993. Identification of ammonia, chlorine, and diazinon as toxicants in a municipal effluent. Arch Environ Chem 25:506–515.
Burkhard N, Guth JA. 1979. Photolysis of organophosphorus insecticides on soil surfaces. Pestic Sci 10:313–319.
*Byrne DH, Kitos PA. 1983. Teratogenic effects of cholinergic insecticides in chick embryos--IV. The role of tryptophan in protecting against limb deformities. Biochem Pharmacol 32(19):2881–2890.6226292
Cakir S, Sarikaya R. 2005. Genotoxicity testing of some organophosphate insecticides in the Drosophila wing spot test. Food Chem Toxicol 43(3):443–450.15680680
California Environmental Protection Agency. 2006. Summary of pesticide use report data 2004 indexed by chemical. Sacramento, CA: California Environmental Protection Agency. California Department of Pesticide Regulation. http://www.cdpr.ca.gov/docs/pur/pur04rep/chmrpt04.pdf. April 25, 2006.
Cantor KP, Blair A, Everett G, 1992. Pesticides and other agricultural risk factors for non-Hodgkin's lymphoma among men in Iowa and Minnesota. Cancer Res 52(9):2447–2455.1568215
Carey AE, Kutz FW. 1985. Trends in ambient concentrations of agrochemicals in humans and the environment of the USA. Environ Monit Assess 5:155–164.24257992
Carlton FB, Simpson WM, Haddad LM. 1998. The organophosphates and other insecticides. In: Haddad LM, Shannon MW, Winchester JF, eds. Clinical management of poisoning and drug overdose. 3rd ed. Philadelphia, PA: WB Saunders Company, 836–845.
Chapman RA, Cole CM. 1982. Observations on the influence of water and soil pH on the persistence of insecticides. J Environ Sci Health B 17(5):487–504.7175098
Chen HH, Sirianni SR, Huang CC. 1982. Sister chromatid exchanges in Chinese hamster cells treated with seventeen organophosphorus compounds in the presence of a metabolic activation system. Environ Mutagen 4:621–624.7140680
Chou C-HSJ, Williams-Johnson M. 1998. Health effects classification and its role in the derivation of minimal risk levels: Neurological effects. Toxicol Ind Health 14(3):455–471.9569449
Chow E, Richter R. 1994. Acute neurotoxicity study with D Z N^®^ diazinon MG87% in rats. Ciba Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID43132204.
Clark RF. 2002. Insecticides: Organic phosphorus compounds and carbamates. In: Goldfrank LR, Flomenbaum NE, Lewin NA, eds. Goldfrank's toxicologic emergencies. 7th ed. New York, NY: Mc-Graw-Hill Medical Publishing Division, 1346–1360.
Clayton CA, Pellizzari ED, Whitmore RW, 2003. Distributions, associations, and partial aggregate exposure of pesticides and polynuclear aromatic hydrocarbons in the Minnesota Children’s Pesticide Exposure Study (MNCPES). J Expo Anal Environ Epidemiol 13:100–111.12679790
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cohen DB. 1986. Ground water contamination by toxic substances. A California assessment. In: Garner WY, Honeycutt RC, Nigg HN, eds. Evaluation of pesticides in ground water. Washington, DC: American Chemical Society, 499–502.
Cowart RP, Bonner FL, Epps EA Jr. 1971. Rate of hydrolysis of seven organophosphate pesticides. Bull Environ Contam Toxicol 6(3):231–234.4115900
Coye MJ, Barnett PG, Midtling JE, 1987. Clinical confirmation of organophosphate poisoning by serial cholinesterase analyses. Arch Intern Med 147:438–442.3827420
Currie KL, McDonald EC, Chung LT K, 1990. Concentrations of diazinon, chlorpyrifos, and beniocarb after application in offices. Am Ind Hyg Assoc J 51(1):23–27.1689096
Dagli AJ, Moos JS, Shaikh WA. 1981. Acute pancreatitis as a complication of diazinon poisoning. A case report. J Assoc Physicians India 29(9):794–795.7345082
Dahlgren JG, Takhar HS, Ruffalo CA, 2004. Health effects of diazinon on a family. J Toxicol Clin Toxicol 42(5):579–591.15462149
Davies DB, Holub BJ. 1980a. Toxicological evaluation of dietary diazinon in the rat. Arch Environ Contam Toxicol 9(6):637–650.7469478
Davies DB, Holub BJ. 1980b. Comparative subacute toxicity of dietary diazinon in the male and female rat. Toxicol Appl Pharmacol 54(3):359–367.7394791
*Davies DB, Holub BJ. 1983. Comparative effects of organophosphorus insecticides on the activities of acetylcholinesterase, diacylglycerol kinase, and phosphatidylinositol phosphodiesterase in rat brain microsomes. Pestic Biochem Physiol 20:92–99.
Davis JE, Stevens ER, Staiff DC, 1983. Potential exposure to diazinon during yard applications. Environ Monit Assess 3:23–28.24258824
Davis JR, Brownson RC, Garcia R, 1993. Family pesticide use and childhood brain cancer. Arch Environ Contam Toxicol 24(1):87–92.8466294
De Ferrari M, Artuso M, Bonassi S, 1991. Cytogenic biomonitoring of an Italian population exposed to pesticides: Chromosome aberration and sister-chromatid exchange analysis in peripheral blood lymphocytes. Mutat Res 260:105–113.2027334
DePalma AE, Kwalick DS, Zukerberg N. 1970. Pesticide poisoning in children. JAMA 211(12):1979–1981.5467154
Di Muccio A, Pelosi P, Camoni I, 1996. Selective, solid-matrix dispersion extraction of organophosphate pesticide residues from milk. J Chromatogr A 754(1–2):497–506.8997741
Domagalski JL, Kuivila KM. 1993. Distributions of pesticides and organic contaminants between water and suspended sediment, San Francisco Bay, California. Estuaries 16(3A):416–426.
DOT. 2005. Purpose and use of hazardous materials table. List of marine pollutants. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101, Appendix B. http://a257.g.akamaitech.net/7/257/2422/09nov20051500/edocket.access.gpo.gov/cfr_2005/octqtr/pdf/49cfr172.101.pdf. January 8, 2008.
*Dressel TD, Goodale RL Jr., Arneson MA, 1979. Pancreatitis as a complication of anticholinesterase insecticide intoxication. Ann Surg 189(2):199–204.426552
*Dressel TD, Goodale RL Jr., Zweber B, 1982. The effect of atropine and duct decompression on the evolution of diazinon-induced acute canine pancreatitis. Ann Surg 195(4):424–434.6175284
Drevenkar V, Vasilic Z, Stengl B, 1993. Chlorpyrifos metabolites in serum and urine of poisoned persons. Chem Biol Interact 87:315–322.7688273
Driss MR, Hennion M-C, Bouguerra ML. 1993. Determination of carbaryl and some organophosphorus pesticides in drinking water using on-line liquid chromatographic preconcentration techniques. J Chromatogr 639:352–358.8335721
Earl FL, Melveger BE, Reinwall JE, 1971. Diazinon toxicity--comparative studies in dogs and miniature swine. Toxicol Appl Pharmacol 18:285–295.5315132
*Ecobichon DJ, Kalow W. 1963. Action of organophosphorus compound upon esterases of human liver. Can Biochem Physiol 41:1537–1546.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
Eisert R, Levsen K, Wuensch G. 1994. Element-selective detection of pesticides by gas chromatography atomic-emission detection and solid-phase microextraction. J Chromatogr 683(1):175–183.
Eitzer BD, Chevalier A. 1999. Landscape care pesticide residues in residential drinking water wells. Bull Environ Contam Toxicol 62:420–427.10094724
El Arab AE, Attar A, Ballhorn L, 1990. Behavior of diazinon in a perch species. Chemosphere 21:193–199.
Enan EE, El-Sebae AH, Enan OH, 1982. In-vivo interaction of some organophosphorus insecticides with different biochemical targets in white rats. J Environ Sci Health [B] 17(5):549–570.
Endo G, Horiguchi S, Kiyota I, 1988. Serum cholinesterase and erythrocyte acetylcholinesterase activities in workers occupationally exposed to organophosphates. In: Sumino K, Seizo I, eds. Asia-Pacific Symposium on Environmental and Occupational Toxicology: Preceedings, 4–7 October, 1987, Singapore. Kobe, Japan: International Center for Medical Research, 561–564.
EPA. 1976. Chemical and photochemical transformation of selected pesticides in aquatic systems. Athens, GA: U.S. Environmental Protection Agency. EPA600376067.
EPA. 1977. Toxicity of diazinon to brook trout and fathead minnows. Ecological Research Series. Duluth MN: U.S. Environmental Protection Agency, Environmental Research Laboratory. EPA600377060.
EPA. 1988. Pesticides in ground water data base: 1988 interim report. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs. EPA5400989036.
EPA. 1990. Cleared science reviews. EPA ID No. 100–524. Diazinon MG8 (technical): Evaluation of six acute toxicity studies. Washington, DC: U.S. Environmental Protection Agency. Tox Review 008217. http://www.epa.gov/pesticides/foia/reviews/057801.htm. May 22, 2006.
EPA. 1993d. Cleared science reviews: Diazinon: Diazinon (MG-8). Submission of a chronic dog feeding study and a chronic feeding study in rats in compliance with EPA's May 1, 1987 data call-in. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/opppmsd1/foia/reviews/057801.htm. April 07, 2006.
EPA. 1993c. Guidance for assessing chemical contaminant data for use in fish advisories: Volume 1, Fish sampling and analysis. Washington DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. EPA823R93002.
EPA. 1993a. Method 1657. The determination of organophosphorus pesticides in municipal and industrial wastewater. In: Methods for the determination of nonconventional pesticides in municipal and industrial wastewater. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA821R93010A.
EPA. 1993b. Method 614. The determination of organophosphorus pesticides in municipal and industrial wastewater. In: Methods for the determination of nonconventional pesticides in municipal and industrial wastewater. Washington DC: U.S. Environmental Protection Agency, Office of Water. EPA821R93010A.
EPA. 1994a. Standards for pesticide containers and containment. Proposed rule. U.S. Environmental Protection Agency. Fed Regist 25(29)6712–6789.
EPA. 1994b. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. Office of Research and Development. EPA6008900066F.
EPA. 1995a. Method 525.2: Determination of organic compounds in drinking water by liquid-solid extraction and capillary column gas chromatography/mass spectrometry. Methods for the determination of organic compounds in drinking water: Supplement III. U.S. Environmental Protection Agency. EPA600R95131. http://web1.er.usgs.gov/nemi/method_pdf/4804.pdf. April 25, 2006.
EPA. 1995b. Method 507: Determination of nitrogen- and phosphorus-containing pesticides in water by gas chromatography with a nitrogen-phosphorus detector. Methods for the determination of organic compounds in drinking water: Supplement III. U.S. Environmental Protection Agency. EPA600R95131. http://web1.er.usgs.gov/nemi/method_pdf/4801.pdf. April 25, 2006.
EPA. 1996. Cleared science reviews: Diazinon: EPA ID No. 057801. Diazinon: Review of a series 82–7 subchronic neurotoxicity study and a specific 28 day feeding study to verify the NOEL and LOEL and assess the time course for inhibition of plasma ChE and RBC and brain AChE. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/foia/reviews/057801.htm. May 22, 2006.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1999. Water resources assessment for diazinon. Washington, DC: U.S. Environmental Protection Agency. Office of Prevention, Pesticides and Toxic Substances. http://www.epa.gov/pesticides/op/diazinon/water.pdf. April 25, 2006.
EPA. 2000a. Memorandum. Diazinon: Toxicology chapter for the RED as revised 3/30/00 in response to the Novartis Crop Protection, Inc. Responses submitted February 9, 2000 to the RED. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/op/diazinon/toxicology.pdf. March 27, 2006.
EPA. 2000b. Method 526: Determination of selected semivolatile organic compounds in drinking water by solid phase extraction and capillary column gas chromatography/mass spectrometry (GC/MS). Methods for the determination of organic and inorganic compounds in drinking water: Volume 1. U.S. Environmental Protection Agency. EPA815R00014. http://web1.er.usgs.gov/nemi/method_summary.jsp?param_method_id=4676. April 25, 2006.
EPA. 2001. Cleared science reviews: Diazinon: EPA ID No.57801. Diazinon: Review of a single dose (MRID No.45184302, July 25, 2000) and a 28-day dosing (MRID No.45184301) studies with diazinon in human volunteers. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/opppmsd1/foia/reviews/057801.htm. April 07, 2006.
EPA. 2002. Organophosphate pesticides: Revised cumulative risk assessment. Appendices: Food: Summary of residue monitoring data on organophosphorus pesticides on foods. U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/cumulative/rra-op/. March 8, 2006.
EPA. 2004a. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822R04005. http://epa.gov/waterscience/criteria/drinking/. March 07, 2006.
EPA. 2004b. Interim reregistration eligibility decision. Diazinon. Washington, DC: U.S. Environmental Protection Agency. EPA738R04006. http://www.epa.gov/oppsrrd1/REDs/diazinon_ired.pdf. March 27, 2006.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2006a. Acute Exposure Guideline Levels (AEGLs) Washington, DC: Office of Pollution Prevention and Toxics. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/chemlist.htm. March 14, 2006.
EPA. 2006b. Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr116.4.pdf. January 8, 2008.
EPA. 2006c. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. March 07, 2006.
EPA. 2006d. National primary drinking water regulations. Monitoring requirements for unregulated contaminants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.40. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr141.40.pdf. January 8, 2008.
EPA. 2006e. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://www.epa.gov/waterscience/criteria/nrwqc-2006.pdf. January 8, 2008.
EPA. 2006f. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr117.3.pdf. January 8, 2008.
EPA. 2006g. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr302.4.pdf. January 8, 2008.
EPA. 2006h. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr372.65.pdf. January 07, 2008.
EPA. 2006i. Tolerances and exemptions from tolerances for pesticide chemicals in food. Diazinon; tolerances for residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.153. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr180.153.pdf. January 8, 2008.
EPA. 2006j. Drinking water contaminant candidate list (CCL). U.S. Environmental Protection Agency. http://epa.gov./ogwdw/ccl/index.html. August 10, 2006.
EPA. 2006k. 2006 Edition of the drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. http://www.epa.gov/waterscience/criteria/drinking/dwstandards.pdf. April 11, 2007.
*Eto M, Seifert J, Engel JL, 1980. Organophosphorus and methylcarbamate teratogens: structural requirements for inducing embryonic abnormalities in chickens and kynurenine formamidase inhibition in mouse liver. Toxicol Appl Pharmacol 54(1):20–30.6156523
Fabrizi L, Gemma S, Testai E, 1999. Identification of the cytochrome P450 isoenzymes involved in the metabolism of diazinon in the rat liver. J Biochem Mol Toxicol 13(1):53–61.9890448
FASE. 1996. Pesticide exports from U.S. ports, 1992–1994. Los Angeles, CA: Foundation for the Advancement of Science Education.
FDA. 1990. Residues in foods, 1989 (3rd annual FDA pesticide residue monitoring program report). U.S. Food and Drug Administration. J AOAC Int 73(5):127A–146A.
FDA. 1991. Residues in foods, 1990 (4th annual FDA pesticide residue monitoring program report). U.S. Food and Drug Administration. J AOAC Int 74(5):121A–140A.
FDA. 1992. Residue monitoring, 1991 (5th annual FDA pesticide residue monitoring program report). U.S. Food and Drug Administration. J AOAC Int 75(5):135A–157A.
FDA. 1994. Residue monitoring, 1993 (7th annual FDA pesticide residue monitoring program report). U.S. Food and Drug Administration. J AOAC Int 77(5):163A–185A.
FDA. 1995. Residue monitoring, 1994 (8th annual FDA pesticide residue monitoring program report). U.S. Food and Drug Administration. J AOAC Int 78(5):119A–142A.
FDA. 1996. Food and Drug Administration pesticide program. Residue monitoring 1995. U.S. Food and Drug Administration. http://www.cfsan.fda.gov/~acrobat/pes95res.pdf. April 24, 2006.
FDA. 1998. Food and Drug Administration pesticide program. Residue monitoring 1996. U.S. Food and Drug Administration. http://www.cfsan.fda.gov/~dms/pes96rep.html. April 24, 2006.
FDA. 2005a. Beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://a257.g.akamaitech.net/7/257/2422/01apr20051500/edocket.access.gpo.gov/cfr_2005/aprqtr/pdf/21cfr165.110.pdf. January 8, 2008.
FDA. 2005b. Food and Drug Administration pesticide program. Residue monitoring 2003. U.S. Food and Drug Administration. http://www.cfsan.fda.gov/~dms/pes03rep.html. April 24, 2006.
FEDRIP. 2006. Diazinon. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Felost AS, Racke KD, Hamilton DJ. 2003. Disposal and degradation of pesticide waste. Rev Environ Contam Toxicol 177:123–200.12666819
Ferrando MD, Alarcon V, Fernandez-Casalderrey A, 1992. Persistence of some pesticides in the aquatic environment. Bull Environ Contam Toxicol 48:747–755.1380353
Flaskos J, Harris W, Sachana M, 2007. The effects of diazinon and cypermethrin on the differentiation of neuronal and glial cell lines. Toxicol Appl Pharmacol 219(2–3):172–180.17239417
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Forbat IN, Skehan JD. 1992. Health effects of organophosphate sheep dip [Comment on Br Med J 305(6861):1090]. Br Med J 305(6867):1503.
Frank R, Logan L. 1988. Pesticide and industrial chemical residues at the mouth of the Grand, Saugeen and Thames Rivers, Ontario, Canada, 1981–85. Arch Environ Contam Toxicol 17:741–754.
Frank R, Braun HE, Chapman N, 1991b. Degradation of parent compounds of nine organophosphorus insecticides in Ontario surface and ground waters under controlled conditions. Bull Environ Contam Toxicol 47:374–380.1768951
Frank R, Braun HE, Clegg BS, 1990b. Survey of farm wells for pesticides, Ontario, Canada, 1986 and 1987. Bull Environ Contam Toxicol 44:410–419.2328348
Frank R, Braun HE, Ripley BD, 1990a. Contamination of rural ponds with pesticide, 1971–85, Ontario, Canada. Bull Environ Contam Toxicol 44:401–409.2328347
Frank R, Clegg BS, Ripley BD, 1987. Investigations of pesticide contaminations in rural wells, 1979–1984, Ontario, Canada. Arch Environ Contam Toxicol 16:9–22.
Frank R, Mineau P, Braun HE, 1991a. Deaths of Canada geese following spraying of turf with diazinon. Bull Environ ContamToxicol 46:852–858.
*Frick TW, Dalo S, OĽeary JF, 1987. Effects of insecticide, diazinon, on pancreas of dog, cat and guinea pig. J Environ Pathol Toxicol Oncol 7(4):1–11.
Frölichsthal P, Piatti E. 1996. Valutazione dei micronuclei in colture primarie di epatociti di ratto dopo trattamento con composti organofosforici. Boll Chim Farm 135(9):541–545.9081297
Gaines TB. 1960. The acute toxicity of pesticides to rats. Toxicol Appl Pharmacol 2:88–99.13825957
Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 14(3):515–534.5787520
Garcia-Lopez JA, Monteoliva M. 1988. Physiological changes in human erythrocyte cholinesterase as measured with the "pH stat". Clin Chem 34(10):2133–2135.3168232
Garcia-Repetto R, Gimenez MP, Repetto M. 2001. New method for determination of ten pesticides in human blood. J AOAC Int 84(2):342–349.11324596
Garcia-Repetto R, Martinez D, Repetto M. 1994. The influence of pH on the degradation kinetics of some organophosphorous pesticides in aqueous solutions. Vet Hum Toxicol 36(3):202–204.8066964
Garcia-Repetto R, Martinez D, Repetto M. 1996. A biodisposition study of diazinon in the Wistar rat. Toxic Subst Mech 15(4):415–423.
Garfitt SJ, Jones K, Mason HJ, 2002. Exposure to the organophosphate diazinon: Data from a human volunteer study with oral and dermal doses. Toxicol Lett 134(1–3):105–113.12191867
Garry VF. 2004. Pesticides and children. Toxicol Appl Pharmacol 198(2):152–163.15236951
Gartrell MJ, Craun JC, Podrebarac DS, 1986. Pesticides, selected elements, and other chemicals in infant and toddler total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69(1):123–145.3949685
Giknis ML A. 1989. A two generation reproductive study in albino rats. EPA guidelines no. 83–4. Laboratory study number 852218. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41158101.
Giordano G, Afsharinejad Z, Guizzetti M, 2007. Organophosphorus insecticides chlorpyrifos and diazinon and oxidative stress in neuronal cells in a genetic model of glutathione deficiency. Toxicol Appl Pharmacol 219(2–3):181–189.17084875
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Glotfelty DE, Majewski MS, Seiber JN. 1990a. Distribution of several organophosphorus insecticides and their oxygen analogues in a foggy atmosphere. Environ Sci Technol 24:353–357.
Glotfelty DE, Schomburg CJ, McChesney MM, 1990b. Studies of the distribution, drift, and volatilization of diazinon resulting from spray application to a dormant peach orchard. Chemosphere 21:1303–1314.
Goodman LR, Hansen DJ, Coppage DL, 1979. Diazinon: Chronic toxicity to, and brain acetylcholinesterase inhibition in, the sheepshead minnow, Cyprinodon variegatus. Trans Am Fish Soc 108(5):479–488.
Gordon SY, Callahan PJ, Nishioka MG, 1999. Residential environmental measurements in the national human exposure assessment survey (NHEXAS) pilot study in Arizona: Preliminary results for pesticides and VOCs. J Expo Anal Environ Epidemiol 9(5):456–470.10554148
Gore RC, Hannah RW, Pattacini SC, 1971. Infrared and ultraviolet spectra of seventy-six pesticides. J Assoc Off Anal Chem 54:1040–1082.5151664
Green VA. 1970. Effects of pesticides on rat and chick embryo. Trace Subst Environ Health 3:183–209.
Gruber SJ, Munn MD. 1998. Organophosphate and carbamate insecticides in agricultural waters and cholinesterase (CHE) inhibition in common carp (Cyprinus carpio). Arch Environ Contam Toxicol 35:391–396.9732468
Guizzetti M, Pathak S, Giordano G, 2005. Effect of organophosphorus insecticides and their metabolites on astroglial cell proliferation. Toxicology 215:182–190.16102884
*Gunderson EL. 1988. FDA total diet study, April 1982-April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71(6):1200–1209.3240978
Gunderson EL. 1995a. Dietary intake of pesticides, selected elements, and other chemicals: FDA Total Diet Study, June 1984 - April 1986. J AOAC Int 78:910–21.7580329
Gunderson EL. 1995b. FDA Total Diet Study, July 1986-April 1991, Dietary intakes of pesticides, selected elements, and other chemicals. J AOAC Inter 78:1353–63.
Gunner HB, Zuckerman BM. 1968. Degradation of 'diazinon' by synergistic microbial action. Nature 217:1183–1184.4868370
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
*Halle A, Sloas DD. 1987. Percutaneous organophosphate poisoning. South Med J 80(9):1179–1181.3629322
Handy RD, Abd-El Samei HA, Bayomy MF F, 2002. Chronic diazinon exposure: Pathologies of spleen, thymus, blood cells, and lymph nodes are modulated by dietary protein or lipid in the mouse. Toxicology 172:13–34.11844612
Hankemeier TH, Louter AJ H, Rinkema FD, 1995. On-line coupling of solid-phase extraction and gas chromatography with atomic emission detection for analysis of trace pollutants in aqueous samples. Chromatographia 40(3–4):119–124.
Harris LW, Fleisher JH, Innerebner TA 1969. The effects of atropine-oxime therapy on cholinesterase activity and the survival of animals poisoned with diethyl-O-(2-isopropyl- 6-methyl-4-pyrimidinyl) phosphorothioate. Toxicol Appl Pharmacol 15:216–224.5798726
Harris SB, Holson JF. 1981. A teratology study of diazinon (CAS Number 333–41-5) in New Zealand white rabbits. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID00079017.
Hartman HR. 1990. 21-Day repeated exposure inhalation toxicity in the rat. EPA guidelines no. 82–4. Laboratory study number 891205. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41557402.
*Hassan RM, Pesce AJ, Sheng P, 1981. Correlation of serum pseudocholinesterase and clinical course in two patients poisoned with organophosphate insecticides. Clin Toxicol 18(4):401–406.7237968
Hata S, Bernstein E, Davis LE. 1986. Atypical ocular bobbing in acute organophosphate poisoning. Arch Neurol 43(2):185–186.3947262
*Hatjian BA, Mutch E, Williams FM, 2000. Cytogenetic response without changes in peripheral cholinesterase enzymes following exposure to a sheep dip containing diazinon in vivo and in vitro. Mutat Res 472(1–2):85–92.11113701
Hayes AL, Wise RA, Weir FW. 1980. Assessment of occupational exposure to organophosphates in pest control operators. Am Ind Hyg Assoc J 41(8):568–575.7405825
Hayes WJ Jr. 1982. Pesticides studied in man. Baltimore, MD Williams & Wilkins, 385–389.
HazDat. 2008. Diazinon. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. June 5, 2008.
*Henderson M, Kitos PA. 1982. Do organophosphate insecticides inhibit the conversion of tryptophan to NAD+ in ovo? Teratology 26(2):173–181.6186043
Hillmann R, Bächmann K. 1995. Extraction of pesticides using supercritical trifluoromethane and carbon dioxide. J Chromatogr A 695(1):149–154.
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Holbert MS. 1989. Acute inhalation toxicity study in rats. EPA guidelines no. 81–3. Laboratory study number 5947–89. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41407220.
Holstege DM, Scharberg DL, Richardson ER, 1991. Multiresidue screen for organophosphorus insecticides using gel permeation chromatography--silica gel cleanup. J Assoc Off Anal Chem 74(2):394–399.1646783
Hong J, Eo Y, Rhee J, 1993. Simultaneous analysis of 25 pesticides in crops using gas chromatography and their identification by gas chromatography-mass spectrometry. J Chromatogr 639:261–271.8335720
Hopper ML. 1988. Improved method for partition of organophosphate pesticide residues on a solid phase partition column. J Asso Off Anal Chem 71(4):731–734.
Howard PH, ed. 1991. Diazinon. In: Handbook of environmental fate and exposure data for organic chemicals. Pesticides. Vol III. Chelsea, MI: Lewis Publishers, Inc., 209–221.
HSDB. 2008. Diazinon. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. June 3, 2008.
Hsu JP, Schattenberg HJ II I, Garza MM. 1991. Fast turnaround multiresidue screen for pesticides in produce. J Assoc Off Anal Chem 74(5):886–892.1783596
Hsu JP, Wheeler HG Jr, Camann DE, 1988. Analytical methods for detection of nonoccupational exposure to pesticides. J Chromatogr Sci 26:181–189.3379124
Hundley HK, Cairns T, Luke MA, 1988. Pesticide residue findings by the Luke method in domestic and imported foods and animal feeds for fiscal years 1982–1986. J Assoc Off Anal Chem 71(5):875–892.3235407
*Husain K, Mirza MA, Matin MA. 1987. Convulsions as the etiology of lactic acidosis in acute diazinon toxicity in rats. Toxicol Lett 37(3):257–261.3617100
IARC. 2007. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1–98. (Alphabetical order). International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/Listagentsalphorder.pdf. January 5, 2008.
Ibanez M, Sancho JV, Pozo OJ, 2006. Use of liquid chromatography quadrupole time-of-flight mass spectrometry in the elucidation of transformation products and metabolites of pesticides. Diazinon as a case study. Anal Bioanal Chem 384(2):448–457.16320041
Infurna RM, Arthur AT. 1985. A teratology study of diazinon technical in Charles River rats. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID00153017.
IRIS. 2008. Diazinon. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/. January 11, 2008.
*IRPTC. 1985. Treatment and disposal methods for waste chemicals. Geneva, Switzerland: International Register of Potentially Toxic Chemicals. United Nations Environment Programme, 251–252.
Iverson F, Grant DL, Lacroix J. 1975. Diazinon metabolism in the dog. Bull Environ Contam Toxicol 13(5):611–618.1148418
Iyaniwura TT. 1991. Relative inhibition of rat plasma and erythrocyte cholinesterases by pesticide combinations. Vet Hum Toxicol 33:166–168.2035247
Jackson MD, Lewis RG. 1981. Insecticide concentrations in air after application of pest control strips. Bull Environ Contam Toxicol 27:122–125.6170370
Jaksa RJ, Palahniuk RJ. 1995. Attempted organophosphate suicide: A unique cause of prolonged paralysis during electroconvulsive therapy. Anesth Analg 80(4):832–833.7893043
Jameson RR, Seidler FJ, Slotkin TA. 2007. Nonenzymatic functions of acetylcholinesterase splice variants in the developmental neurotoxicity of organophosphates: chlorpyrifos, chlorpyrifos oxon, and diazinon. Environ Health Perspect 115(1):65–70.17366821
Janes NF, Machin AF, Quick MP, 1973. Toxic metabolites of diazinon in sheep. J Agric Food Chem 21:121–124.4682326
Jenkins LJ. 1988. Acute delayed neurotoxicity of diazinon MG-8 in domestic fowl. Project No. 5152–87. Stillmeadow, Inc. Submitted to the U.S. Environmental Protection Agency. MRID40660806.
Jeyaratnam J, Maroni M. 1994. Organophosphorus compounds. Toxicology 91(1):15–27.8052981
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johnson WE, Fendinger NJ, Plimmer JR. 1991. Solid-phase extraction of pesticides from water: Possible interferences from dissolved organic material. Anal Chem 63:1510–1513.1952081
Kabrawala VN, Shah RM, Oza GG. 1965. Diazinon poisoning. (A study of 25 cases). Indian Pract 18(10):711–717.5847442
Kadenczki L, Arpad Z, Gardi I, 1992. Column extraction of residues of several pesticides from fruits and vegetables: A simple multiresidue analysis method. J AOAC Int 75(1):53–61.
Kalender S, Ogutcu A, Uzunhisarcikli M, 2005. Diazinon-induced hepatotoxicity and protective effect of vitamin E on some biochemical indices and ultrastructural changes. Toxicology 211(3):197–206.15925023
Kalender Y, Uzunhisarcikli M, Ogutcu A, 2006. Effects of diazinon on pseudocholinesterase activity and haematological indices in rats: The protective role of vitamin E. Environ Toxicol Pharmacol 22(1):46–51.21783685
Kamha AA, Al Omary IY M, Zalabany HA, 2005. Organophosphate poisoning in pregnancy: A case report. Basic Clin Pharmacol Toxicol 96(5):397–398.15853933
KAN-DO. 1995. Office of pesticide team. Accumulated pesticide and industrial chemical findings from a ten-year study of ready to eat foods. J AOAC Int 78(3):614–630.7756874
Kappers WA, Edwards RJ, Murray S, 2001. Diazinon is activated by CYP2C19 in human liver. Toxicol Appl Pharmacol 177:68–76.11708902
Keizer, D'Agotino G, Vittozzi L. 1991. The importance of biotransformation in the toxicity of xenobiotics to fish. Part I. Toxicity and bioaccumulation of diazinon in guppy (Poecilia reticulate) and zebra fish (Brachydanio rerio). Aquat Toxicol 21:239–254.
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–38.7379718
Kendall RJ, Brewer LW, Hitchcock RR. 1993. Response of Canada geese to a turf application of diazinon AG500. J Wildl Dis 29(3):458–464.8355349
*Kimbrough RD, Gaines TB. 1968. Effect of organic phosphorus compounds and alkylating agents on the rat fetus. Arch Environ Health 16:805–808.5654550
Kiraly J, Szentesi I, Ruzicska M, 1979. Chromosome studies in workers producing organophosphate insecticides. Arch Environ Contam Toxicol 8:309–319.507940
Kirchner FR, McCormick GC, Arthur AT. 1991. One/two year oral toxicity study in rats. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41942002.
Kirkbride KP. 1987. An estimation of diazinon in omental tissue. J Anal Toxicol 11:6–7.3821078
Klaassen CD, Amdur MO, Doull J, eds. 1986. Diazinon. In: Casarett and Doull's toxicology. 3rd ed. New York, NY: MacMillan Publishing Co., 523, 529, 572, 837, 891.
Klemmer HW, Reichert ER, Yauger WL, 1978. Five cases of intentional ingestion of 25 percent diazinon with treatment and recovery. Clin Toxicol 12(4):435–444.657758
Kojima M, Fukunaga K, Sasaki M, 2005. Evaluation of estrogenic activities of pesticides using an in vitro reporter gene assay. Int J Environ Health Res 15(4):271–280.16175743
*Kojima T, Tsuda S, Shirasu Y. 1992. Non-cholinergic mechanisms underlying the acute lethal effects of P=S type organophosphorus insecticides in rats. J Vet Med Sci 54(3):529–533.1386532
Kolpin DW, Barbash JE, Gilliom RJ. 2000. Pesticides in ground water of the United States, 1992–1996. Ground Water 38(6):858–863.
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ II I, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kubo T, Urano K, Utsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554.
Kudzin ZH, Kotynski A, Kielbasinski P. 1991. Application of the iodine-azide reagent for selective detection of thiophosphoryl compounds in thin-layer chromatography. J Chromatogr 588:307–313.
*Kuhn JO. 1989a. Acute oral toxicity study in rats. EPA guidelines no. 81–1. Laboratory study number 5942–89. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41407218.
Kuhn JO. 1989b. Dermal sensitization study in guinea pigs. EPA guidelines no. 81–6. Laboratory study number 5946–89. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41407223.
*Kuhn JO. 1989c. Primary eye irritation study in rabbits. EPA guidelines no. 81–4. Laboratory study number 5944–89. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41407221.
*Kurt TL. 1988. Persistent symptoms of cholinesterase inhibiting pesticide toxicity (diazinon) [letter]. Vet Hum Toxicol 30(3):268.3388758
Kutz FW, Yobs AR, Yang HS C. 1976. National pesticide monitoring networks. In: Lee RE, ed. Air pollution from pesticides and agricultural processes. Cleveland, OH: CRC Press, 95–136.
Kwakman PJ M, Vreuls JJ, Brinkman UA T, 1992. Determination of organophosphorus pesticides in aqueous samples by on-line membrane disk extraction and capillary gas chromatography. Chromatographia 34:41–47.
Lambropoulou DA, Albanis TA. 2003. Headspace solid-phase microextraction in combination with gas chromatography–mass spectrometry for the rapid screening of organophosphorus insecticide residues in strawberries and cherries. J Chromatogr A 993(1–2):197–203.12735453
Larkin DJ, Tjeerdema RD. 2000. Fate and effects of diazinon. Rev Environ Contam Toxicol 166:49–82.10868076
Lawrence JF, Iverson F. 1975. Analysis of the diazinon metabolites G 27550 and GS 31144 by gas liquid chromatography with nitrogen-specific detection after derivatization. J Chromatogr 103:341–347.1117046
Lee HS. 1989. Acute pancreatitis and organophosphate poisoning--a case report and review. Singapore Med J 30(6):599–601.2635407
Lee SM, Papathakis ML, Feng H-MC, 1991. Multipesticide residue method for fruits and vegetables: California Department of Food and Agriculture. Fresenius J Anal Chem 339:376–383.
Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lenhart SW, Kawamoto MM. 1994. Residual air concentrations of pesticides in a commercial greenhouse. Appl Occup Environ Hyg 9(1):9–15.
Leoni V, Caricchia AM, Chiavarini S. 1992. Multiresidue method for quantitation of organophosphorus pesticides in vegetable and animal foods. J AOAC Int 75(3):511–518.
Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Levanon D, Meisinger JJ, Codling EE, 1994. Impact of tillage on microbial activity and the fate of pesticides in the upper soil. Water Air Soil Pollut 72(1–4):179–189.
Lewis RG, Fortune CR, Blanchard FT, 2001. Movement and deposition of two organophosphorus pesticides within a residence after interior and exterior applications. J Air Waste Manage Assoc 51:339–351.
Lewis RG, Lee RE Jr. 1976. Air pollution from pesticides: Sources, occurrence, and dispersion. In: Lee RE Jr., ed. Air pollution from pesticides and agricultural processes. Cleveland, OH: CRC Press, 5–50.
Li PC H, Swanson EJ, Gobas FAPC. 2002. Diazinon and its degradation products in agricultural water courses in British Columbia, Canada. Bull Environ Contam Toxicol 69(1):59–65.12053258
Liao W, Joe T, Cusick WG. 1991. Multiresidue screening method for fresh fruits and vegetables with gas chromatographic/mass spectrometric detection. J Assoc Anal Chem 74:554–565.
Lichtenstein EP, Fuhremann TW, Schulz. 1968. Effect of sterilizing agents on persistence of parathion and diazinon in soils and water. J Agric Food Chem 15:870–873.
Limaye MR. 1966. Acute organophosphorous compound poisoning: A study of 76 necropsies. J Indian Med Assoc 47(10):492–498.5979310
Lioy PJ, Edwards RD, Freeman N, 2000. House dust levels of selected insecticides and a herbicide measured by the EL and LWW samplers and comparisons to hand rinses and urine metabolites. J Expo Anal Environ Epidemiol 10:327–340.10981727
Lisi P, Caraffinis S, Assalve D. 1987. Irritation and sensitization potential of pesticides. Contact Dermatitis 17(4):212–218.2962818
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Liu Z, Sirimanne SR, Patterson DG Jr. 1994. Comprehensive two dimensional gas chromatography for the fast separation and determination of pesticides extracted from human serum. Anal Chem 66(19):3086–3092.7978304
Lopez D, Aleixandre C, Merchan M, 1986. In vitro induction of alterations in peripheral blood lymphocytes by different doses of diazinon. Bull Environ Contam Toxicol 37:517–522.3768547
Lopez-Avila V, Hirata P, Kraska S, 1985. Determination of atrazine, lindane, pentachlorophenol, and diazinon in water and soil by isotope dilution gas chromatography/mass spectrometry. Anal Chem 57:2797–2801.
Lox CD. 1983. Effects of acute pesticide poisoning on blood clotting in the rat. Ecotoxicol Environ Safety 7(5):451–454.6641583
Lox CD. 1987. The effects of short term diazinon exposure on blood clotting activity in the rat. J Environ Pathol Toxicol Oncol 7:67–71.3559918
Lox CD, Davis JR. 1983. The effects of long-term malathion or diazinon ingestion on the activity of hepatic synthesized clotting factors. Ecotoxicol Environ Safety 7(6):546–551.6662056
Lu C, Rodriguez T, Funez A, 2006. The assessment of occupational exposure to diazinon in Nicaraguan plantation workers using saliva biomonitoring. Ann N Y Acad Sci 1076:355–365.17119215
Machin AF, Anderson PH, Hebert CN. 1974. Residue levels and cholinesterase activities in sheep poisoned experimentally with diazinon. Pestic Sci 5:49–56.
Machin AF, Quick MP, Rogers H, 1971. The conversion of diazinon to hydroxydiazinon in the guinea-pig and sheep. Bull Environ Contam Toxicol 6(1):26–27.5153742
Machin AF, Rogers H, Cross AJ, 1975. Metabolic aspects of the toxicology of diazinon. I. Hepatic metabolism in the sheep, cow, pig, guinea-pig, rat, turkey, chicken and duck. Pesticide Science 6:461–473.
Maguire RJ, Tkacz RJ. 1993. Occurrence of pesticides in the Yamaska River, Quebec. Arch Environ Contam Toxicol 25(2):220–226.
Maizlish N, Schenker M, Weisskopf C, 1987. A behavioral evaluation of pest control workers with short-term, low-level exposure to the organophosphate diazinon. Am J Ind Med 12(2):153–172.3661569
Majewski MS, Foreman WT, Goolsby DA, 1998. Airborne pesticide residues along the Mississippi River. Environ Sci Technol 32:3689–3698.
Makhteshim-Agan. 1989. Diazinon technical: Comparative toxicity study by dietary administration to CD rats for six weeks. Makhteshim-Agan (America) Incorporated. Submitted to the U.S. Environmental Protection Agency. MRID41432301.
*Maliwal BP, Guthrie FE. 1981. Interaction of insecticides with human plasma lipoproteins. Chem-Biol Interact 35(2):177–188.7214601
Mallet VN, Duguay M, Bernier M, 1990. An evaluation of high performance liquid chromatography - UV for the multi-residue analysis of organophosphorous pesticides in environmental water. Intern J Environ Anal Chem 39:271–279.
Mansour M, Feicht EA, Behechti A, 1997. Experimental approaches to studying the photostability of selected pesticides in water and soil. Chemosphere 35(1/2):39–50.
Marshall TC, Dorough HW, Swim HE. 1976. Screening of pesticides for mutagenic potential using Salmonella typhimurium mutants. J Agric Food Chem 24:560–563.818141
*Matin MA, Husain K. 1987. Changes in cerebral glycogenolysis and related enzymes in diazinon treated hyperglycaemic animals. J Appl Toxicol 7(2):131–134.3624768
*Matin MA, Husain K, Khan SN. 1990. Modification of diazinon-induced changes in carbohydrate metabolism by adrenalectomy in rats. Biochem Pharmacol 39(11):1781–1786.2344375
*Matin MA, Khan SN, Hussain K, 1989. Effect of adrenalectomy on diazinon-induced changes in carbohydrate metabolism. Arch Toxicol 63(5):376–380.2818201
Matsuoka A, Hayashi M, Ishidate M Jr. 1979. Chromosomal aberration tests on 29 chemicals combined with S9 mix in vitro. Mutat Res 66:277–290.375085
Matsushita T, Aoyama K. 1981. Cross reactions between some pesticides and the fungicide benomyl in contact allergy. Ind Health 19(2):77–83.7263305
Matsushita T, Aoyama K, Yoshimi K, 1985. Allergic contact dermatitis from organophosphorus insecticides. Ind Health 23(2):145–154.2932413
Mattern GC, Louis JB, Rosen JD. 1991. Multipesticide determination in surface water by gas chromatography/chemical ionization/mass spectrometry/ion trap detection. J Assoc Off Anal Chem 74:982–986
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McGregor DB, Brown A, Cattanach P, 1988. Responses of the L5178Y tk+/tk- mouse lymphoma cell forward mutation assay: III. 72 coded chemicals. Environ Mol Mutagen 12:85–154.3383842
Meister RT, Sine C, Sharp DT, , eds. 2006. Diazinon. Crop protection handbook 2006. Willohughby, OH: Meister Media Worldwide. D136, F118.
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
Michel FC, Reddy CA, Forney LJ. 1997. Biodegradation and bioremediation: Fate of carbon-14 diazinon during the composting of yard trimmings. J Environ Qual 26:200–205.
Mihara K, Isobe N, Ohkawa H, 1981. Effects of organophosphorus insecticides on mitochondrial and microsomal functions in the liver of rat with special emphasis on fenitrothion. J Pestic Sci 6(3):307–316.
*Misawa M, Doull J, Kitos PA, 1981. Teratogenic effects of cholinergic insecticides in chick embryos. I. Diazinon treatment on acetylcholinesterase and choline acetyltransferase activities. Toxicol Appl Pharmacol 57(1):20–29.6451954
*Misawa M, Doull J, Uyeki EM. 1982. Teratogenic effects of cholinergic insecticides in chick embryos. III. Development of cartilage and bone. J Toxicol Environ Health 10(4–5):551–563.7161815
Miyahara M, Suzuki T, Saito Y. 1992. Multiresidue method for some pesticides in lanolin by capillary gas chromatography with detection by electron capture, flame photometric, mass spectrometric, and atomic emission techniques. J Agric Food Chem 40:64–69.
Morgan MK, Stout DM, Wilson NK. 2001. Feasibility study of the potential for human exposure to pet-borne diazinon residues following lawn applications. Bull Environ Contam Toxicol 66:295–300.11178642
Morris PD, Koepsell TD, Daling JR, 1986. Toxic substance exposure and multiple myeloma. A case-control study. J Natl Cancer Inst 76(6):987–994.3458965
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Moser VC. 1995. Comparisons of the acute effects of cholinesterase inhibitors using a neurobehavioral screening battery in rats. Neurotoxicol Teratol 17(6):617–625.8747743
Moser VC, Casey M, Hamm A, 2005. Neurotoxicological and statistical analyses of a mixture of five organophosphorus pesticides using a ray design. Toxicol Sci 86(1):101–115.15800032
*Moscioni AD, Engel JL, Casida JE. 1977. Kynurenine form amidase inhibition as a possible mechanism for certain teratogenic effects of organophosphorus and methylcarbamate insecticides in chicken embryos. Biochem Pharmacol 26:2251–2258.73376
Mount ME. 1984. Diagnostic value of urinary dialkyl phosphate measurement in goats exposed to diazinon. Am J Vet Res 45(4):817–824.6731999
Mücke W, Alt KO, Esser OH. 1970. Degradation of [14C]-labeled diazinon in the rat. J Agric Food Chem 18(2):208–212.5524472
Müller F, Streibert HP, Farooq S, eds. 2005. Acaricides. In: Ullmann's encyclopedia of industrial chemistry. John Wiley & Sons, Inc. http://www.mrw.interscience.wiley.com/ueic/articles/a01_017/pdf_fs.html. April 24, 2006.
Musshoff F, Junker H, Madae B. 2002. Simple determination of 22 organophosphorus pesticides in human blood using headspace solid-phase microextraction and gas chromatography with mass spectrometric detection. J Chromatogr Sci 40(1):29–34.11866384
Mutch E, Williams FM. 2006. Diazinon, chlorpyrifos and parathion are metabolised by multiple cytochromes P450 in human liver. Toxicology 224(1–2):22–32.16757081
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
NCI. 1979. Bioassay of diazinon for possible carcinogenicity. National Cancer Institute Technical Report Series No. 137, National Institutes of Health, Public Health Service, U.S. Department of Health, Education, and Welfare, Bethesda, MD. NCI-CG-TR-137. DHEW/PUB/NIH-79–1392.
NIOSH. 1994. Method 5600: Organophosphorus Pesticides. In: NIOSH manual of analytical methods. 4th ed. National Institute of Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/5600.pdf. May 23, 2006
NIOSH. 2005. Diazinon. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. March 08, 2006.
NIOSH. 2006a. International Chemical Safety Cards (ICSCs): U.S. National version. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/ipcs/nicstart.html. March 1, 2006
NIOSH. 2006b. National occupational exposure survey 1981–1983. National Institute of Occupational Safety and Health. http://www.cdc.gov/noes/noes1/23360sic.html. May 23, 2006.
Nishihara T, Nishikawa J, Kanayama T, 2000. Estrogenic activities of 517 chemicals by yeast two-hybrid assay. J Health Sci 46(4):282–298.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Academy Press. National Research Council.
NTP. 2004. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. January 11, 2008.
Nutley BP, Berry HF, Roff M, 1995. The assessment of operator risk from sheep dipping operations using organophosphate based dips. In: Best GA, Ruthven D, eds. Pesticides: Developments, impacts, and controls. Cambridge, UK: Royal Society of Chemistry, 43–54.
Ogutcu A, Uzunhisarcikli M, Kalender S, 2006. The effects of organophosphate insecticide diazinon on malondialdehyde levels and myocardial cells in rat heart tissue and protective role of vitamin E. Pestic Biochem Physiol 86(2):93–98.
Olsson AO, Nguyen JV, Sadowski MA, 2003. A liquid chromatography electrospray ionization-tandem mass spectrometry method for quantification of specific organophosphorus pesticide biomarkers in human urine. Anal Bioanal Chem 376(6):808–815.12811448
O'Neil MJ, Smith A, Heckelman PE, eds. 2001. Diazinon. In: The Merck index. An encyclopedia of chemicals, drugs, and biologicals. 13th ed. Whitehouse Station, NJ: Merck & Co., Inc., 528.
OSHA. 1986. Method 062: Chlorpyrifos (dursban), DDVP (dichlorvos), diazinon, malathion, parathion. Occupational Safety and Health Administration. http://www.osha.gov/dts/sltc/methods/organic/org062/org062.html. April 25, 2006.
OSHA. 2005. Limits for air contaminants. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. March 08, 2006.
Osmundson M. 1998. Insecticides and pesticides. In: Viccellio P, Bania T, Brent J, , eds. Emergency toxicology. 2nd ed. Philadelphia, PA: Lippincott-Raven Publishers, 401–413.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Padilla S, Sung H-J, Moser VC. 2004. Further assessment of an in vitro screen that may help identify organophosphorus pesticides that are more acutely toxic to the young. J Toxicol Environ Health A 67:1477–1489.15371233
Palmgren MS, Lee TC. 1984. Malathion and diazinon levels in grain dust from New Orleans area grain elevators. Am Ind Hyg Assoc J 45(30):168–171.6720579
Pereira WE, Hostettler FD. 1993. Nonpoint source contamination of the Mississippi River and its tributaries by herbicides. Environ Sci Technol 27(8):1542–1552.
Poet TS, Kousba AA, Dennison SL, 2004. Physiologically based pharmacokinetic pharmacodynamic model for the organophosphorus pesticide diazinon. Neurotoxicology 25(6):1013–1030.15474619
Poet TS, Wu H, Kousba AA, 2003. In vitro rat hepatic and intestinal metabolism of the organophosphate pesticides chlorpyrifos and diazinon. Toxicol Sci 72(2):193–200.12655035
Poklis A, Kutz FW, Sperling JF, 1980. A fatal diazinon poisoning. Forensic Sci Int 15(2):135–140.7358325
Poulin P, Krishnan K. 1996. A tissue composition-based algorithm for predicting tissue: Air partition coefficients of organic chemicals. Toxicol Appl Pharmacol 136:126–130.8560465
Qiao D, Seidler FJ, Slotkin TA. 2001. Developmental neurotoxicity of chlorpyrifos modeled in vitro: Comparative effects of metabolites and other cholinesterase inhibitors on DNA synthesis on PC12 and C6 cells. Environ Health Perspect 109(9):909–913.11673119
Rajendra W, Oloffs PC, Banister EW. 1986. Effects of chronic intake of diazinon on blood and brain monoamines and amino acids. Drug Chem Toxicol 9(2):117–131.2875863
Ray DE. 1998. Chronic effects of low level exposure to anticholinesterases - a mechanistic review. Toxicol Lett 102–103:527–533.
Raymer JH, Velez GR. 1991. Development of a flexible, on-line supercritical fluid extraction-gas chromatographic (SFE-GC) system. J Chromatogr Sci 29:467–475.
Rayner MD, Popper JS, Carvalho EW, 1972. Hyporeflexia in workers chronically exposed to organophosphate insecticides. Res Commun Chemical Pathol Pharmacol 4(3):595–606.
Reichert ER, Yauger WL Jr, Rashad MN, 1977. Diazinon poisoning in eight members of related households. Clin Toxicol 11(1):5–11.872541
Reid SJ, Watts RR. 1981. A method for the determination of dialkyl phosphate residues in urine. J Anal Toxicol 5:126–131.7265925
Richter ED, Kowalski M, Leventhal A, 1992. Illness and excretion of organophosphate metabolites four months after household pest extermination. Arch Environ Health 47(2):135–138.1567237
Robens JF. 1969. Teratologic studies of carbaryl, diazinon, norea, disulfiram, and thiram in small laboratory animals. Toxicol Appl Pharmacol 15(1):152–163.5798722
Roy TS, Sharma V, Seidler FJ, 2005. Quantitative morphological assessment reveals neuronal and glial deficits in hippocampus after a brief subtoxic exposure to chlorpyrifos in neonatal rats. Brain Res Dev Brain Res 155(1):71–80.15763277
RTECS. 2006. Diazinon. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc. April 24, 2006.
Rudzki MW, McCormick GC, Arthur AT. 1991. 52-Week oral toxicity study in dogs. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41942001.
*Sakai K, Matsumura F. 1971. Degradation of certain organophosphate and carbamate insecticides by human brain esterases. Toxicol Appl Pharmacol 19:660–666.5132034
Salas JH, Gonzalez M, Noa M, 2003. Organophosphorus pesticide residues in Mexican commercial pasteurized milk. J Agric Food Chem 51:4468–4471.12848527
Sams C, Cocker J, Lennard MS. 2004. Biotransformation of chlorpyrifos and diazinon by human liver microsomes and recombinant human cytochrome P450s (CYP). Xenobiotica 34(10):861–873.15764407
Sancho E, Ferrando MD, Gamon M, 1993. An approach to the diazinon toxicity in the European eel, bioaccumulation studies. Science of the Total Environment (Suppl 1993):461–468.
Sanders PF, Seiber JN. 1983. A chamber for measuring volatilization of pesticides from model soil and water disposal systems. Chemosphere 12:999–1012.
Sapozhnikova Y, Bawardi O, Schlenk D. 2004. Pesticides and PCB's in sediments and fish from the Salton Sea, California, USA. Chemosphere 55:797–809.15041284
Schenker MB, Albertson TE, Saiki CL. 1992. Pesticides (chapter 71). In: Rom WN, ed. Environmental and occupational medicine. 2nd ed. Boston: Little, Brown and Co., 887–902.
Scheunert I, Mansour M, Doerfler U, 1993. Fate of pendimethalin, carbofuran and diazinon under abiotic and biotic conditions. Sci Total Environ 132:361–369.
Schiff K, Sutula M. 2004. Organophosphorus pesticides in storm-water runoff from southern California (USA). Environ Toxicol Chem 23:1815–1821.15352468
Schoen SR, Winterlin WL. 1987. The effects of various soil factors and amendments on the degradation of pesticide mixtures. J Environ Sci Health B 22(3):347–377.3655189
Schomburg CJ, Glotfelty DE, Seiber JN. 1991. Pesticide occurrence and distribution in fog collected near Monterey, California. Environ Sci Technol 25:155–160.
See RH, Dunn BP, San RH C. 1990. Clastogenic activity in urine of workers occupationally exposed to pesticides. Mutat Res 241:251–259.2366805
Seguchi K, Asaka S. 1981. Intake and excretion of diazinon in freshwater fishes. Environ Contam Toxicol 27(2):244–249.
Seiber JN, Glotfelty DW, Lucas AD, 1990. A multiresidue method by high performance liquid chromatography-based fractionation and gas chromatographic determination of trace levels of pesticides in air and water. Arch Environ Contam Toxicol 19:583–592.2386412
Seiber JN, Wilson BW, McChesney MM. 1993. Air and fog deposition residues of four organophosphate insecticides used on dormant orchards in the San Joaquin Valley, California. Environ Sci Technol 27(10):2236–2243.
*Seifert J, Casida JE. 1978. Relation of yolk sac membrane kynurenine formamidase inhibition to certain teratogenic effects of organophosphorus insecticides and of carbaryl and eserine in chicken embryos. Biochem Pharmacol 27:2611–2615.83147
*Seifert J, Pewnim T. 1992. Alteration of mice L-tryptophan metabolism by the organophosphorous acid triester diazinon. Biochem Pharmacol 44(11):2243–2250.1282004
Setchell BP, Waites GM H. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Sethunathan N, MacRae IC. 1969. Persistence and biodegradation of diazinon in submerged soils. J Agric Food Chem 17:221–225.
Sethunathan N, Yoshida T. 1969. Fate of diazinon in submerged soil. J Agric Food Chem 17:1192–1195.
Shankar PS. 1978. Diazinon poisoning. Q Med Rev 29(2):31–43.740851
Shankar PS. 1967. Pulmonary oedema in diazinon poisoning. Indian J Chest Dis 9(2):106–110.5634269
Sharom MS, Miles JR W, Harris CR, 1980a. Behavior of 12 insecticides in soil and aqueous suspensions of soil and sediment. Water Res 14:1095–1100.
Sharom MS, Miles JR W, Harris CR, 1980b. Persistence of 12 insecticides in water. Water Res 14:1089–1093.
Shirasu Y, Moriya M, Kato K, 1976. Mutagenicity screening of pesticides in the microbial system. Mutat Res 40:19–30.814455
*Shishido T, Fukami J-I. 1972. Enzymatic hydrolysis of diazoxon by rat tissue homogenates. Pestic Biochem Physiol 2:30–50.
Singh AR. 1988. 90-Day oral toxicity study in rats. EPA guidelines no. 82–1. Laboratory study number 882011. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID40815003.
*Skinner CS, Kilgore WW. 1982. Acute dermal toxicities of various organophosphate insecticides in mice. J Toxicol Environ Health 9:491–497.7097799
Slotkin TA, Levin ED, Seidler FJ. 2006a. Comparative developmental neurotoxicity of organophosphate insecticides: Effects on brain development are separable from systemic toxicity. Environ Health Perspect 114(5):746–751.16675431
Slotkin TA, Seidler FJ, Fumagalli F. 2007. Exposure to organophosphates reduces the expression of neurotrophic factors in neonatal rat brain regions: Similarities and differences in the effects of chlorpyrifos and diazinon on the fibroblast growth factor superfamily. Environ Health Perspect 115(6):909–916.17589599
Slotkin TA, Tate CA, Ryde IT, 2006b. Organophosphate insecticides target the serotonergic system in developing rat brain regions: Disparate effects of diazinon and parathion at doses spanning the threshold for cholinesterase inhibition. Environ Health Perspect 114(10):1542–1546.17035140
Smith C. 2001. Pesticide exports from U.S. ports, 1997–2000. Int J Occup Environ Health 7:266–274.11783856
*Smith ID. 1970. An unusual sequel to the shower dipping of sheep with diazinon. Vet Rec 86(10):284–286.5461592
*Soliman MS, el-Missiry AG, Abdel Messih MS, 1984. The effect of diazinon and neguvon on the liver of experimentally intoxicated mice. J Egypt Soc Parasitol 14:557–562.6512302
Soliman SA, Sovocool GW, Curley A, 1982. Two acute human poisoning cases resulting from exposure to diazinon transformation products in Egypt. Arch Environ Health 37(4):207–212.7114900
Somasundaram L, Coats JR, Racke KD. 1989. Degradation of pesticides in soil as influenced by the presence of hydrolysis metabolites. J Environ Sci Health B 24:457–478.
Somasundaram L, Coats JR, Racke KD. 1991. Mobility of pesticides and their hydrolysis metabolites in soil. Environ Toxicol Chem 10:185–194.
Spyker JM, Avery DL. 1977. Neurobehavioral effects of prenatal exposure to the organophosphate diazinon in mice. J Toxicol Environ Health 3(5–6):989–1002.
SRI. 1994. Diazinon. Directory of chemical producers. Menlo Park, CA: SRI International, 802.
SRI. 1995. Diazinon. Directory of chemical producers. Menlo Park, CA: SRI International, 798.
SRI. 2005. Diazinon. 2005 Directory of chemical producers. Menlo Park, CA: Access Intelligence, LLC. SRI Consulting, 776.
Stalberg E, Hilton-Brown P, Kolmodin-Hedman B, 1978. Effect of occupational exposure to organophosphorus insecticides on neuromuscular function. Scand J Work Environ Health 4(3):255–261.212825
Suffet IH, Faust SD, Carey SF. 1967. Gas liquid chromatographic separation of some organophosphate pesticides, their hydrolysis products, and oxons. Environ Sci Technol 1:639–643.22148566
Suzuki S, Otani T, Iwasaki S, 2003. Monitoring of 15 pesticides in rainwater in Utsunomiya, Eastern Japan, 1999–2000. J Pestic Sci 28:1–7.
Szeto SY, Wan MT, Price P, 1990. Distribution and persistence of diazinon in a cranberry bog. J Agric Food Chemistry 38(1):281–285.
Takahashi H, Kojima T, Ikeda T, 1991. Differences in the mode of lethality produced through intravenous and oral administration of organophosphorus insecticides in rats. Fundam Appl Toxicol 16:459–468.1855619
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Timchalk C, Nolan RJ, Mendrala AL, 2002. A physiologically based pharmacokinetic and pharmacodynamic (PBPK/PD) model for the organophosphate insecticide chlorpyrifos in rats and humans. Toxicol Sci 66:34–53.11861971
Timchalk C, Poet TS, Hinman MN, 2005. Pharmacokinetic and pharmacodynamic interaction for a binary mixture of chlorpyrifos and diazinon in the rat. Toxicol Appl Pharmacol 205(1):31–42.15885262
Tisch M, Schmezer P, Faulde M, 2002. Genotoxicity studies on permethrin, DEET and diazinon in primary human nasal mucosal cells. Eur Arch Otorhinolaryngol 529(3):150–153.
Tomokuni K, Hasegawa T, Hirai Y, 1985. The tissue distribution of diazinon and the inhibition of blood cholinesterase activities in rats and mice receiving a single intraperitoneal dose of diazinon. Toxicology 37(1–2):91–98.
Toyoda M, Adachi K, Ida T, 1990. Simple analytical method for organophosphorus pesticide residues in milk. J Assoc Off Anal Chem 3(5):770–772.
TRI05. 2007. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. December 20, 2007.
Trutter JA. 1991. 6-Week feeding study in rats with diazinon. Nippon Kayaku Company, Ltd. Submitted to the U.S. Environmental Protection Agency. MRID41886301.
Tsuda T, Aoki S, Inoue T, 1995. Accumulation and excretion of diazinon, fenthion and fenitrothion by killifish: Comparison of individual and mixed pesticides. Water Res 29(2):455–458.
Tsuda T, Aoki S, Kojima M, 1989. Bioconcentration and excretion of diazinon, IBP, malathion and fenitrothion by willow shiner. Toxicol Environ Chem 24:185–190.
Tsuda T, Aoki S, Kojima M, 1990. Bioconcentration and excretion of diazinon, IBP, malathion and fenitrothion by carp. Comp Biochem Physiol C 96C(1):23–26.
Tsuda T, Kojima M, Harada A, 1997. Relationships of bioconcentration factors of organophosphate pesticides among species of fish. Comp Biochem Physiol 116C(3):213–218.
*Uchiyama M, Yoshida T, Homma K, 1975. Inhibition of hepatic drug-metabolizing enzymes by thiophosphate insecticides and its drug toxicological implications. Biochem Pharmacol 24(11–12):1221–1225.1137607
Ueyama J, Wang D, Kondo T, 2007. Toxicity of diazinon and its metabolites increases in diabetic rats. Toxicol Lett 170(3):229–237.17442507
USDA. 2006. Costs and charges. U.S. Department of Agriculture, Animal and Plant Health Inspection Service. Code of Federal Regulations. 7 CFR 301.81–10. http://a257.g.akamaitech.net/7/257/2422/01jan20061500/edocket.access.gpo.gov/cfr_2006/janqtr/pdf/7cfr301.81-10.pdf. January 11, 2008.
USGS. 1993. Diazinon concentrations in the Sacramento and San Joaquin Rivers and San Francisco Bay, California, January 1993. U.S. Geological Survey. Open-File Report 93–440. (Water fact sheet)
USGS. 2002a. Pesticides in surface water of the Takima River Basin, Washington 1999–2000. Their occurrence and an assessment of factors affecting concentrations and loads. Water-Resources Investigations Report. Portland, OR: U.S. Geological Survey, 1–50.
USGS. 2002b. Method O-1433–01: Pesticides and degradates, filtered water, gas chromatography/mass spectrometry. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory: Determination of wastewater compounds by polystyrene-divinylbenzene solid-phase extraction and capillary-column gas chromatography/mass spectrometry. U.S. Geological Survey. WRIR01–4186. http://nwql.usgs.gov/Public/pubs/WRIR01-4186.pdf. April 18, 2006.
USGS. 2002c. Method O-1402–01: Organophosphate pesticides, filtered water, gas chromatography. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory: Determination of organophosphate pesticides in filtered water by gas chromatography with flame photometric detection. U.S. Geological Survey. WRIR02–4071. http://nwql.usgs.gov/Public/pubs/WRIR02-4071.pdf. April 25, 2006.
USGS. 2002d. Method O-5404–02: Organophosphate pesticides, bottom sediment, high-performance gel-permeation chromatography, gas chromatography. Methods of analysis of the U.S. Geological Survey National Water Quality Laboratory: Determination of organophosphate pesticides in bottom sediment by gas chromatography with flame photometric detection. U.S. Geological Survey. WRIR02–4222. http://web1.er.usgs.gov/nemi/method_pdf/8943.pdf. April 25, 2006.
*Uzokwu M. 1974. Comparative feto-toxicity of organophosphate insecticide in mice. Bull Epizoot Dis Afr 22(2):161–166.4478980
van der Hoff GR, Baumann RA, Brinkman UA T, 1993. On-line combination of automated micro liquid-liquid extraction and capillary gas chromatography for the determination of pesticides in water. J Chromatogr 644:367–373.
Vasilic Z, Drevenkar V, Stengl B, 1993. Diethylphosphorus metabolites in serum and urine of persons poisoned by phosalone. Chem Biol Interactions 87:305–313.
Veith GD, Kosian P. 1983. Estimating bioconcentration potential from octanol/water partition coefficients. Ch. 15 In: Mackay D, Paterson S, Eisenreich SJ eds. Physical behavior of PCB's in the Great Lakes. Ann Arbor, MI: Ann Arbor Science Publishers, 269–282.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Wachs T, Gutenmann WH, Buckley EH, 1983. Concentration of diazinon in air of a retail garden store. Bull Environ ContamToxicol 31:582–584.
Wadia RS, Sadagopan C, Amin RS, 1974. Neurological manifestations of organophosphorus insecticide poisoning. J Neurol Neurosurg Psychiat 37:841–847.4853328
Wan Mt, Szeto S, Price P. 1994. Organophosphorus insecticide residues in farm ditches of the lower Fraser Valley of British Columbia. J Environ Science and Health B 29(5):917–949.
Wecker L, Mrak RE, Dettbarn WD. 1985. Evidence of necrosis in human intercostal muscle following inhalation of an organophosphate insecticide. J Environ Pathol Toxicol Oncol 6(2):171–175.
Wedin GP, Pennente CM, Sachdev SS. 1984. Renal involvement in organophosphate poisoning [letter]. JAMA 252(11):1408.
Weizman Z, Sofer S. 1992. Acute pancreatitis in children with anticholinesterase insecticide intoxication. Pediatrics 90(2):204–206.1379357
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Wester RC, Sedik L, Melendres J, 1993. Percutaneous absorption of diazinon in humans. Food Chem Toxicol 31(8):569–572.8349202
Whitmore RW, Immerman FW, Camann DE 1994. Non-occupational exposures to pesticides for residents of two U.S. cities. Arch Environ Contamin Toxicol 25(1):47–59.
WHO. 1998. Diazinon. Environmental health criteria 198. Geneva: United Nations Environment Programme. International Labour Organisation. World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc198.htm. March 03, 2006.
WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/Document/AIQ/AirQualRepMtg.pdf. March 08, 2006.
WHO. 2004. Guidelines for drinking-water quality. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 08, 2006.
Whyatt RM, Rauh V, Barr DB, 2004. Prenatal insecticide exposures and birth weight and length among an urban minority cohort. Environ Health Perspect 112(10):1125–1132.15238288
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
Williams PL, Burson JL, eds. 1985. Industrial toxicology: Safety and health applications in the workplace. New York, NY: Van Nostrand Reinhold Company, 129, 213, 216–217.
Williams DT, Shewchuck C, Lebel GL, 1987. Diazinon levels in indoor air after periodic application for insect control. Am Ind Hyg Assoc J 48(9):780–785.
Wilson BW. 2001. Cholinesterases. In: Krieger RI, ed. Handbook of pesticide toxicology. Vol. 2. San Diego, CA: Academic Press, 967–986.
Wong PK, Wai CC, Liong E. 1989. Comparative study on mutagenicities of organophosphorus insecticides in Salmonella. Chemosphere 18:2413–2422.
Worthing CR, Walker SB. 1983. The pesticide manual. A world compendium. Croydon: The British Crop Protection Council, 171.
Wright CG, Leidy RB, Dupree HE. 1996. Insecticide residues in the ambient air of commercial pest control buildings, 1993. Bull Environ Contam Toxicol 56:21–28.9026153
Wu HX, Evreux-Gros C, Descotes J. 1996c. Diazinon toxicokinetics, tissue distribution and anticholinesterase activity in the rat. Biomed Environ Sci 9(4):359–369.8988804
Wu HX, Evreux-Gros C, Descotes J. 1996a. Effects of cimetidine on the toxicokinetics and in vitro metabolism of diazinon in the rat. Res Commun Pharmacol Toxicol 1(1):67–80.
Wu HX, Evreux-Gros C, Descotes J. 1996b. Influence of cimetidine on the toxicity and toxicokinetics of diazinon in the rat. Hum Exp Toxicol 15:391–395.8735462
*Wylie PL, Oguchi R. 1990. Pesticide analysis by gas chromatography with a novel atomic emission detector. J Chromatogr 517:131–142.2250048
Yang RS H, Hodgson E, Dauterman WC. 1971. Metabolism in vitro of diazinon and diazoxon in rat liver. J Agric Food Chem 19(1):10–13.4395717
Yess NJ, Gunderson EL, Roy RR. 1993. U.S. Food and Drug Administration monitoring of pesticide residues in infant foods and adult foods eaten by infants/children. J AOAC Int 76(3):492–507.8318840
Yokley RA, Shen N, Cheung MW. 2000. Determination of two oxy-pyrimidine metabolites of diazinon in urine by gas chromatography/mass selective detection and liquid chromatography/electrospray ionization/mass spectrometry/mass spectrometry. J Assoc Off Anal Chem 83(5):1229–1238.
Zabik JM, Seiber JN. 1993. Atmospheric transport of organophosphate pesticides from California's Central Valley to the Sierra Nevada Mountains. J Environ Qual 22(1):80–90.
Zegers BN, De Geus HJ, Wildenburg SH J, 1994b. Large volume injection in packed capillary supercritical fluid chromatography. J Chromatogr 677(1):141–150.
Zegers BN, Hogenboom AC, Dekkers SE G, 1994a. Packed capillary supercritical fluid chromatography of organophosphorus pesticides: Selective detection and application. J Microcol Sep 6(1):55–62.
*Zhang Q, Pehkonen SO. 1999. Oxidation of diazinon by aqueous chlorine: Kinetics, mechanisms, and product studies. J Agric Food Chem 47(4):1760–1766.10564051
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372