# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of diazinon is located in Table 4-1.

Diazinon is manufactured in the United States and formulated as granules, a wettable powder, an emulsifiable solution, a dust, a seed dressing, or a mixed formulation with other insecticides. Manufacture of diazinon for indoor use products in the United States was discontinued as of March 1, 2001, and manufacture of non-agricultural outdoor use products was discontinued as of June 30, 2003 (HSDB 2008; WHO 1998).

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of diazinon is located in Table 4-2.

Table 4-1 Chemical Identity of Diazinon

Characteristic | Information | Reference
Chemical name | O,O-Diethyl O-(2-isopropyl-6-methyl-4-pyrimidinyl) phosphorothioate | HSDB 2008
Synonyms(s) | O,O-Diethyl-O-(2-isopropyl-4-methyl-6-pyrimidinyl) phosphorothioate; O,O-diethyl-O-6-methyl-2-isopropyl-4-pyrimidinyl] phosphorothioate; others | HSDB 2008
Registered trade name(s) | Diazinon; Alfa-tox; Basudin; Diazol; Gardentox; Knox-Out; Spectracide; others | HSDB 2008
Chemical formula | C_12_H_21_N_2_O_3_PS | HSDB 2008
Chemical structure | [image] | Kappers et al. 2001
Identification numbers:
CAS registry | 333-41-5 | HSDB 2008
NIOSH RTECS | TF 3325000 | NIOSH 2006
EPA hazardous waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | UN 2783 Organophosphorouspesticides; UN 2784 Organophosphorouspesticides; UN 3017 Organophosphorouspesticides; UN 3018 Organophosphorouspesticides; IM06.1 Organophosphorouspesticides; solid; IMO3.0 Organophosphorouspesticides; liquid | HSDB 2008
HSDB | 303 | HSDB 2008
NCI | CO 8673 | HSDB 2008

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/Intergovernmental Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS=Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Diazinon

Property | Information | Reference
Molecular weight | 304.35 | HSDB 2008
Color | Colorless | HSDB 2008
Physical state | Liquid | HSDB 2008
Melting point | No data | HSDB 2008
Boiling point | 83–84 °C at 2×10^−3^ mm Hg; decomposes at >120 °C | O’Neil et al. 2001
Density:
at 20 °C/4 °C | 1.116–1.118 g/mL | HSDB 2008
Odor | Faint ester-like | HSDB 2008
Odor threshold:
Water | No data
Air | No data | HSDB 2006
Taste threshold | No data
Solubility:
Water at 20 °C | 0.004% (40 mg/L) | HSDB 2008
Organic solvent(s) | Miscible with petroleum ether, alcohols, ether, cyclohexane, benzene and similar hydrocarbons | HSDB 2008
Partition coefficients:
Log K_ow_ | 3.81 | HSDB 2008
Log K_oc_ | 1.602–2.635, average for three soils, 2.281 | HSDB 2008
Vapor pressure
at 20 °C | 9.01×10^−5^ mm Hg | HSDB 2008
at 40 °C^b^ | 1.1×10^−3^ mm Hg | O’Neil et al. 2001
Henry’s law constant | 1.17×10^−7^ atm-m^3^/mol
Autoignition temperature | No data | HSDB 2008
Flashpoint | 82.2 °C | NIOSH 2006
Flammability limits | Practically nonflammable | HSDB 2008
Explosive limits | No data | HSDB 2008

HSDB = Hazardous Substances Data Bank; NIOSH = National Institute for Occupational Safety and Health;