# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Diazinon Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Diazinon
CAS Numbers: | 333-41-5
Date: | June 2008
Profile Status: | Final Draft Post-Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graphic Key: | 5
Species: | Rat

[underlined: Minimal Risk Level]: 0.01 [ ] mg/kg/day [X] mg/m^3^

[underlined: Reference]: Hartman HR. 1990. 21-Day repeated exposure inhalation toxicity in the rat. EPA guidelines no. 82-4. Laboratory study number 891205. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41557402.

[underlined: Experimental design]: Four groups of albino rats (10/sex) were exposed (nose only) to aerosols of diazinon (in ethanol) at concentrations of 0, 0.05, 0.46, 1.57, or 11.6 mg/m^3^ for 6 hours/day, 5 days/week for 3 weeks. Particle size analysis was performed to ensure that the test aerosols were in the respirable range for the rat. Two control groups were used, one exposed to humidified filtered air only and the other to the carrier vehicle ethanol. The test substance was the liquid MG-8 formulation (88% diazinon). Exposure levels were monitored by gas chromatography. Clinical examinations included ophthalmology, body weight, food consumption, hematology, and blood chemistry (including plasma ChE and RBC AChE activity). At necropsy, organ weights and brain AChE activity were assessed and histopathological examinations were performed on nasal tissues and lungs from all groups and on the spleen, heart, liver, kidney, adrenal gland, and any tissue with gross lesions from the control and 11.6 mg/m^3^ groups.

[underlined: Effect noted in study and corresponding doses]: No deaths or changes in body weights or food consumption were observed. Piloerection was noted in most animals, particularly during the first week of exposure, the incidence gradually declining during weeks 2 and 3 of exposure. This sign was neither exposure- nor dose-related and no clinical signs of organophosphate toxicity were observed. No exposure-related ophthalmoscopic or histopathological lesions were found. There were no statistically significant exposure-related effects on hematological parameters, although minimally lower values for erythrocyte count, hemoglobin, and packed red cell volume were observed in female rats of the highest exposure level. A significantly higher lung-to-body weight ratio was observed in female rats of the 0.46 and 1.57 mg/m^3^ exposure levels, but not at the highest exposure level. The toxicological significance of this effect is uncertain because no histopathological evidence of exposure-related lung lesions was found. As shown in Table A-1, significant reductions in plasma ChE (marker for exposure) were seen in males at exposure levels ≥1.57 mg/m^3^ and females at exposure levels ≥0.46 mg/m^3^. Organophosphate-induced plasma ChE inhibition is typically observed at exposure levels lower than those inducing measurable RBC or brain AChE inhibition. Plasma ChE inhibition is used as an indicator of exposure, but does not serve as a reliable indicator of a neurotoxic effect. Therefore, plasma ChE inhibition was not considered relevant to the selection of the critical effect for diazinon. However, inhibition of RBC AChE and brain AChE represents a relevant neurological effect. In the principal study (Hartman 1990), significant reductions in RBC AChE activity (surrogate marker for neural AChE activity) were seen in male rats at 11.6 mg/m^3^ and in female rats at 1.57 and 11.6 mg/m^3^ (Table A-1). Treatment-related 20–59% RBC or brain AChE inhibition is considered to represent a less serious adverse effect in the absence of more clear indicators of neurotoxicity (Chou and Williams-Johnson 1998). The 10% RBC AChE inhibition observed in the 1.57 mg/m^3^ group of female rats is below the level of inhibition considered to represent an adverse effect. Therefore, the 1.57 mg/m^3^ exposure level is a NOAEL and the highest exposure level (11.6 mg/m^3^) is the lowest-observed-adverse-effect level (LOAEL) for 36 and 39% RBC AChE inhibition in the male and female rats, respectively. There was no significant difference between brain AChE activity in any of the exposure groups of male rats and that of vehicle controls. All diazinon-exposed groups of female rats exhibited significantly decreased brain AChE activity, relative to vehicle controls. The report of significantly increased brain AChE inhibition in the female rats of all exposure levels is indicative of an inherent problem with the brain data set, perhaps related to tissue collection or quantitative analysis of enzymatic activity in the brain tissue of the female rats. Furthermore, results of repeated oral dosing (Singh 1988) indicate that the male and female rats are comparably sensitive to diazinon-induced effects on both RBC and brain AChE activity. Therefore, the report (Hartman 1990) of significant brain AChE inhibition in the female rats exposed to diazinon by inhalation at levels much lower than the LOAEL of 11.6 mg/m^3^ for RBC AChE inhibition is questionable and a clear LOAEL for brain AChE inhibition cannot be determined.

Table A-1 Relative Change (Percent of Control Values) in Cholinesterase Activities in Male and Female Rats Following Exposure to Aerosols of Diazinon for 90 Days

| Plasma ChE | RBC AChE | Brain AChE
Male rats
0.05 mg/m^3^ | +9%^a^ | +2% | −1%
0.46 mg/m^3^ | −5% | −5% | +1%
1.57 mg/m^3^ | −14%^b^ | −6% | −4%
11.6 mg/m^3^ | −19%^b^ | −36%^a^ | −3%
Female rats
0.05 mg/m^3^ | −3% | −1% | −24%^a^
0.46 mg/m^3^ | −20%^b^ | +6% | −17%^b^
1.57 mg/m^3^ | −27%^a^ | −10%^b^ | −20%^b^
11.6 mg/m^3^ | −43%^a^ | −39%^a^ | −37%^a^

a Statistically significantly different from control (p≤0.01)

b Statistically significantly different from control (p≤0.05)

AChE = acetylcholinesterase; ChE = cholinesterase; RBC = red blood cell

Source: Hartman 1990

[underlined: Dose and end point used for MRL derivation]: A NOAEL of 1.57 mg/m^3^; the LOAEL was 11.6 mg/m^3^ for 36–39% RBC AChE inhibition in male and female rats of the principal study

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [X] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [X] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: The NOAEL of 1.57 mg/m^3^ was adjusted for intermittent exposure as follows:

NOAEL_ADJ_ = 1.57 mg diazinon/m^3^ x 6 hours/24 hours x 5 days/7 days = 0.28 mg diazinon/m^3^

A regional deposited dose ratio (RDDR_ER_) of 1.558 for extrarespiratory effects was used to extrapolate from rats to humans. The RDDR_ER_ was calculated using EPA’s software (Version 2.3) (EPA 1994b) for calculating RDDRs and the parameters listed in Table A-2.

Table A-2 Parameters^a^ Used to Calculate the Regional Deposited Dose Ratio (RDDR_ER_) for Diazinon-induced Extrarespiratory Effects Using EPA’s Software (Version 2.3)

Biological parameters^b^ | Rat | Human
Surface area
Extrathoracic | 15 cm^2^ | 200 cm^2^
Tracheobronchial | 22.5 cm^2^ | 3,200 cm^2^
Pulmonary | 0.34 m^2^ | 54 m^2^
Minute ventilation | 147.24 mL | 13.8 L
Body weight | 196 g | 70 kg

a Mass Median Aerodynamic Diameter (MMAD) = 0.85 μm from lower limit of 0.8 μm and upper limit of 0.9 μm for the 1.57 mg/m^3^ exposure group of female rats reported by Hartman (1990); Geometric Standard Deviation (GSD) = 1.3 μm from lower limit of 1.2 μm and upper limit of 1.4 μm reported by Hartman (1990).

b Parameters are default values for rats and humans from the EPA software, except for the rat body weight which was the mean body weight for the 1.57 mg/m^3^ exposure group of female rats.

Source: Hartman 1990

The human equivalent concentration was calculated using Equation 4–5 (EPA 1994b) as follows:

NOAEL_HEC_ = NOAEL_ADJ_ x RDDR_ER_ = 0.28 mg diazinon/m^3^ x 1.558 = 0.44 mg diazinon/m^3^

The NOAEL_HEC_ of 0.44 mg/m^3^ was divided by an uncertainty factor of 30 (3 for extrapolation from animals to humans using dosimetric adjustment and 10 for human variability), resulting in an intermediate-duration inhalation MRL of 0.01 mg/m^3^.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: This is the only available well-conducted, intermediate-duration inhalation study for diazinon. In an acute-duration study in which rats were exposed to 2,300 mg/m^3^ diazinon for 4 hours (Holbert 1989), mild signs of organophosphate toxicity were noted (nasal discharge, salivation).

[underlined: Agency Contacts (Chemical Managers)]: G. Daniel Todd, Ph.D.; Carolyn Harper, Ph.D.; Paula Burgess, M.D.

## Diazinon Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Diazinon
CAS Numbers: | 333-41-5
Date: | June 2008
Profile Staus: | Final Draft Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graphic Key: | 23
Species: | Rat

[underlined: Minimal Risk Level]: 0.006 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: Davies DB, Holub BJ. 1980a. Toxicological evaluation of dietary diazinon in the rat. Arch Environ Contam Toxicol 9(6):637–650.7469478

[underlined: Experimental design]: Groups of female Wistar rats (50/group) were exposed to diazinon (99.2% purity) in the diet at concentrations of 0, 5, 10, or 15 ppm for 92 days. Interim assessments of neurological end points included treatment day 12 assessment, which represents acute-duration oral exposure. Blood samples were collected on treatment days 3, 8, and 12 from 10 rats/group for assessment of plasma ChE and RBC AChE activity. Other groups of similarly-treated rats were sacrificed (n=6) for assessment of brain AChE activity. All rats were assessed daily for clinical signs of neurotoxicity and body weights and food intake were monitored throughout the treatment period. The study authors reported starting mean body weight (0.139 kg), mean body weight gain (0.00163 kg/day), and mean food consumption (0.0178 kg/day) for all rats, and indicated that they did not significantly differ among treatment groups. Using the average body weight gain for 12 days (0.00163 kg/day x 12 days=0.02 kg), the average body weight for the 12-day period was equal to the starting body weight (0.139 kg) plus one-half the body weight gain during the 12-day period (0.5x0.02 kg)=0.149 kg. The diazinon dose equals the product of the diazinon concentration in food times the mean daily food consumption divided by the average body weight. Calculated in this manner, the doses to the 5-, 10-, and 15-ppm exposure groups were 0.6, 1.2, and 1.8 mg/kg/day, respectively.

[underlined: Effect noted in study and corresponding doses]: No clinical signs of toxicity were observed in any of the treated groups. Compared to controls, significant plasma ChE inhibition was observed in all diazinon-treated groups at all timepoints (including treatment days 3, 8, and 12). At treatment day 12, treatment-related effects included 43, 70, and 73% plasma ChE inhibition and 5, 22, and 33% RBC AChE inhibition in the 0.6, 1.2, and 1.8 mg/kg/day dose groups, respectively. There was no significant effect on brain AChE activity. Plasma ChE inhibition is used as an indicator of exposure, but does not serve as a reliable indicator of a neurotoxic effect. Therefore, plasma ChE inhibition was not considered relevant to the selection of the critical effect for diazinon. However, inhibition of RBC AChE and brain AChE represents a relevant neurological effect. Treatment-related 20–59% RBC or brain AChE inhibition is considered to represent a less serious adverse effect in the absence of more clear indicators of neurotoxicity. The principal study (Davies and Holub 1980a) identified a NOAEL of 0.6 mg/kg/day and a LOAEL of 1.2 mg/kg/day for 22% RBC AChE inhibition at interim day 12 assessment of female rats administered diazinon in the diet for 92 days.

[underlined: Dose and end point used for MRL derivation]: A NOAEL of 0.6 mg/kg/day; the LOAEL was 1.2 mg/kg/day for 22% RBC AChE inhibition

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [X] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [X] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Doses were calculated from reported mean values for initial body weight, food consumption, and body weight gain for the first 12 days of treatment.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: In an unpublished study (EPA 1996), male and female rats were administered diazinon in the diet for 28 days and assessed for cholinesterase inhibition at weeks 1, 2, and 4. A dose of 2.4 mg/kg/day resulted in 38–59% RBC AChE inhibition in both males and females, which was observed as early as week 1 and peaked at week 2. The next lower dose (0.02 mg/kg/day) represented a NOAEL. The principal study for deriving the acute-duration oral MRL for diazinon (Davies and Holub 1980a) was performed using only female rats. However, Davies and Holub (1980a) noted that dietary studies in their laboratory had demonstrated that female rats were more sensitive than male rats to diazinon induced plasma ChE and RBC and brain AChE inhibition. In light of this finding, the selection of RBC AChE inhibition in the female rats as the critical effect from the principal study that assessed the critical effect only in female rats (Davies and Holub 1980a) is appropriate.

[underlined: Agency Contacts (Chemical Managers)]: G. Daniel Todd, Ph.D.; Carolyn Harper, Ph.D.; Paula Burgess, M.D.

## Diazinon Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical name: | Diazinon
CAS number(s): | 333-41-5
Date: | June 2008
Profile Status: | Final Draft Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to figure: | 63
Species: | Rat

[underlined: Minimal Risk Level:] 0.002 [X] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference:] Davies DB, Holub BJ. 1980a. Toxicological evaluation of dietary diazinon in the rat. Arch Environ Contam Toxicol 9(6):637–650.7469478

Note: Available intermediate-duration oral (dietary) toxicity studies of diazinon include 10 studies in rats and 2 studies in dogs (see Table A-4, page A-14, for a summary of NOAELs and LOAELs for RBC and brain AChE inhibition identified in these studies). Although dose spacing is variable, and in some studies may be in excess of 100-fold for levels at or below identified LOAELs for AChE inhibition, these studies collectively indicate that the threshold for less serious AChE inhibition occurs in rats and dogs at repeated oral dose levels between 0.2 and 2 mg/kg/day. The report of Davies and Holub (1980a) includes results from separate 35-, 42-, and 92-day studies.

[underlined: Experimental design]: In the principal study, groups of female Wistar rats (16/group) were exposed to diazinon (99.2% purity) in the diet at concentrations of 0, 1, 2, 3, or 4 ppm for 42 days (Davies and Holub 1980a). Blood samples were collected periodically from 10 rats/group for assessment of plasma ChE and RBC AChE activity. Six rats per group were sacrificed on day 35 for assessment of brain AChE activity. All rats were assessed daily for clinical signs of neurotoxicity and body weights and food intake were monitored throughout the treatment period. The study authors stated that female rats were used in the study because they were noted to be more sensitive than male rats to the neurotoxic effects of diazinon. The study authors reported starting mean body weight (0.149 kg), mean body weight gain (0.00259 kg/day), and mean food consumption (0.0178 kg/day) for all rats, and indicated that they did not significantly differ among treatment groups. Using the average body weight gain for 42 days (0.00259 kg/day x 42 days=0.11 kg), the average body weight for the 42-day period was equal to the starting body weight (0.149 kg) plus one-half the body weight gain during the 42-day period (0.5x0.11 kg)=0.2 kg. The diazinon dose equals the product of the diazinon concentration in food times the mean daily food consumption divided by the average body weight. Calculated in this manner, the doses to the 1-, 2-, 3-, and 4-ppm exposure groups were 0.09, 0.18, 0.27, and 0.36 mg/kg/day.

[underlined: Effects noted in study and corresponding doses:] No clinical signs of toxicity were observed in any of the treated groups (Davies and Holub 1980a). Significant plasma ChE inhibition was observed at most timepoints in all diazinon-treated groups, relative to controls. The magnitude of inhibition in all treatment groups increased with time and appeared to peak around day 35, remaining near the peak level for the remaining 7 treatment days. Maximum plasma ChE inhibition in the 1, 2, 3, and 4 ppm treatment groups was approximately 35, 50, 55, and >60%, respectively. Plasma ChE inhibition is used as an indicator of exposure, but does not serve as a reliable indicator of a neurotoxic effect. Therefore, plasma ChE inhibition was not considered relevant to the selection of the critical effect for diazinon. Through treatment day 35, there was no significant treatment-related effect on RBC AChE activity in any of the treatment groups. However, on treatment day 42, significant RBC AChE inhibition was observed at treatment levels of 2, 3, and 4 ppm (magnitude 9, 20, and 22%, respectively). There were no indications of treatment-related significant brain AChE inhibition at any timepoint during the 42 days of treatment. The results of RBC AChE activity in the female rats of the principal study (Davies and Holub 1980a) are presented in Table A-3. Inhibition of RBC AChE and brain AChE represents a relevant neurological effect. Treatment-related 20–59% RBC or brain AChE inhibition is considered to represent a less serious adverse effect in the absence of more clear indicators of neurotoxicity. The principal study (Davies and Holub 1980a) identified a NOAEL of 0.18 mg/kg/day and a LOAEL of 0.27 mg/kg/day for 20% RBC AChE inhibition in female rats administered diazinon in the diet for 42 days.

Table A-3 RBC AChE Data From Female Rats Exposed to Diazinon in the Diet for 42 Days

Dose group (mg/kg/day) | Number of rats | RBC AChE activity (μmole/mL packed cells/minute) | Percent RBC AChE inhibition
0 | 10 | 0.74±0.05^a^
0.09 | 10 | 0.68±0.07 | 8
0.18 | 10 | 0.67±0.06 | 9
0.27 | 10 | 0.59±0.04 | 20
0.36 | 10 | 0.58±0.02 | 22

a Mean±standard error

AChE = acetylcholinesterase; RBC = red blood cell

Source: Davies and Holub 1980a

The linear model in the EPA Benchmark Dose Software (Version 1.3.2) was fit to the female rat data for RBC AChE activity shown in Table A-3. A benchmark response (BMR) of 20% below the control mean RBC AChE activity was selected because treatment-related 20–59% RBC or brain AChE inhibition is considered to represent a less serious adverse effect in the absence of more clear indicators of neurotoxicity (Chou and Williams-Johnson 1998). Although the linear model provided adequate fit to the data from Table A-3, as indicated by acceptable p values for tests for (1) differences in response and/or variances among dose levels, (2) homogeneous or non-homogeneous variance, and (3) model mean fit, a non-homogeneous variance model run was suggested. Adequate fit was also provided by the linear model using non-homogeneous variance, which resulted in a BMD_20_ of 0.3267 mg/kg/day and a BMDL_20_ of 0.2238 mg/kg/day. Because the simplest model, the linear model, provided adequate fit to the RBC AChE data from the 42-day rat study of Davies and Holub (1980a), the application of more complex continuous variable models was not considered necessary. The BMDL_20_ of 0.2238 mg/kg/day served as the point of departure for deriving an intermediate-duration oral MRL for diazinon.

Figure A-1 is a plot of predicted and observed levels of RBC AChE activity in the female dogs of the principal study (Davies and Holub 1980a) generated from the linear model using non-homogeneous variance.

Figure A-1 Predicted and Observed Levels of RBC AChE Activity in Female Dogs Orally Exposed to Diazinon for 42 Days^*^ * BMD and BMDL (in mg/kg/day) are associated with a benchmark response of 20% reduction in RBC AChE activity from the control value

The linear model form and parameters output from benchmark dose analysis of RBC AChE activity in the female rats of the principal study (Davies and Holub 1980a) follows:

The form of the response function is:

   Y[dose] = beta_0 + beta_1*dose + beta_2*dose^2 + ...

   Dependent variable = MEAN
   Independent variable = dose
   Signs of the polynomial coefficients are not restricted
   The variance is to be modeled as Var(i) = alpha*mean(i)^rho

   Total number of dose groups = 5
   Total number of records with missing values = 0
   Maximum number of iterations = 250
   Relative Function Convergence has been set to: 1e-008

   Parameter Convergence has been set to: 1e-008 
 
  
          Default Initial Parameter Values
                  alpha =      0.02612
                    rho =            0
                 beta_0 =        0.734
                 beta_1 =    -0.455556 
 
  
     Parameter Estimates     95.0% Wald ConfidenceInterval
 Variable       Estimate       Std. Err. Lower Conf. Limit Upper Conf. Limit
  alpha       0.729698        0.927763        -1.08868           2.54808
   rho        8.31            2.91288          2.60086          14.0191
 beta_0       0.73306         0.0466142        0.641698          0.824422
 beta_1      -0.448823       0.162678         -0.767667         -0.129979
 
  
         Asymptotic Correlation Matrix of Parameter Estimates
  
 
                alpha          rho      beta_0        beta_1

        alpha       1         0.99      -0.049         0.064
          rho    0.99            1      -0.053         0.068
       beta_0  -0.049       -0.053           1         -0.93
       beta_1   0.064        0.068       -0.93             1
  
 
         Table of Data and Estimated Values of Interest
  
 
      Dose   N   Obs Mean   Obs Std Dev   Est Mean   Est Std Dev   Chi^2 Res.
         0  10      0.74        0.16        0.733        0.235        0.0934
      0.09  10      0.68        0.22        0.693        0.186        -0.216
      0.18  10      0.67        0.19        0.652        0.145         0.387
      0.27  10      0.59        0.13        0.612        0.111        -0.623
      0.36  10      0.58        0.06        0.571       0.0835         0.322
  
 
  Model Descriptions for likelihoods calculated
 
  
  Model A1:        Yij = Mu(i) + e(ij)
             Var{e(ij)} = Sigma^2
 
   Model A2:       Yij = Mu(i) + e(ij)
            Var{e(ij)} = Sigma(i)^2
 
   Model A3:       Yij = Mu(i) + e(ij)
            Var{e(ij)} = alpha*(Mu(i))^rho
 
   Model R:         Yi = Mu + e(i)
             Var{e(i)} = Sigma^2


                        Likelihoods of Interest

 
             Model      Log(likelihood)   DF       AIC
              A1           68.760362       6   -125.520725
              A2           76.244732      10   -132.489465
              A3           74.537476       7   -135.074952
            fitted         72.450460       4   -136.900920
              R            64.715236       2   -125.430471


                       Explanation of Tests
 
 
Test 1: Does response and/or variances differ among Dose levels? (A2 vs. R)
Test 2: Are Variances Homogeneous? (A1 vs A2)
Test 3: Are variances adequately modeled? (A2 vs. A3)
Test 4: Does the Model for the Mean Fit? (A3 vs. fitted)


                        Tests of Interest
 
 
Test        -2*log(Likelihood Ratio)  Test df    p-value
 
 
Test 1                    23.059         8    0.003289
Test 2                   14.9687         4    0.004766
Test 3                   3.41451         3       0.332
Test 4                   4.17403         3      0.2433


The p-value for Test 1 is less than .05. There appears to be a difference between response and/or variances among the dose levels. It seems appropriate to model the data


The p-value for Test 2 is less than .05. A non-homogeneous variance model appears to be appropriate


The p-value for Test 3 is greater than .05. The modeled variance appears to be appropriate here


The p-value for Test 4 is greater than .05. The model chosen seems to adequately describe the data


 Benchmark Dose Computation
Specified effect =            0.2


Risk Type        =      Relative risk


Confidence level =            0.95
             
             BMD =        0.326659

            BMDL =          0.2238

The BMDL_20_ of 0.2238 mg/kg/day was divided by a total uncertainty factor (UF) of 100 (10 for extrapolation from animals to humans and 10 for human variability) as follows:

Intermediate-duration oral MRL = BMDL_20_ ÷ UF = 0.2238 mg/kg/day ÷ 100 = 0.002 mg/kg/day

[underlined: Dose end point used for MRL derivation]: BMDL_20_ of 0.2238 mg/kg/day for RBC AChE activity

[ ] NOAEL [ ] LOAEL [X] Benchmark

[underlined: Uncertainty factors used in MRL derivation:]

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [X] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [X] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Doses were calculated from reported mean values for initial body weight, food consumption, and body weight gain for the 42-day treatment period.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The selection of the BMD_20_ of 0.3267 mg/kg/day and its lower 95% confidence limit (BMDL_20_) of 0.2238 mg/kg/day from the female rats of the principal study (Davies and Holub 1980a) as a point of departure for deriving an intermediate-duration oral MRL for diazinon is supported by the results of several studies (see Table A-4). These studies collectively indicate that the threshold for less serious AChE inhibition occurs in rats and dogs at repeated oral dose levels between 0.2 and 2 mg/kg/day. The derived intermediate-duration oral MRL of 0.002 mg/kg/day is supported by the free-standing NOAEL of 0.03 mg/kg/day identified in four male volunteers administered diazinon in gelatin capsules at a dose level of 0.03 mg/kg/day for 28–31 days.

Table A-4 NOAELs and LOAELs for RBC and Brain AChE Inhibition Following Intermediate-duration Dietary Exposure to Diazinon

Study type estimated doses (mg/kg/day) | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) AChE inhibition | Reference
28-Day rat study | 0.02 (M, F) | 2.4; M, F: 38–59% RBC | EPA 1996
M, F: 0, 0.02, 2.4, 23, 213
30-Day rat study | ND | 2.86; 58% RBC | Davies and Holub 1980b
F: 0, 2.86 | | | Davies and Holub 1980b
35-Day rat study | 0.2 | ND | Davies and Holub 1980a
F: 0, 0.009, 0.05, 0.09, 0.2 | | | Davies and Holub 1980a
42-Day rat study | 0.2 | 0.3; 20% RBC | Davies and Holub 1980a
F: 0, 0.09, 0.18, 0.27, 0.36 | | | Davies and Holub 1980a
6-Week rat study | 0.2 (M, F) | 2.0; M, F: 46–61% RBC | EPA 2000a
0, 0.02, 0.05, 0.2, 2, 9.5, 28
6-Week rat study | | | EPA 2000a
M: 0, 0.02, 0.04, 0.17, 1.68, 8.6, 25.8 | 0.17 (M) | 1.68; M: 29–35% RBC
F: 0, 0.02, 0.05, 0.19, 1.82, 9.27, 29 | 0.19 (F) | 1.82; F: 16–35% RBC
6-Week rat study | 0.2 (M, F) | 8.4; M: 21% RBC | Singh 1988
M: 0, 0.04, 0.2, 8.4, 165
F: 0, 0.05, 0.2, 9.4, 198 | | 9.4; F: 21% RBC and 24% brain
90-Day rat study | | | Singh 1988
M: 0, 0.03, 0.3, 15, 168 | 0.3 (M) | 15; M: 27% RBC
F: 0, 0.04, 0.4, 19, 212 | 0.4 (F) | 19; F: 41% RBC
90-Day rat study | 0.018 (M, F) | 1.8; M, F: 37–75% RBC | EPA 1996
0, 0.018, 1.8, 18, 180
92-Day rat study | 0.4 | 0.7; 40% RBC | Davies and Holub 1980a
F: 0, 0.4, 0.7, 1 | | | Davies and Holub 1980a
4-Week dog study | | | Barnes 1988
M: 0, 0.02, 0.073, 0.8, 14.68 | 0.8 (M) | 14.68; M: 25% RBC; 31% brain
F: 0, 0.023, 0.082, 0.75, 15.99 | 0.75 (F) | 5.6; F: 31% RBC; 30% brain
13-Week dog study | 0.02 (M, F) | | Barnes 1988
M: 0, 0.0034, 0.02, 5.9, 10.9 | | 5.9; M: 26% RBC; 31% brain
F: 0, 0.0037, 0.02, 5.6, 11.6 | | 5.6; F: 31% RBC; 30% brain

AChE = acetylcholinesterase; F = female; LOAEL = lowest-observed-adverse-effect level; M = male; ND = not determined; NOAEL = no-observed-adverse-effect level; RBC = red blood cell

[underlined: Agency Contacts (Chemical Managers)]: G. Daniel Todd, Ph.D.; Carolyn Harper, Ph.D.; Paula Burgess, M.D.

## Diazinon Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Diazinon
CAS Numbers: | 333-41-5
Date: | June 2008
Profile Status: | Final Draft Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 91
Species: | Rat

[underlined: Minimal Risk Level]: 0.0007 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: Kirchner FR, McCormick GC, Arthur AT. 1991. One/two year oral toxicity study in rats. Ciba-Geigy Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41942002.

[underlined: Experimental design]: (human study details or strain, number of animals per exposure/control group, sex, dose administration details): Diazinon MG-8 (purity 87.7%) was dissolved in acetone vehicle and added to the diet of male and female Sprague-Dawley rats at concentrations of 0, 0.1, 1.5, 125, or 250 ppm for up to 98 weeks. The study included both untreated and vehicle control groups. According to the study report, the corresponding doses were 0, 0.004, 0.06, 5, and 10 mg/kg/day for males and 0, 0.005, 0.07, 6, and 12 mg/kg/day for females). Averaged among male and female rats, the corresponding doses were 0, 0.0045, 0.065, 5.5, and 11 mg/kg/day. Twenty rats/sex/group were treated for the full 98 weeks. Ten rats/sex/group were treated for 52 weeks and sacrificed for interim assessment. Additional groups of 10 rats/sex were assigned to the untreated control, vehicle control, and 250 ppm groups and assessed for recovery 45 days following 52 weeks of treatment. Animals were observed daily for clinical signs of toxicity. Food consumption, water intake, and body weights were monitored. Ophthalmoscopic examinations were performed during weeks 2, 51, and 97 or 98. Blood was collected at several timepoints between days 88 and 684. Ten animals/sex/group from the 98-week treatment groups received clinical chemistry evaluation at treatment days 88, 181, 356, 390, 552, and 684. Urinalysis was performed on all surviving rats of the 98-week treatment groups at treatment days 81, 189, 350, 545, and 679. All rats were subjected to comprehensive gross and microscopic pathologic examination at death or sacrifice.

[underlined: Effect noted in study and corresponding doses]: There were no apparent treatment-related effects on survival, food or water consumption, body weights, or hematological or urinalysis parameters examined. Due to mortality in all groups including controls the study was terminated at 97 weeks. Ophthalmoscopic and gross and microscopic examinations did not reveal evidence of dose-related effects. The major findings of this study were those of dose-related decreased plasma ChE and RBC and brain AChE activity in both male and female rats. Significantly decreased plasma ChE activity (28–51% lower than controls) was noted in 0.065 mg/kg/day male rats at treatment days 88 and 684, but not at treatment days 181, 356, or 552 and in 0.065 mg/kg/day female rats (approximately 50% lower than controls) at most timepoints. High-dose male and female rats consistently exhibited significantly decreased plasma ChE activity, ranging from 80 to 97% lower than controls. In 0.065 mg/kg/day groups, RBC and brain AChE activity was not significantly decreased at any timepoint. The 5.5 mg/kg/day groups exhibited significantly decreased RBC AChE activity at all timepoints, ranging in magnitude from 15 to 28% and from 22 to 25% in males and females, respectively. At the 5.5 and 11 mg/kg/day levels, the magnitude of the effect did not appear to increase with either duration of treatment or increased dose. Following 52 weeks of treatment and 45 days of recovery, RBC AChE activity had returned to control levels in high-dose male rats and to within 7% of control levels in high-dose female rats. Brain AChE activity was significantly decreased in 5.5 and 11 mg/kg/day male and female rats. In 5.5 and 11 mg/kg/day males, the magnitude of the effect was effect was 24 and 42%, respectively, after 684 days of treatment, but not significantly different from controls at 370 days. In 5.5 and 11 mg/kg/day female rats, the effect was noted at both 370- and 684-day timepoints; the magnitude of the effect was >24% at 5.5 mg/kg/day and >40% at 11 mg/kg/day. This study identified a NOAEL of 0.065 mg/kg/day (1.5 ppm of diazinon in the diet) and a LOAEL of 5.5 mg/kg/day (125 ppm of diazinon in the diet) for 22–28% decreased RBC AChE activity in male and female rats administered diazinon in the diet for up to 97 weeks, which is considered the critical effect. The effect was observed as early as day 88 of treatment and did not appear to increase in magnitude with duration of treatment.

[underlined: Dose and end point used for MRL derivation]: A NOAEL of 0.065 mg/kg/day; the LOAEL was 5.5 mg/kg/day for 22–28% decreased RBC AChE activity

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [X] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [X] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Estimated doses were included in the original study.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:] Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure?] Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL:] Groups of 5-month-old male and female Beagle dogs (4/sex/group) were administered diazinon MG-8 (87.7% purity) in the diet for 52 weeks at concentrations of 0, 0.1, 0.5, 150, or 300 ppm (Rudzki et al. 1991). The highest dose level was reduced to 225 ppm after 14 weeks due to the lack of body weight gain at the 300 ppm level. According to the study authors, the corresponding diazinon doses (adjusted for purity) were 0, 0.0032, 0.015, 4.7, and 7.7 mg/kg/day for the males and 0, 0.0037, 0.02, 4.5, and 9.1 mg/kg/day for the females. Averaged among male and female dogs, the corresponding doses were 0, 0.0034, 0.017, 4.6, and 7.9 mg/kg/day. Animals were observed daily for clinical signs of toxicity. Food consumption and body weights were monitored throughout the study. Physical, auditory, and ophthalmoscopic examinations were periodically performed. Blood and urine were collected 4 weeks prior to dosing and during treatment weeks 13, 26, 39, and 52 for hematological and clinical chemistry assessment and urinalysis. At death or scheduled sacrifice, organ weights were recorded and all animals were subjected to histological examination of all major organs and tissues. One high-dose male was sacrificed on test day 2 and one female in the 0.5 ppm group was found dead on test day 12. Both deaths were attributed to gastrointestinal infections and the animals were replaced. Clinical signs of toxicity were limited to a single high-dose male that exhibited signs of dehydration and emaciation. Although food consumption in all treatment groups of male and female dogs was lower than that of controls at most timepoints during the 52 weeks of treatment, there was no clear pattern of dose-related decreased food consumption. The 4.6 mg/kg/day dose level may represent a LOAEL for body weight gain in the males, but a clear effect level for body weight gain was not identified in females. Plasma ChE inhibition generally exceeded 20% in all dose groups of males and females, with the exception of the 0.0034 mg/kg/day groups. Significant RBC AChE inhibition (magnitude ranging from approximately 21 to 35%) was noted in treated males and females of the two highest exposure groups (4.6 and 7.9 mg/kg/day), but not at lower exposure levels. Significant brain AChE inhibition was noted at 4.6 and 7.9 mg/kg/day in females (magnitude 25.5 and 34.7%, respectively). High-dose males exhibited 24.8% brain AChE inhibition (not statistically significant). Although serum amylase activity was generally increased in diazinon-treated male and female dogs at most timepoints, the only statistically significant increase occurred in 4.6 mg/kg/day males only at week 52. There were no other treatment-related effects on clinical chemistry parameters examined. Ophthalmoscopic examinations, hematology, and urinalysis did not reveal evidence of treatment-related effects. There were no apparent treatment-related effects on organ weights and extensive gross and microscopic examinations were unremarkable. This study identified a NOAEL of 0.5 ppm (0.017 mg/kg/day) and a LOAEL of 150 ppm (4.6 mg/kg/day) for RBC AChE inhibition of 20% or more in both male and female dogs.

[underlined: Agency Contacts (Chemical Managers)]: G. Daniel Todd, Ph.D.; Carolyn Harper, Ph.D.; Paula Burgess, M.D.