# 8 REFERENCES

*Cited in text

*ACGIH. 1994. Threshold limit values for chemical substances and physical agents and biological exposure indices (1994- 1995). American Conference of Governmental Industrial Hygienists. Cincinnati. OH.
*Ahdaya SM, Monroe RJ, Guthrie FE. 1981. Absorption and distribution of intubated insecticides in fasted mice. Pestic Biochem Physiol 16(1):38–46.
*Ahmad MM, Ahmad MM, Sarvat S. 1993. Effects of endosulfan and chlorpyrifos on the reproductive organs and sex hormones of neonatal rats. Pakistan J Zool 25(1):11–14.
*Aiuto LA, Pavlakis SG, Boxer RA. 1993. Life-threatening organophosphate-induced delayed polyneuropathy in a child after accidental chlorpyrifos ingestion. J Pediatr 122(4):658–660.7681876
*Amer SM, Aly FA. 1992. Cytogenetic effects of pesticides. IV. Cytogenetic effects of the insecticides Gardona and Dursban. Mutat Res 279(3):165–170.1377331
*Amer SM, Fahmy MA. 1982. Cytogenetic effects of pesticides. I. Induction of micronuclei in mouse bone marrow by the insecticide Dursban. Mutat Res 101(3):247–255.6178020
*Ames RG, Brown SK, Rosenberg J, . 1989. Health symptoms and occupational exposure to flea control products among California pet handlers. Am Ind Hyg Assoc J 50(9):466–472.2801514
*Andersen ME, Clewell HJ,III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. In: Harry Salem ed. Animal Test Alternatives 9–25.
*Anderson DJ, Hites RA. 1988. Chlorinated pesticides in indoor air. Environ Sci Technol 22(6):717–720.
*Aprea C, Sciarra G, Sartolli P, . 1994. Biological monitoring of exposure to organophosphorus insecticides by assay of urinary alkylphosphates: influence of protective measures during manual operations with treated plants. Int Arch Occup Environ Health 66:333–338.7896418
*Atkinson R. 1987. A structural-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. Intemat J Chem Kinetics 19:799–828.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*Baker DB, Richards P. 1988. Transport of soluble pesticides through drainage networks in large agricultural river basins. In: Kurtz DA. ed., Long range transport of pesticides. Lewis Publishers, Inc.
*Bakke JE, Feil VJ, Price CE. 1976. Rat urinary metabolites from O,O-diethyl-0(3,5,6-trichloro-2-pyridyl) phosphorothioate. J Environ Sci Health Bull 3:225–230.
*Ballantyne B, Marrs TC. 1992. Clinical and experimental toxicology of organophosphates and carbamates. Buterworth-Heinemann, Ltd., Lindacre House, Jordan Hill Oxford.
*Barcelo D, Lacorte S, Marty JL. 1995. Validation of an enzymatic biosensor with liquid chromatography for pesticide monitoring. Trends In Analytical Chemistry 14(7):334–340.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. U.S. Environmental Protection Agency. Regul Toxicol Pharmacol 8:471–486.3222488
*Barra R, Car-n% J. 1995. A simple method for extraction and gc-ecd analysis of chlorpyrifos from water environmental samples. Journal of High Resolution Chromatography 18(3): 194–195.
*Barron MG, Plakas SM, Wilga PC. 1991. Chlorpyrifos pharmacokinetics and metabolism following intravascular and dietary administration in channel catfish. Toxicol Appl Pharmacol 108(3):474–482.1708533
*Bartele MJ, Kastl PE. 1992. Analysis of 3,5,6-trichloropyridinol in human urine using negative-ion chemical ionization gas chromatography-mass spectrometry. J Chromatogr 575(1):69–74.1517302
*Berry DF, Tomkinson RA, Hetzel GH, . 1993. Application of solid state fermentation techniques to dispose of chlorpyrifos and methachlor. Waste Manage 13(3):271–277.
*Berteau PE, Deen WA. 1978. A comparison of oral and inhalation toxicities of four insecticides to mice and rats. Bull Environ Contam Toxicol 19(1):113–20.75750
*Blanchet DF, St. George A. 1982. Kinetics of chemical degradation of organophosphorus pesticides; hydrolysis of chlorpyrifos and chlorpyrifos-methyl in the presence of copper(II). Pestic Sci 13:85–91.
*Bogus ER, Watschke TL, Mumma RO. 1990. Utilization of solid-phase extraction and reversed-phase and ion-pair chromatography in the analysis of seven agrochemicals in water. J Agric Food Chem 38(1):142–144.
*Bowman BT, Sans WW. 1983. Determination of octanol-water partitioning coefficients (Kow) of 61 organophosphorus and carbamate insecticides and their relationship to respective water solubility (S) values. J Environ Sci Health B18(6):667–683.
*Bowman BT, Sans WW. 1985. Effect of temperature on the water solubility of insecticides. J Environ Sci Health B20(6):625–631.
*Braun HE. 1974. Gas-liquid chromatographic determination of residues of chlorpyriphos and leptophos, including their major metabolites, in vegetable tissue. J Assoc Off Anal Chem 57(1):182–188.4131026
*Braun HE, Frank R. 1980. Organochlorine and organophosphorus insecticides: Their use in eleven agricultural watersheds and their loss to stream waters in southern Ontario, Canada, 19751977. Sci Total Environ 15:169–192.
*Breslin WJ, Liberacki AB, Dittenber DA, . 1996. Evaluation of the developmental and reproductive toxicity of chlorpyrifos in the rat. Fundam Appl Toxicol 29:119–130.8838647
*Brock TCM, van den Bogaert M, Bos AR, . 1992. Fate and effects of the insecticide Dursban 4E indoor Elodea-dominated and macrophyte-free freshwater model ecosystems: II. Secondary effects on community structure. Arch Environ Contam Toxicol 23:391–409.1280070
*Brown RL, Farmer CN, Millar RG. 1987. Optimization of sweep codistillation apparatus for determination of coumaphos and other organophosphorus pesticide residues in animal fat. J Assoc Off Anal Chem 70(3):442–445.3610955
*Bushnell PJ, Pope CN, Padilla S. 1993. Behavioral and neurochemical effects of acute chlorpyrifos in rats: tolerance to prolonged inhibition of cholinesterase. J Pharmacol Exp Ther 266(2):1007–1017.7689099
*Cai CP, Liang M, Wen RR. 1995. Rapid multiresidue screening method for organophosphate pesticides in vegetables. Chromatographia 40(7–8):417–420.
*Capodicasa E, Scapellato ML, Moretto A, . 1991. Chlorpyrifos-induced delayed polyneuropathy. Arch Toxicol 65(2):150–155.1711837
*Carey AE, Kutz FW. 1985. Trends in ambient concentrations of agrochemicals in humans and the environment of the USA. Environ Monit Assess 5(2):155–164.24257992
*CELDs. 1994. Computer-assisted Environmental Legislative Database. University of Illinois at Urbana.
*Chakraborti TK, Farrar JD, Pope CN. 1993. Comparative neurochemical and neurobehavioral effects of repeated chlorpyrifos exposures in young and adult rats. Pharmacol Biochem Behav 46(1):219–224.7504821
*Chambers H, Brown B, Chambers JE. 1990. Noncatalytic detoxication of six organophosphorus compounds by rat liver homogenates. Pestic Biochem Physiol 36(3):308–315.
*Chambers JE, Chambers HW. 1989. Oxidative desulfuration of chlorpyrifos, chlorpyrifos-methyl, and leptophos by rat brain and liver. J Biochem Toxicol 4(3):201–203.2481746
*Chambers JE, Ma T, Boone JS, . 1994. Role of detoxification pathways in acute toxicity levels of phosphorothionate insecticides in the rat. Life Sci 54(18):1357–1364.7514706
*Cheng T, Bodden RM, Puhl RJ, . 1989. Absorption, distribution, and metabolism of [14C]chlorpyrifos applied dermally to goats. J Agric Food Chem 37(4): 1108–111.
*Chiappa S, Padilla S, Koenigsberger C, . 1995. Slow accumulation of acetycholinesterase in rat brain during enzyme inhibition by repeated dosing with chlorpyrifos. Biochem Pharmacol 49(7):955–963.7537966
*Cid Montanes JF, Van Hattum B, Deneer J. 1995. Bioconcentration of chlorpyrifos by the freshwater isopod Asellus aquaticus (L.) in outdoor experimental ditches. Environmental Pollution 88:137–146.15091553
*Cink JH, Coats JR. 1993. Effect of concentration, temperature, and soil moisture on the degradation of chlorpyrifos in an urban iowa soil. In: Racke KD, Leslie AR, eds. Pesticides in Urban Environments. Fate and Significance. ACS Symposium Series 522. American Chemical Society, Washington, DC. 62–69.
*Clabom HV, Hoffman RA, Mann HD, . 1968. Residues of Dursban and its oxygen analog in the body tissues of treated cattle. J Econ Entomol 61(4):983–986.5662009
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations using physiologically-based pharmacokinetic modeling. Toxicol Ind Health 1:111–131.3843496
*Cochran RC, Kishiyama J, Aldous C, . 1995. Chlorpyrifos: Hazard assessment based on a review of the effects of short-term and long-term exposure in animals and humans. Food Chem Toxicol 33(2):165–172.7532610
*Corley RA, Calhoun LL, Dittenber DA, . 1989. Chlorpyrifos: a 13-week nose-only vapor inhalation study in Fischer 344 rats. Fundam Appl Toxicol 13(3):616–618.2482212
*Cartes HJ, Green LS, Campbell RM. 1991. On-line coupling of supercritical fluid extraction with multidimensional microcolumn liquid chromatography/gas chromatography. Anal Chem 63(23):2719–2724.1722652
*Coulston F, Golberg L, Abraham R, . 1972. Final Report on Safety Evaluation and Metabolic Studies on Dow co. 179(IN151). Inst Exp Path01 Toxicol, Albany Medical College.
*Cowgill UM, Gowland RT, Ramirez CA, . 1991. The history of a chlorpyrifos spill: Cartagena, Columbia. Environ Int 17:61–71.
*Currie KL, Mcdonald EC, Chung LTK, . 1990. Concentrations of diazinon, chlorpyrifos, and bendiocarb after application in offices. Am Ind Hyg Assoc J 51(1):23–27.1689096
*Deacon MM, Murray JS, Pilny MK, . 1980. Embryotoxicity and fetotoxicity of orally administered chlorpyrifos in mice. Toxicol Appl Pharmacol 54(1):31–40.6156524
Dieter MP, Garnett J. 1993. Use of F344 rat leukemia transplant model to test the farm chemical pesticides parathion chlorpyrifos and atrazine for potential tumorigenicity 84TH Annual Meeting of the American Association for Cancer Research, Orlando, Florida, USA, May 19-22, Proc. Am Assoc Cancer Res Annu Meet; 34. 173.
*Dillon AP. 1981. Pesticide disposal and detoxification. Processes and techniques. A.P. Dillon, ed. Noyes Data Corporation, Park Ridge, NJ. 375–377, 414–420.
*Dishburger HJ, McKellar RL, Pennington JY, . 1977. Determination of residues of chlorpyrifos, its oxygen analogue, and 3,5,6-trichloro-2-pyridinol in tissues of cattle fed chlorpyrifos. J Agric Food Chem 25(6):1325–1329.72084
*Domine D, Devillers J, Chastrette M, . 1992. Mutivariate structure-property relationships (MSPR) of pesticides. Pestic Sci 35:73–82.
Dow. 1983a. Dursban Insecticide: Assessment of neonatal survival in a two-generation reproduction study in rats. Health and Environmental Sciences-Texas. Dow Chemical USA. Lake Jackson Research Center, Freeport, Texas.
*Dow. 1983b. Acute Inhalation toxicity study in rats exposed to pyrenone Dursban aqueous base. Cosmopolitan Safety Evaluation, Inc. Lafayette, New Jersey. Study #0702C.
*Dow. 1984. Acute Inhalation toxicity study in rats exposed to non-volatile portion of pyrenone-Dursban W.B. pressurized spray. Cosmopolitan Safety Evaluation, Inc. Lafayette, New Jersey. Study #1043C.
*Dow. 1993. Chlorpyrifos: 13-week neurotoxicity study in Fischer 344 rats. The Dow Chemical Company. Health and Environmental Sciences. Midland, Michigan. Study K-044793-094
*Downey JR. 1987. Henry’s Law Constant for chlorpyrifos in water. Dow Elanco, Indianapolis, IN. [unpublished study] (As cited in Racke 1993)
*Dreisbach RH, Robertson WO. 1987. Cholinesterase inhibitor pesticides. In: Handbook of Poisoning: Prevention, Diagnosis & Treatment. Appleton & Lange 110–117.
*Drevenkar V, Stengl B, Froebe Z. 1994. Microanalysis of dialkylphosphorus metabolites of organophosphorus pesticides in human blood by capillary gas chromatography and by phosphorus-selective and ion trap detection. Anal Chim Acta 290(3):277–286.
*Drevenkar V, Vasilic Z, Stengl B, . 1993. Chlorpyrifos metabolites in serum and urine of poisoned persons. Chem Biol Interact 87(1–3):315–322.7688273
*Duggan RE, Corneliussen PE, Duggan MB, . 1983. Pesticide residue levels in foods in the United States from July 1, 1969 to June 30, 1976. In: Residue Monitoring Data. Published jointly by Food and Drug Administration and Association of Official Analytical Chemists. Washington, DC. 15–33.
Ehrich M. Correll L. Veronesi B. 1994. Neuropathy target esterase inhibition by organophosphorus esters in human neuroblastoma cells. Neurotoxicology 15(2):309–314.7991219
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
*El-Sebae AH, Ahmed NS, Soliman SA. 1978. Effect of pre-exposure on acute toxicity of organophosphorus insecticides to white mice. J Environ Sci Health [B] 13(1):11–24.
El-Sebae AH, Soliman SA, Elamayem MA, . 1977. Neurotoxicity of organophosphorus insecticides Leptophos and EPN. J Environ Sci Health [B] 12(4):269–287.
Enan EE, El-Sebae AH, Enan OH, . 1982. In-vivo interaction of some organophosphorus insecticides with different biochemical targets in white rats. J Environ Sci Health [B] 17(5):549–570.
*EPA. 1976a. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.
*EPA. 1976b. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.3.
*EPA. 1978a. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
*EPA. 1978b. Federal Water Pollution Act. Section 311. U.S. Environmental Protection Agency, Washington, DC.
*EPA. 1979. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 186.1000.
*EPA. 1982a. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.1000.
*EPA. 1982b. Determination of the environmental impact of several substitute chemicals in agriculturally affected wetlands. Washington, DC: U.S. Environmental Protection Agency Document No. EPA-600/4-82-052.
*EPA. 1983. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122, App. D.
*EPA. 1984. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 125.
*EPA. 1986a. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
*EPA. 1986b. Clean Water Act. Section 311. U.S. Environmental Protection Agency, Washington, DC.
*EPA. 1986c. Gas chromatography/method 8140. In: Test methods for evaluating solid wastes. SW-846. 3rd ed. Volume 1B: Laboratory manual. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986d. Gas chromatography/mass spectrometry for semivolatile organics: capillary column technique-method 8270. In: Test methods for evaluating solid wastes. SW-846. 3rd ed. Volume 1B: Laboratory manual. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986e. A national pesticide usage data base, summary of report submitted to the office of standards and regulations, U.S. EPA under cooperative agreement CR 811858-01-0 by Resources for the Future, Washington, DC.
*EPA. 1987. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.342.
*EPA. 1988a. Chlorpyrifos. Section 313 of title III. The Emergency Planning and Community Right-to-Know Act of 1986. U.S. Environmental Protection Agency, Washington, DC.
*EPA. 1988b. Chlorpyrifos. In: Pesticide Fact Handbook. U.S. Environmental Protection Agency. Noyes Data Corporation, Park Ridge, NJ. 180–187.
*EPA. 1988c. Method T010: Method for the determination of organochlorine pesticides in ambient air using low volume polyurethane foam (PUF) sampling with gas chromatography/ electron capture detection (GCYECD). In: Winberry WT, Murphy NT, Riggan RM, eds. Compendium of methods for the determination of toxic organic compounds in ambient air. Environmental Monitoring Systems Laboratory, Office of Research and Development, Environmental Protection Agency, Research Triangle Park, NC.
*EPA. 1989. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1990. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA-600/8-90/066A.
*EPA. 1991. Method 507. U.S. Environmental Protection Agency.
*EPA. 1992a. National study of chemical residues in fish. Volume 1. Office of Science and Technology, U.S. Environmental Protection Agency. EPA 823-R-92-008a.
*EPA. 1992b. Method 8141A. In: Test methods for evaluating solid wastes. SW-846. 3rd ed. Volume 1B: Laboratory manual of physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1992c. Method 622. In: Test methods for evaluating solid wastes. SW-846. 3rd ed. Volume1B: Laboratory manual of physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1993a. Environmental Protection Agency. Federal Register. 58 FR 20802.
*EPA. 1993b. Guidance for assessing chemical contamination data for use in fish advisories. Volume 1: Fish sampling and analysis. Office of Water, U.S. Environmental Protection Agency. EPA 823-R-93-002.
*EPA. 1993c. Guidance for assessing chemical contaminant data for use in fish advisories. Volume 1: Fish sampling and analysis. Environmental Protection Agency, Office of Water.
*EPA. 1994. Drinking water regulations and health advisories. Office of Water, U.S. Environmental Protection Agency, Washington, DC.
*EPA. 1995. Drinking water regulations and health advisories. Office of Water, U. S. Environmental Protection Agency.
*EPA. 1997. Review of chlorpyrifos poisoning data. U.S. Environmental Protection Agency, Office of Prevention, Pesticides and Toxic Substances, Washington, D.C. Jan. 14, 1997.
*Erdmann F, Brose C, Schuetz H. 1990. A TLC screening program for 170 commonly used pesticide using the corrected Rf value (Rcf value). Int J Legal Med 104(1):25–32.11453088
*Everett RW. 1982. Effect of Dursban 44 on semen output of Holstein bulls. J Dairy Sci 65(9):1781–1794.6183301
*Farm Chemcials Handbook. 1993. Chlorpyrifos. In: Sine C. ed., Pesticide Dictionary. Farm Chemicals Handbook ‘93. Meister Publishing Co., Willoughby, OH.
*Farm Chemicals Handbook. 1994. Chlorpyrifos. In: Sine C.ed., Pesticide Dictionary. Farm Chemicals Handbook ‘94. Meister Publishing Co., Willoughby, OH. C84.
*FDA. 1990. Residues in foods, 1989 (3rd annual FDA pesticide residue monitoring program report). J Assoc Off Anal Chem 73(5):127A–146A.
*FDA. 1991. Residues in foods, 1990 (4th annual FDA pesticide residue monitoring program report). J Assoc Off Anal Chem 74(5):121A–140A.
*FDA. 1992. Residue monitoring, 1991 (5th annual FDA pesticide residue monitoring program report). J Assoc Off Anal Chem Int 75(5):135A–157A.
*FDA. 1993. Residue monitoring, 1992 (6th annual FDA pesticide residue monitoring program report). J Assoc Off Anal Chem Int 76(5):127A–148A.
*FDA. 1994a. PAM1 method 302. In: Pesticide analytical manual. Vol. 1: Multiresidues methods, 3rd ed. Food and Drug Administration, Public Health Service, U.S. Department of Health and Human Services.
*FDA. 1994b. PAM1 method 304. In: Pesticide analytical manual. Vol. 1: Multiresidues methods, 3rd ed. Food and Drug Administration, Public Health Service, U.S. Department of Health and Human Services.
*FDA. 1995. Pesticide program residue monitoring. Food and Drug Administration. J Assoc Off Anal Chem Int 78(5):119A–142A.
*Felsot AS, Dahm PA. 1979. Sorption of organophosphorus and carbamate insecticides in soil. J Agric Food Chem 27:557–563.
*Felsot AS. 1991. Enhanced biodegradation of soil insecticides in the USA--significance and management. In: Walker A. ed,. British Crop Protection Council Monograph, no. 47. Pesticides in Soils and Water: Current Perspectives. British Crop Protection Council: Famham, England, UK.
*Felsot AS, Pedersen WL. 1990. Pesticidal activity of degradation products. In: Somasundaram L. Coats JR., eds. ACS (American Chemical Society) symposium series, vol. 459. Pesticide Transformation Products: Fate and Significance in the Environment.
*Fendinger NJ, Glotfelty DE. 1990. Hem-y’s law constants for selected pesticides, PAHs and PCBs. Environ Toxicol Chem 9(6):731–736.
*Fenske RA, Black KG, Elkner KP, . 1990. Potential exposure and health risks of infants following indoor residential pesticide applications. Am J Public Health 80(6):689–693. -1693041
Fenske RA, Lu C. 1994. Determination of handwash removal efficiency: Incomplete removal of the pesticide chlorpyrifos from skin by standard handwash techniques. Am Ind Hyg Assoc J 55(5): 425–432.7516116
*Fermanich KJ, Daniel TC. 1991. Pesticide mobility and persistence in microlysimeter soil columns from a tilled and no-tilled plot. J Environ Qual 20(1):195–202.
*Fikes JD, Zachary JF, Parker AJ, . 1992. Clinical, biochemical, electrophysiologic, and histologic assessment of chlorpyrifos induced delayed neuropathy in the cat. Neurotoxicology 13(3):663–678.1282230
*Flach AJ, Donahue ME. 1994. Pet flea and tick collar-induced anisocoria. Arch Ophthalmol 112(5):586.8185512
*Fontaine DD, Teeter D. 1987. Photodegradation of chlorpyrifos in the vapor phase. Rep. GH-C 1911. Dow Chemical U.S.A., Midland, Michigan. [unpublished study] (As cited in Racke 1993)
*Fontaine DD, Wetters JH, Weseloh JW, . 1993. Field dissipation and leaching of chlorpyrifos. Dow Elance, Indianapolis, IN. [unpublished study] (As cited in Racke 1993)
*Francis BM, Metcalf RL, Hansen LG. 1985. Toxicity of organophosphorus esters to laying hens after oral and dermal administration. J Environ Sci Health [B] 20(1):73–95.
*Frank R, Braun HE, Chapman N, . 1991. Degradation of parent compounds of nine USA organophosphorus insecticides in Ontario surface and ground waters under controlled conditions. Bull Environ Contam Toxicol 47(3):374–380.1768951
*Freed VH, Chiou CT, Schmedding DW. 1979. Degradation of selected organophosphate pesticides in water and soil. J Agric Food Chem 27:706–708.
*FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Chemical Communication Subcommittee, Federal State Toxicology and Regulatory Alliance Committee (FSTRAC), U.S. Environmental Protection Agency, Washington, DC.
*Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 14:515–534.5787520
*Gans DA, Kilgore WW, Ito J. 1994. Residues of chlorinated pesticides in processed foods imported into Hawaii from western Pacific Rim countries. Bull Environ Contam Toxicol 52:560–567.8167450
*Gartrell MJ, Craun JC, Podrebarac DS, . 1986. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980- March 1982. J Assoc Off Anal Chem 69(1):146–161.3949687
*Gelardi RC, Mountford MK. 1993. Infant formulas evidence of the absence of pesticide residues. Regul Toxicol Pharmacol 17(2 PART 1):181–192.8484026
*Gerhart BB, Cortes HJ. 1990. Determination of chlorpyrifos in water by large-volume direct aqueous injection capillary gas chromatography. J Chromatogr 503(2):377–384.
*Gianessi LP. 1986. A national pesticide usage data base summary report submitted to the Office of Standards and Regulations. Renewable Resources Division, U.S. Environmental Protection Agency, Washington DC.
*Gillespie AM, Walters SM. 1986. HPLC silica column fractionation of pesticides and PCB from butterfat. J Liq Chromatogr 9(10):2111–2142.
*Gillespie AM, Walters SM. 1989. Semi-preparative reverse phase HPLC fractionation of pesticides from edible fats and oils. J Liq Chromatogr 12(9): 1687–1704.
*Gillespie AM, Walters SM. 1991. Rapid clean-up of fat extracts for organophosphorus pesticide residue determination using carbon-18 solid-phase extraction cartridges. Anal Chim Acta 245(2):259–266.
*Glotfelty DE, Majewski MS, Seiber JN. 1990. Distribution of several organophosphorus insecticides and their oxygen analogues in a foggy atmosphere. Environ Sci Technol 24(3):353–357.
*Glotfelty DE, Seiber JN, Liljedahl LA. 1987. Pesticides in fog. Nature 325:602–605.3808063
*Gollapudi BB, Mendrala AL, Linscombe VA. 1995. Evaluation of the genetic toxicity of the organophosphate insectide chlorpyrifos. Mutat Res 342:25–36.7533892
*Gordon CJ. 1994. Thermoregulatory effects of chlorpyrifos in the rat: long-term changes in cholinergic and noradrenergic sensitivity. Neurotoxicol Teratol 16(1): 1–9.7514260
*Gunderson EL. 1988. Chemical contaminants monitoring: FDA total diet study, April 1982 – April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71(6):1200–1209.3240978
*Haas PJ, Buck WB, Hixon JE, . 1983. Effect of chlorpyrifos on Holstein steers and testosterone-treated Holstein bulls. Am J Vet Res 44(5):879–881.6191601
*Haddad LM, Winchester JF. 1990. Insecticides: Organophosphates and carbamates. In: Haddad LM, Winchester JF. Clinical Management of Poisoning and Drug Overdose. 2nd edition. W. B. Saunders Company.
*Hallberg GR. 1989. Pesticide pollution of groundwater in the humid USA. Agric Ecosyst Environ 26(3–4):299–368.
*Haraguchi K, Kitamura E, Yamshita T, . 1995. Simultaneous determination of trace pesticides in urban precipitation. Atmospheric Environment 29(2):247–253.
*Harris CR, Chapman RA, Tolman JH, . 1988. A comparison of the persistence in a clay loam of single and repeated annual applications of seven granular insecticides used for corn rootworm control. J Environ Sci Health, Part B- Pestic Food Contam Agric Wastes 23(1):1–32.
*Harrison. 1983. Cholinesterase inhibitor insecticides. In: Harrison’s Principles of Internal Medicine. McGraw-Hill, Inc.
*Harrison SA, Watschke TL, Mumma RO, . 1992. Nutrient and pesticide concentrations in water from chemically treated turfgrass. In: Racke KD, Leslie AR., eds. ACS Symposium Series, 522. Pesticides in Urban Environments: Fate and Significance.
*HazDat 1994. Database. Agency for Toxic Substance and Disease Registry (ATSDR), Atlanta Georgia.
*HazDat. 1996. Database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*He F. 1993. Biological Monitoring of Occupational Pesticides Exposure. Int Arch Occup Environ Health 65:S69–S76.8406941
*Hedlund RT. 1973. Bioconcentration of chlorpyrifos by mosquito fish in a flowing system. Dow Elanco, Indianapolis, IN. [unpublished study as cited in Racke 19931
*Helrich K. 1990a. Method 981.03, liquid chromatography method. Chlorpyrifos in pesticide formulations. In: Helrich K., ed. Official Methods of Analysis of the Association of Official Analytical Chemists, 15th ed. Arlington, VA: Association of Analytical Chemists, Inc. 199.
*Helrich K. 1990b. Method 985.22, gas chromatography method. Organochlorine and organophosphorus pesticide residues. In: Helrich K., ed. Official Methods of Analysis of the Association of Official Analytical Chemists, 15th ed. Arlington, VA: Association of Analytical Chemists, Inc. 282–283.
*Hill AS, Skerritt JH, Bushway RJ, . 1994. Development and application of laboratory and field immunoassays for chlorpyrifos in water and soil matrices. J Agric Food Chem 42(9):2051–2058.
*Hill RJ, Head SL, Baker S, . 1995. Pesticide residues in urine of adults living in the United States: reference range concentrations. Envion Res 71(2):99–108.
*Hodgson MJ, Block GD, Parkinson DK. 1986. Organophosphate poisoning in office workers. J Occup Med 28(6):434–437.2425064
*Holstege DM, Scharberg DL, Richardson ER, . 1991. Multiresidue screen for organophosphorus insecticides using gel permeation chromatography - silica gel cleanup. J Assoc Off Anal Chem Int 74(2):394–399.
*Holstege DM, Scharberg DL, Tor ER, . 1994. A rapid multiresidue screen for organophosphorus, organochlorine, and n-methyl carbamate insecticides in plant and animals tissues. J Assoc Off Anal Chem Int 77(5):1263–1274.
*Hooser SB, Beasley VR, Sundberg JP, . 1988. Toxicologic evaluation of chlorpyrifos in cats. Am J Vet Res 49(8):1371–1375.2460000
*Hopper ML. 1991. Analysis of organochlorine pesticide residues using simultaneous injection of two capillary columns with electron capture and electrolytic conductivity detectors. J ASSOC Off Anal Chem 74(6):974–981.1757423
*Hopper ML, King JW. 1991. Enhanced supercritical fluid carbon dioxide extraction of pesticides from foods using pelletized diatomaceous earth. J Assoc Off Anal Chem 74(4):661–666.1917813
*HSDB. 1994. Hazardous Substance Data Bank. National Library of Medicine, National Toxicology Program. Bethesda MD. December 20, 1994.
*HSDB. 1995. Hazardous Substance Data Bank. National Library of Medicine, National Toxicology Program. Bethesda MD.
*Hsu JP, Wheeler HG Jr., Camann DE, . 1988. Analytical methods for detection of nonoccupational exposure to pesticides. J Chromatogr Sci 26: 181–189.3379124
*Huff RA, Corcoran JJ, Anderson JK, . 1994. Chlorpyrifos oxon binds directly to muscarinic receptors and inhibits CAMP accumulation in rat striatum. J Pharmacol Exp Ther 269:329–335.7513360
*Hughes DN, Boyer MG, Papst MH, . 1980. Persistence of three organophosphorus insecticides in artificial ponds and some biological implications. Arch Environ Contam Toxicol 9:269–279.6156660
*Hundley HK, Cairns T, Luke MA, . 1988. Pesticide Residue Findings by the Luke Method in Domestic and Imported Foods and Animal Feeds for Fiscal Years 1982-1986. J Assoc Off Anal Chem 71(5):875–892.3235407
*Hunt LM, Gilbert BN, Schlinke JC. 1969. Rapid gas chromatographic method for analysis of O,O-diethyl-O-3,5,6-trichloro-2-pyridyl phosphorothioate (Dursban) in turkey and chicken tissues. J Agric Food Chem 17(6):1166–1167.
*Inman RD, Kiigemagi U, Deinzer ML. 1981. Determination of chlorpyrifos and 3, 5, 6-trichloro-Zpyridinol residues in peppermint hay and peppermint oil. J Agric Food Chem 29(2):321–323.6164709
*Ioerger BP, Smith JS. 1994. Determination and confirmation of organophosphate pesticides and their metabolites in beef tissue using thermospray/lc-ms. J Agric Food Chem 42(11):2619–2624.
*IRIS. 1994. Integrated Risk Information System (IRIS). Online. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office, Cincinnati, OH.
*IRIS. 1995. Integrated Risk Information System (IRIS). Online. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office, Cincinnati, OH.
*IRPTC. 1989. IRPTC data profile on: chlorpyrifos. International Register of Potentially Toxic Chemicals, United Nations Environment Programme, Geneva, Switzerland. January 1989.
*Ivey MC, Clabom HV. 1968. Dursban oxygen analog: determination in fortified milk and body tissues of cattle. J Assoc Offic Anal Chem 51(6): 1245–1246.
*Ivey MC, Mann HD, Oehler DD, . 1972. Chlorpyrifos and its oxygen analogue: residues in the body tissues of dipped cattle. J Econ Entomol 65(6):1647–1649.4118164
*Ivey MC, Palmer JS. 1981. Chlorpyrifos and 3,5,6-trichloro-2-pyridinol: residues in the body tissues of sheep treated with chlorpyrifos for sheep Ked control. J Econ Entomol 74(2): 136–137.6172455
*Jackson MD, Lewis RG. 1981. Insecticide concentrations in air after application of pest control strips. Bull Environ Contam Toxicol 27(1):122–125.6170370
*Jaggy A, Oliver JE. 1992. Chlorpyrifos toxicosis in two cats. J Vet Int Med 4(3):135–139.
*Jitsunari F, Asakawa F, Nalcajima T, . 1989. Determination of 3,5,6-trichloro-2-pyridinol levels in the urine of termite control workers using chlorpyrifos. Acta Med Okayama 43(5):299–306.2481940
*Johnson MK. 1982. The target for initiation of delayed neurotoxicity by organophosphorus esters: Biochemical studies and toxicological applications. Rev Biochem Toxicol 4:141–212.
*Johnson WE, Fendinger NJ, Plimmer JR. 1991. Solid-phase extraction of pesticides from water: Possible interferences from dissolved organic material. Anal Chem 63(15): 15 10–15 13.
*Joubert J, Joubert PH, van der Spuy M, . 1984. Acute organophosphate poisoning presenting with choreo-athetosis. J Toxicol Clin Toxicol 22: 187–191.6209420
*Judge DN, Mullins DE, Young RW. 1993. High performance thin layer chromatography of several pesticides and their major environmental by-products. J Planar Chromatogr 6(4):300–306.
*Kadoum AM, Mock DE. 1978. Herbicide and insecticide residues in tailwater pits: Water and pit bottom soil from irrigated corn and sorghum fields. J Agric Food Chem 26(1):45–50.621340
*Kaplan JG, Kessler J, Rosenberg N, . 1993. Sensory neuropathy associated with Dursban (chlorpyrifos) exposure. Neurology 43(11):2193–2196.7694187
*Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotox Environ Saf 4:26–38.
*Kenaga EE, Whitney WK, Hardy JL, . 1965. Laboratory tests with Dursban insecticide. J Econ Entomol 58:1043–1050. (As cited in Racke 1993)
*Krill RM, Sonzogni WC. 1986. Chemical monitoring of Wisconsin’s groundwater. Am Water Works Assoc J 78(9):70–75.
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Principles and methods of toxicology. 3rd edition, Wallace Hayes, ed. Raven Press, Ltd. New York. NY.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Toxicology of chemical mixtures, R.S.A. Yang, ed. Academic Press, New York, NY.
*Lacorte S, Molina C, Barcelo D. 1993. Screening of organophosphorus pesticides in environmental matrices by various gas chromatographic techniques. Anal Chim Acta 281(1):71–84.
*Lee SM, Wylie PL. 1991. Comparison of the atomic emission detector to other element-selective detectors for the gas chromatographic analysis of pesticide residues. J Agric Food Chem 39(12):2192–2199.
*Lehotay SJ, Eller KI. 1995. Development of a method of analysis for 46 pesticides in fruits and vegetables by supercritical fluid extraction and gas chromatography/ion trap mass spectrometry. J Aoac Int 78(3):821–830.7756898
Leidy RB, Wright CG. 1991. Trapping efficiency of selected adsorbents for various airborne pesticides. J Environ Sci Health Part B Pestic Food Contam Agric Wastes 26 (4):367–382.
*Leidy RB, Wright CG, Dupree HE, Jr. 1992. Exposure levels to indoor pesticides. In: Racke KD, Leslie AR, eds., Pesticides in Urban environments: Fate and Significance. ACS symposium series, 522. American Chemical Society. Washington, dc. 282–296.
*Leonard RA. 1990. Movement of pesticides into surface waters. In: Cheng HH, ed.SSSA (Soil Science Society of America) Book Series, no. 2. Pesticides in the Soil Environment: Processes, Impacts, and Modeling. Soil Science Society of America, Inc., Madison, WI.
*Leoni V, Caricchia AM, ChiavarinI S. 1992. Multiresidue method for quantitation of organophosphorus pesticides in vegetable and animal foods. J Assoc Off Anal Chem Int 75(3):511–518.
*Leung H. 1993. Physiologically-based pharmacokinetic modeling. General and Applied Toxicology. Vol. I. Ballantine B, Marro T, Turner T, eds. Stockton Press, New York, NY. 53–164.
*Lewis RG, Bond AE, Johnson DE, . 1988. Measurements of atmospheric concentrations of common household pesticides: A pilot study. Environ Monit Assess 10(1):59–74.24248528
*Lewis RG, Fortmann RC, Camann DE. 1994. Evaluation of methods for monitoring the potential exposure of small children to pesticides in the residential environment. Arch Environ Contam Toxicol J 26(1):37–46.
*Line CM, Noronha da Silveira MI. 1994. Chlorpyrifos, ethion, fenitrothion, and methidathion residues in chickens. Bull Environ Contam Toxicol 52(3):425–431.8142715
*Long GG, Scheidt AB, Everson RJ, . 1986. Age related susceptibility of newborn pigs to the cutaneous application of chlorpyrifos. Vet Hum Toxicol 28(4):297–299.2428159
*Lopez-Avila V, Beckert WF, Billets S. 1991. Supercritical fluid extraction and its application to environmental analysis. In: Friedman D., ed. ASTM (American Society for Testing and Materials) Special Technical Publication, 1075. Waste Testing and Quality Assurance, vol. 3. ASTM (American Society for Testing and Materials): Philadelphia, PA. 141–153.
*Lotti M, Moretto A, Zoppellari R, . 1986. Inhibition of lymphocytic neuropathy target esterase predicts the development of organophosphate-induced delayed polyneuropathy. Arch Toxicol 59(3):176–179.2434058
*Luke BG, Richards JC. 1984. Recent advances in cleanup of fats by sweep co-distillation. Part 2: organophosphorus residues. J Assoc Off Anal Chem Int 67:902–904.
*Luke MA, Masumot HT, Cairns T, . 1988. Levels and incidences of pesticide residues in various foods and animal feeds analyzed by the Luke Multiresidue Methodology for fiscal Years 1982-1986. J Assoc Off Anal Chem Int 71(2):415–420.
*Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Handbook of Chemical Property Estimation Methods: Environmental behavior of organic compounds. New York, NY: McGraw-Hill Book Company.
*Lyman WJ, Reehl WF, Rosenblatt DH, eds. 1990. Handbook of Chemical Property Estimation Methods. Environmental behavior of organic compounds. Washington, DC: American Chemical Society, 5-1 – 5-30.
*Ma T, Chambers JE. 1994. Kinetic parameters of desulfuration and dearylation of parathion and chlorpyrifos by rat liver microsomes. Food Chem Toxicol 32(8):763–767.7520881
*Macalady DL, Wolfe NL. 1983. New perspectives on the hydrolytic degradation of the organophosphorothioate insecticide chlorpyrifos. J Agric Food Chem 31: 1139–1147.
*Macek KJ, Walsh DF, Hogan JW, . 1972. Toxicity of the insecticide Dursban to fish and aquatic invertebrete in ponds. Trans Am Fish Sot 3:420–477.
*Maddy KT, Fong HR, Lowe JA, . 1982. A study of well water in selected California communities for residues of 1,3-dichloropropene, chloroallyl alcohol and 49 organophosphate or Chlorinated Hydrocarbon Pesticides. Bull Environ Contam Toxicol 29:354–359.7126926
*Manclus JJ, Montoya A. 1995. Development of immunoassays for the analysis of chlorpyrifos and its major metabolite 3,5,6-trichloro-2-pyridinol in the aquatic environment. Anal Chim Acta 311(3):341–348.
*Mansour SA. 1985. Determination of residues of chlorpyrifos and its oxygen analog in dates. J Pestic SC1 10(4):677–680.
*Mattern GC, Louis JB, Rosen JD. 1991. Multipesticide determination in surface water by gas chromatography/chemical ionization/mass spectrometry/ion trap detection. J Assoc Off Anal Chem Int 74(6):982–986.
*McCall PJ, Oliver GR, McKellar RI.,. 1984. Modeling the runoff potential and behavior of chlorpyrifos in a terrestrial-aquatic watershed. Rep. GH-C 1694. Dow Chemical U.S.A., Midland, Michigan.
*McCall PJ, Swann RL, Bauriedel WR. 1985. Volatility characteristics of chlorpyrifos from soil. Rep. GH-C 1782. Dow Chemical U.S.A., Midland, Michigan.
*McCall PJ, Swann RL, Laskowski DA, . 1980. Estimation of chemical mobility in soil from liquid chromatographic retention times. Bull Environ Contam Toxicol 24: 190–195.7362897
*McCollister SB, Kociba RJ, Humiston CG. . 1974. Studies of the acute and long term oral toxicity of chlorpyrifos (O,O diethyl O (3,5,6 trichloro 2 pyridyl) phosphorothioate) Food Cosmet Toxicol 12(1):(45–61).4142440
*Merck. 1989. Merck index: an encyclopedia of chemicals, drugs, and biologicals. 11th ed. Budavari S, ed. Rahway NJ: Merck & Co., Inc. 2194.
*Mikhail TH, Aggour N, Awadallah R, . 1979. Acute toxicity of organophosphorus and organochlorine insecticides in laboratory animals. Z Ernahrungswiss 18(4):258–268.95070
*Miles J RW, Harris CR, TU CM. 1983. Influence of temperature on the persistence of chlorpyrifos and chlorfenvinphos in sterile and natural mineral and organic soils. J Environ Sci Health, Part B-Pestic Food Contam Agric Wastes 18(6):705–712.
*Miles JRW, Harris CR, Tu CM. 1984. Influence of moisture in the persistence of chlorpyrifos and chlorfenvinphos in sterile and natural mineral and organic soils. J Environ Sci Health Part B 19:237–243.
*Miles JRW, Tu CM, Harris CR. 1979. Persistence of eight organophosporus insecticides in sterile and non-sterile mineral and organic soils. Bull Environ Contam Toxicol 22(3):312–318.465800
*Miles WS, Randall LG. 1992. Supercritical fluid extraction in the analytical laboratory. A technique whose time has come. In: Supercritical Fluid Technology, Theoretical and Applied Approaches to Analytical Chemistry. F. V. Bright and M. E. P. McNally, eds. American Chemical Society, Washington, D.C. 266–287.
*Miller GC, Zepp RG. 1983. Extrapolating photolysis rates from the laboratory to the environment. Residue Rev 85:89–110. (As cited in Racke 1993)
*Minnaard WA, Slobodnik J, Vreuls JJ, . 1995. Rapid liquid chromatographic screening of organic micropollutants in aqueous samples using a single short column for trace enrichment and separation. J Chromatogr 696(2):333–340.
*Minyard JP Jr., Roberts WE. 1991. State findings on pesticide residues in foods: 1988 and 1989. J Assoc Off Anal Chem Int 74(3):438–452.
Miyazaki S, Hodgson GC. 1972. Chronic toxicity of Dursban and its metabolite 3,5,6-trichloro-2-pyridynol in chickens. Toxicol Appl Pharmacol 23:391–398.4117467
*Moser VC. 1995. Comparisons of the acute effects of cholinesterase inhibitors using a neurobehavioral screening battery in rats. Neurotoxicol and Teratol 17(6):617–625.
*Moye HA, Malagodi MH. 1987. Levels of airborne chlordane and chlorpyrifos in two plenum houses: Saranex S-15 as a vapor barrier. Bull Environ Contam Toxicol 39(3):533–540.2444294
*Mulla MS, Norland RL, Westlake WE, . 1973. Aquatic midge larvicides: their efficacy and residues in water, soil, and fish in a warm water lake. Environ Entomol 258–65.
*Muto MA, Lobelle F Jr., Bidanset JH, . 1992. Embryotoxicity and neurotoxicity in rats associated with prenatal exposure to DURSBAN. Vet Hum Toxicol 34(6):498–501.1283795
*Nakamura Y, Tonogai Y, Sekiguchi Y, . 1994. Multresidue analysis of 48 pesticides in agricultural products by capillary gas chromatography. J Agric Food Chem 42(11):2508–2518.
*Nam KS, King JW. 1994. Coupled sfe-sfc-gc for the trace analysis of pesticide residues in fatty food samples. Journal of High Resolution Chromatography 17(8):577–582.
*Namba T, Nolte CT, Jackrel JJ, . 1971. Poisoning due to organophosphate insecticides. Acute and chronic manifestations. Amer J Med 50:475–492.4324629
*NAS/NC. 1982. An assessment of the health risks of 7 pesticides used for termite control. Prepared by the Committee on Toxicology, a Board on Toxicology and Environmental Health Hazards. National Research Council. National Academy Press, Washington, DC.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*NATICH. 1992. NATICH data base report of federal, state, and local air toxics activities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, National Air Toxics Information Clearinghouse. EPA-453\R-92-008.
*Nelson MC, Jalal SM, Larson OR. 1990. Genotoxicity of the organophosphorus insecticide chlorpyrifos based on human lymphocyte culture. Cytologia (TOKYO) 55(4):588–592.
*NIOSH. 1992. Recommendations for occupational safety and health. Compendium of policy documents and statements. U.S. Department of Health and Human Services, National Institute of Occupational Safety and Health, Cincinnati, OH. Section B, 63.
*NIOSH. 1994. Manual of analytical methods(NMAM), fourth edition, Method 5600, organophosphorus pesticides. U. S. Department of Health and Human Services.
*NIOSH. 1994. Recommendations for occupational safety and health. Compendium of policy documents and statements. U.S. Department of Health and Human Services, National Institute of Occupational Safety and Health, Cincinnati, OH.
*NOES. 1994. Numbers of potentially exposed employees. National Occupational Exposure Survey. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, OH.
*Nolan RJ, Rick DL, Freshour NL, . 1984. Chlorpyrifos: pharmacokinetics in human volunteers. Toxicol Appl Pharmacol 73(1):8–15.6200956
*Odenkirchen EW, Eisler R. 1988. Chlorpyrifos hazards to fish, wildlife, and invertebretes: A synoptic review. Contaminant Hazards Reviews, report no. 13. Biological report 85(1 .13). U.S. Fish and Wildlife Service, U.S. Department of the Interior.
*Oliver GR, McKellar RL, Woodburn KB, . 1987. Field dissipation and leaching study for chlorpyrifos in Florida citrus. Rep. GH-C 1870. Dow Chemical U.S.A., Midland, Michigan.
*OSHA. 1986. Method 62. In: Manual of methods. Organic Methods Evaluation Branch, OSHA Analytical Laboratory, Occupational Safety and Health Administration, Salt Lake City, UT.
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Office of Technology, Washington, DC. OTB-BA-438.
Palmer JS, Rowe LD, Crookshank HR. Aug 1980. Effect of age on tolerance of calves to chlorpyrifos. Am J Vet Res 41(8):1323–1325.6160793
*Patnaik KK, Tripathy NK. 1992. Farm-grade chlorpyrifos (Durmet) is genotoxic in somatic and germ-line cells of Drosophila. Mutat Res 279(1):15–20.1374528
*Pence BC, Demick DS, Richard BC, . 1991. The efficacy and safety of chlorpyrifos (Dursban) for control of Myobia musculi infestation in mice. Lab Anim Sci 41(2):139–142.1719272
*Pionke HB, Glotfelty DE. 1989. Nature and extent of groundwater contamination by pesticides in an agricultural watershed. Water Res 23(8):1031–1037.
*Pionke HB, Glotfelty DE, Lucas AD, . 1988. Pesticide contamination of groundwaters in the Mahantango creek watershed Pennsylvania USA. J Environ Qual 17(1):76–84.
*Plimmer JR. 1992. Dissipation of pesticides in the environment. In: Schnoor JL, ed., Fate of Pesticides and Chemicals in the Environment. John Wiley & Sons, Inc. New York, NY. 79–90.
Pope C, Chaudhuri J, Chakraborti T, . 1993. Up-regulation of muscarinic receptors in rat brain by the organophosphate (OP) insecticide chlorpyrifos (CPF). 23rd annual meeting of the Society for Neuroscience, Washington, D.C., USA, Society for Neuroscience Abstracts 19(1–3):429.
*Pope CN, Chakraborti TK. 1992. Dose-related inhibition of brain and plasma cholinesterase in neonatal and adult rats following sublethal organophosphate exposures. Toxicology 73(1):35–43.1375401
*Pope CN, Chakraborti TK, Chapman ML, . 1991. Comparison of in vivo cholinesterase inhibition in neonatal and adult rats by three organophosphorothioate insecticides. Toxicology 68(1):%–61.
*Pope CN, Chakraborti TK, Chapman ML, . 1992. Long-term neurochemical and behavioral effects induced by acute chlorpyrifos treatment. Pharmacol Biochem Behav 42(2):251–256.1378635
*Racke KD. 1992. Degradation of organophosphorus insecticides in environmental matrices. In: Organophosphates: Chemistry, Fate and Effects. Academic Press, 47–78
*Racke KD. 1993. Environmental fate of chlorpyrifos. Rev Environ Contam Toxicol 131: 1–150.7678349
*Racke KD, Coats JR. 1988. Comparative degradation of organophosphorus insecticides in soil: Specificity of enhanced microbial degradation. J Agric Food Chem 36:193–199. (As cited in Racke 1993).
*Racke KD, Coats JR. 1990. Enhanced biodegradation of insecticides in Midwestern corn soils. In: Racke KD, Coats JR. eds., Enhanced Biodegradation of Pesticides in the Environment. ACS Symposium Series 426. American Chemical Society, Washington, DC. 68–81.
*Racke KD, Coats JR, Titus KR. 1988. Degradation of chlorpyrifos and its hydrolysis product 3,5,6-trichloro-2-pyridinol in soil. J Environ Sci Health B23(6):527–54
*Racke KD, Kesterson AL, Jackson SB. 1991. Laboratory volatility of chlorpyrifos from soil. Dow Elanco, Indianapolis, IN. (unpublished study as cited in Racke 1993)
*Racke KD, Robbins ST. 1990. Factors affecting the degradation of 3 5 6 trichloro-2-pyridinol in soil. In: Somasundaram L, Coats JR Jr., ed. ACS (American Chemical Society) Symposium Series, vol. 459. Pesticide Transformation Products: Fate and Significance in the Environment.
*Richards RP, Baker DB. 1993. Pesticide concentration patterns in agricultural drainage networks in the Lake Erie basin. Environ Toxicol Chem 12(1): 13–26.
*Richardson RJ. 1995. Assessment of the neurotoxic potential of chlorpyrifos relative to other organophosphorus compounds: A critical review of the literature. J Toxicol Environ Health 44:135–165.7531775
*Richardson RJ, Moore TB, Kayyali US, . 1993a. Inhibition of hen brain acetychlinesterase and neurotoxic esterase by chlorpyrifos in vivo and kinetics of inhibition by chlopyrifos oxon in vitro: Applications to assessment of neuropathic risk. Fund Applied Toxicol 20:273–279.
*Richardson RJ, Moore TB, Kayyali US, . 1993b. Chlorpyrifos: Assessment of potential for delayed neurotoxicity by repeated dosing in adult hens with monitoring of brain acetycholinesterase, brain and lymphocyte neurotoxic esterase, and plasma butyrycholinesterase activities. Fund Appl Toxicol 21:89–96.
*Rigterink RH. 1966. O-pyridyl phosphates and phosphorothioates. U.S. Patent No. 3,244,586. (as cited in Racke 1993)
*Robinson JC, Pease WS, Albright DS, . 1994. Pesticides in the home and community: Health risks and policy alternatives. California Policy Seminar Report, Center for Occupational and Environmental Health, School of Public Health, University of California, Berkeley.
*Rouchaud J, Gustin F, Van de Steene F. 1991. Transport of the insecticides chlorpyrifos, chlorfenvinphos, carbonfuran, carbonsulfan, and furathiocarb from soil into the foilage of cauliflower and brussels sprouts plants grown in the field. Toxicol Environ Chem 30(1/2):79.
*Schattenberg HJ III, Hsu J-P. 1992. Pesticide residue survey of produce from 1989 to 1991. J Assoc Off Anal Chem Int 75(5):925–933.
*Schimmel SC, Gamas RL, Patrick JM Jr., . 1983. Acute toxicity, bioconcentration, and persistence of AC 222,705, benthiocarb, chlorpyrifos, fenvalerate, methyl parathion, and permethrin in the estuarine environment. J Agric Food Chem 31(1):104–113.6681821
*Schroeder WH, Lane DA. 1988. The fate of toxic airborne pollutants. Environ Sci Technol 22:240–246.22288853
*Selden BS, Curry SC. 1987. Prolonged succinylcholine-induced paralysis in organophosphate insecticide poisoning. Ann Emerg Med 16(2):215–217.2432808
*Shah PV, Fisher HL, Sumler MR, . 1987. Comparison of the penetration of 14 pesticides through the skin of young and adult rats. J Toxicol Environ Health 21(3):353–366.3586065
*Shah PV, Monroe RJ, Guthrie FE. 1981. Comparative rates of dermal penetration of insecticides in mice. Toxicol Appl Pharmacol 59(3):414–423.6791307
*Sherma J, Slobodien R. 1984. Determination of chlorpyrifos and its metabolite 3,5,6-trichloro-2-pyridinol in tap water and bananas by quantitative TLC on preadsorbent silica gel. J Liq Chromatogr 7(14):2735–2742.
*Sherman JD. 1995. Organophosphate pesticides--Neurological and respiratory toxicity. Toxicol Indust Health 11 (1):33–39.
*Sittig M. 1980. Pesticide manufacturing and toxic materials control encyclopedia. M. Sittig, ed. Noyes Data Corporation, Park Ridge, NJ. 199–202.
*Sittig M. 1994. World-wide limits for toxic and hazardous chemicals in air, water and soil. Noyes Data Corporation, Park Ridge, NJ.
*Sittig M, ed. 1985. Handbook of Toxic and Hazardous Chemicals and Carcinogens. Park Ridge, NJ: Noyes Data Corporation.
*Smith GN, Watson BS, Fischer FS. 1967. Investigations on dursban insecticide: Metabolism of [36Cl] O,O-diethyl-O- 3,5,6-trichloro-2-pyridyl phosphorothioate in rats. J Agric Food Chem 15:132–138.
*Smith JL, Rust MK. 1992. Activity and water-induced movement of termiticides in soil. J Econ Entomol 85(2):430–434.
*Sobti RC, Krishan A, Pfaffenberger CD. 1982. Cytokinetic and cytogenetic effects of some agricultural chemicals on human lymphoid cells in vitro: organophosphates. Mutat Res 102(1):89–102.6981766
*Somasundaram L, Coats JR, Racke KD. 1989. Degradation of pesticides in soil as influenced by the presence of hydrolysis metaboiltes. J Environ Sci Health, Part B- Pestic Food Contamin Agric 24(5):457–478.
*SRC. 1994. Syraucse Research Center. Henry’s Law Constant Program (Henrywin, version 2.50, serial H0142). Chemical Hazard Assessment Divsion, Enviommental Chemistry Center, Syracuse, NY.
*SRC. 1995. Syracuse Research Center. Atmospheric Research Center. Atmospheric Oxidation Program (AOPWIN, version 1.65, serial 0156). Chemical hazard assessment division, Environmental Chemistry Center, Syracuse, NY.
*SRI. 1994. Stanford Research Institute International. Directory of chemical producers: United States of America. Menlo Park, Ca: SRI International, 801.
*SRI. 1995. Stanford Research Institute International. Directory of chemical producers: United States of America. Menlo Park, Ca: SRI International.
*Stamper JH, Nigg HN, Mahon WD, . 1989. Pesticide exposure to greenhouse handgunners. Arch Environ Contam Toxicol 18(4):515–529.2774669
*Stan H-J, Heil S. 1991. Two-dimensional capillary gas chromatography with three selective detectors as a valuable tool in residue analysis: State-of-the-art. Fresenius’ J Anal Chem 339 (1):34–39.
*Stan H-J, Kellner G. 1989. Confirmation of organophosphorus pesticide residues in food applying gas chromatography-mass spectrometry with chemical ionization and pulsed positive negative detection. Biomed Environ Mass Spectrom 18(9):645–651.
*Stanton ME, Mundy WR, Ward T, . 1994. Time-dependent effects of acute chlorpyrifos administration on spatial delayed alternation and cholinergic neurochemistry in weanling rats. Neurotoxicology 15(1):201–208.7522308
Sultatos LG. 1988. Factors affecting the hepatic biotransformation of the phosphorothioate pesticide chlorpyrifos. Toxicology 51: 191–200.2459806
*Sultatos LG. 1991. Metabolic activation of the organophosphorus insecticides chlorpyrifos and fenitrothion by perfused rat liver. Toxicology 68(1):1–9.1714638
*Sultatos LG, Costa LG, Murphy SD. 1982. Factors involved in the differential acute toxicity of the insecticides chlorpyrifos and methyl chlorpyrifos in mice. Toxicol Appl Pharmacol 65(1): 144–152.6183791
*Sultatos LG, Minor LD, Murphy SD. 1985. Metabolic activation of phosphorothioate pesticides: role of the liver. J Pharmacol Exp Ther 232(3):624–628.2579231
*Sultatos LG, Murphy SD. 1983a. Kinetic analyses of the microsomal biotransformation of the phosphorothioate insecticides chlorpyrifos and parathion. Fundam Appl Toxicol 3(1): 16–21.6193025
*Sultatos LG, Murphy SD. 1983b. Hepatic microsomal detoxification of the organophosphates paraoxon and chlorpyrifos oxon in the mouse. Drug Metab Dispos Biol Fate Chem 11(3):232–238.6191937
*Suntio LR, Shiu WY, Mackay D, . 1987. A critical review of Henry’s constants for pesticides. Rev Environ Contam Toxicol 103:1–59.
*Szeto SY, Mackemzie JR, Vernon RS. 1988. Comparative persistence of chlorpyrifos in a mineral soil after granular and drench applications. J Environ Sci Health, Part B- Pestic Food Contam Agric Wastes 23(6):541–558.
*Takamiya K. 1994. Monitoring of urinary alkyl phosphates in pest control operators exposed to various organophosphorus insecticides. Bull Environ Contam Toxicol 52(2):190–195.8123977
*Thier H-P, Zeumer H. 1987a. Method S8: Organochlorine, organophosphorus and triazine compounds. In: Manual of Pesticide Residue Analysis, VOL. 1. VCH Publishers, INC.,-New York, NY 283–295.
*Thier H-P, Zeumer H. 1987b. Method S19, Organochlorine, organophosphorus, nitrogen-containing and other compounds. In: Manual of Pesticide Residue Analysis, VOL. 1. VCH Publishers, INC., New York. NY 384–400.
*Thrasher JD, Madison R, Broughton A. 1993. Immunologic abnormalities in humans exposed to chlorpyrifos: Preliminary observations. Arch Environ Health 48(2):89–93.7682805
*Tilio R, Krishnan K, Kapila S, . 1994. A simple analytical methodology for multiresidue pollutant determinations. Chemosphere 29(9–11):1849–1858.
*Trotter WJ, Dickerson R. 1993. Pesticide residues in cornposited milk collected through the U.S. Pasteurized Milk Network. J Assoc Off Anal Chem Int 76(6): 1220–1225.
*Vaccaro JR. 1993. Risks associated with exposure to chlorpyrifos and chloropyrifos formulation components. In: Racke KD, Leslie AR, Eds., Pesticides in urban Environments: Fate and Significance; ACS Symposium Series, 522. American Chemical 297–306.
*Valsaraj KT, Thoma GJ, Reible DD, . 1993. On the enrichment of hydrophobic organic compounds in fog droplets. Atmos Environ, Part A- Gen Top 27(2):203–210.
*Van Beelen P, Fleuren-Kemila AK. 1993. Toxic effects of pentachlorophenol and other pollutants on the mineralization of acetate in several soils. Ecotoxicol Environ Saf 26(1):10–17.7691530
*Van Beelen P, Van Vlaardingen P LA, Fleuren-Kemila AK. 1994. Toxic effects of pollutants on the mineralization of chloroform in river sediments. Ecotox Environ Saf 27(2):158–167.
*Vasilic Z, Drevenkar V, Rumenjak V, . 1992. Urinary excretion of diethylphosphorus metabolites in persons poisoned by quinalphos or chlorpyrifos. Arch Environ Contam Toxicol 22(4):351–357.1375016
*Verschueren K. 1983. Chlorfpyrifos. In: Verschueren K., ed., Handbook of Environmental Data on Organic Chemicals. Second edition. Van Nostrand Reinhold Co. New York, NY 391.
Vodela JK, Patil RD, Whittiker MB, . 1994. Comparative toxicity of chlorpyrifos in rats and chickens Experimental Biology 94, Parts I and II, Anaheim, California. FASEB Journal 8(4–5):A407.
*Waite DT, Grover R, Westcott ND, . 1992. Pesticides in ground water, surface water and spring runoff in a small Saskatchewan watershed. Environ Toxicol Chem 11(6):741–748.
*Walia S, Dureja P, Mukerjee SK. 1988. New photodegradation products of chlorpyrifos and their detection on glass, soil, and leaf surfaces. Arch Environ Contam Toxicol 17(2):183–188.
*Walker WW, Cripe CR, Pritchard PH, . 1988. Biological and abiotic degradation of xenobiotic compounds in in vitro estuarine water and sediment-water systems. Chemosphere 17(12):2255–2270.
*Walters SM. 1990. Clean-up techniques for pesticides in fatty foods. Anal Chim Act% 236(1):77–82.
*Watschke TL, Mumma RO. 1989. The effect of nutrients and pesticides applied to turf on the quality of runoff and percolating water. Environmental Resources Research Institute report ER 8904, Pennsylvania State University, University Park, PA.
*Welling W, de Vries JW. 1992. Bioconcentration kinetics of the organophosphorus insecticide chlorpyrifos in guppies (Poecilies reticulate). Ecotoxicol Environ Saf 23:64–75. (As cited in Racke 1993)1375149
*Whang JM, Schomburg CJ, Glotfelty DE, . 1993. Volatilization of fonofos, chlorpyrifos, and atrazine from conventional and no-till surface soils in the field. J Environ Qual 22(1):173–180.
*Whitmore RW, Immerman FW, Camann DE, . 1994. Non-occupational exposures to pesticides for residents of two U.S. cities. Arch Environ Contam Toxicol 26(1):47–59.8110023
*Whitney . 1995. Development neurotoxicity of chlorpyrifos: cellular mechanisms. Toxicol Appl Pharmacol 13453–62.
*WHO. 1975. Chemical and biochemical methodology for the assessment of hazards of pesticides for man. Report of a WHO scientific group. WHO Technical Report Series no.560. World Health Organization, Geneva, Switzerland.
*Winterlin W, Seiber JN, Craigmill A, . 1989. Degradation of pesticide waste taken from a highly contaminated soil evaporation pit in California USA. Arch Environ Contam Toxicol 18(5):734–747.
*Wolfe NL. 1988. Abiotic transformations of toxic organic chemicals in the liquid phase and sediments. In: Media. Z. Gerstl . eds Ecological studies, vol. 73. Toxic organic chemicals in porous. Springer-Verlag: Berlin, West Germany 136–147.
*Woodruff RC, Phillips JP, Irwin D. 1983. Pesticide-induced complete and partial chromosome loss in screens with repair-defective females of Drosophila melanogaster. Environ Mutagen 5(6):835–846.6418539
*Worthing CR. 1987. The pesticide manual. A world compendium. Seventh edition. C.R. Worthing, ed. The British Crop Protection Council. 3050.
*Wright CG, Leidy RB. 1980. Insecticide residues in the air of buildings and pest control vehicles. Bull Environ Contam Toxicol 24(4):582–589.6155163
*Wright CG, Leidy RB, Dupree HE. 1991. Chlorpyrifos in the air and soil of houses four years after its application for termite control. Bull Environ Contam Toxicol 46:686–689. (as cited in Racke 1993)1710157
*Wright CG, Leidy RB, Dupree HE JR. 1988. Chlorpyrifos in the ambient air of houses treated for termites. Bull Environ Contam Toxicol 40(4):561–568.2453238
*Wright CG, Leidy RB, Dupree HE, JR. 1994. Chlorpyrifos in the air and soil of houses eight years after its application of termite control. Bull Environ Contam Toxicol 52(1):131–134.7510550
*Yamano T, Morita S. 1993. Effects of pesticides on isolated rat hepatocytes, mitochondria, and microsomes. Arch Environ Contam Toxicol 25(2):271–278.8368870
*Yess NJ, Houston MG, Gunderson EL. 1991a. Food and Drug Administration Pesticide Residue Monitoring of Foods: 1978-1982. J Off Anal Chem 74(2):265–272.
*Yess NJ, Houston MG, Gunderson EL. 1991b. Food and Drug Administration Pesticide Residue Monitoring of Foods: 1983-1986. J Off Anal Chem 74(2):273–280.
*Zabik JM, Seiber JN. 1993. Atmospheric transport of organophosphate pesticides from California’s Central Valley to the Sierra Nevada mountains. J Environ Qual 22(1):80–90.