# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding chlorpyrifos in air, water, and other media are summarized in Table 7-1.

ATSDR has derived a Minimal Risk Level (MRL) of 0.003 mg/kg/day for both acute (14 days or less) and intermediate (15-364 days) duration oral exposure to chlorpyrifos, based on a NOAEL of 0.03 mg/kg/day observed in human adult males exposed orally to chlorpyrifos (Coulston et al. 1972). An uncertainty factor of 10 was used in the calculation of the MRL to account for variability in susceptibility within the human population.

ATSDR has derived a chronic-duration oral MRL of 0.001 mg/kg/day, based on a NOAEL for acetylcholinesterase inhibition in rats exposed to 0.1 mg/kg/day chlorpyrifos in feed for 2 years (McCollister et al. 1974). An uncertainty factor of 100 was used in the calculation of the MRL: 10 for extrapolation from animals to humans and 10 for variability within the human population.

The U.S. EPA oral reference dose for chlorpyrifos is 3×10^−3^ mg/kg/day (IRIS 1994). No inhalation reference concentration exists for this compound.

Chlorpyrifos is one of the chemicals regulated under “The Emergency Planning and Community Rightto-Know Act of 1986” (EPCRA) (EPA 1988a). Section 313 of Title III of EPCRA requires owners and operators of certain facilities that manufacture, import, process, or otherwise use the chemicals on this list to report annually their release of those chemicals to any environmental media.

An Occupational Safety and Health Administration (OSHA) permissible exposure limit (PEL) for chlorpyrifos has not been set.

Chlorpyrifos is designated a hazardous substance and subject to regulations implementing Section 311 of the Federal Water Pollution Act (EPA 1978b) and Section 311 of the Clean Water Act (EPA 1986b). A maximum contaminant level in (MCL) drinking water does not exist.

Tolerances for chlorpyrifos in raw agricultural commodities, foods, and animal feeds have been established by EPA (EPA 1987, 1982, 1979) ranging from 0.05 to 25 ppm.

Table 7-1 Regulations and Guidelines Applicable to Chlorpyrifos

Agency | | Description | Information | References
[underlined: INTERNATIONAL]
Guidelines:
| WHO | Drinking-water guideline values for health-related organics | None | WHO 1984
[underlined: NATIONAL]
Regulations:
a. | Water
a. | EPA OW | Designation of Hazardous Substances | Yes | 40 CFR 116.4; EPA 1978a
a. | EPA OW | Reportable Quantities of Hazardous Substances Pursuant to the Clean Water Act | 1 lbs. | 40 CFR 117.3; EPA 1986a
a. | EPA OW | National Pollutant Discharge Elimination System (NPDES) -- List of Toxic Pollutants and Hazardous Substances | Yes | 40 CFR 122, App. D; EPA 1993a
a. | EPA OW | Instructions -- Form 2c, NPDES Criteria and Standards | Yes | 40 CFR 125; EPA 1984
a. | EPA OW | Proposed Rule: Water Quality Guidance for the Great Lakes System | Yes | 58 FR 20802; EPA 1993b
b. | Food:
b. | EPA OPTS | Tolerances for Related Pesticide Chemicals | Yes | 40 CFR 180.3; EPA 1976b
b. | EPA OPTS | Tolerance Range for Agriculture Products | 0.05–15.0 ppm | 40 CFR 180.342; EPA 1987
b. | EPA OPTS | Listing of Pesticide Chemicals | Yes | 40 CFR 180; EPA 1976a
b. | EPA OPTS | Tolerance in Food: | Yes | 40 CFR 185.1000; EPA 1982a
b. | EPA OPTS | Citrus Oil | 25 ppm | 40 CFR 185.1000; EPA 1982a
b. | EPA OPTS | Corn Oil | 3.0 ppm | 40 CFR 185.1000; EPA 1982a
b. | EPA OPTS | Mint Oil | 10.0 ppm | 40 CFR 185.1000; EPA 1982a
b. | EPA OPTS | Peanut Oil | 1.5 ppm | 40 CFR 185.1000; EPA 1982a
b. | EPA OPTS | Tolerance Range in Animal Feeds | 0.5–15.0 ppm | 40 CFR 186.1000] EPA 1979
c. | Other
c. | EPA OERR | Reportable Quantity | 1 lb. | 40 CFR 302.4; EPA 1989
Guidelines:
a. | Air:
a. | ACGIH | Threshold Limit Value for Occupational Exposure (TLV-TWA) | 0.90 mg/m^3^ (skin) | ACGIH 1-994
a. | NIOSH | Recommended Exposure Limit for Occupational Exposure (TWA) | 0.2 mg/m^3^ | NIOSH 1992
a. | NIOSH | Recommended Exposure Limit for Occupational Exposure (STEL) | 0.6 mg/m^3^ | NIOSH 1992
NRC | | Recommended maximum air concentration in residential houses | 10 μg/m^3^ | NAS/NRC 1982
b. | Water:
b. | EPA OW | 1-d Health Advisory | 0.03 mg/L (child) | EPA 1994
b. | EPA OW | 10-d Health Advisory | 0.03 mg/L (child) | EPA 1994
b. | EPA OW | Lifetime Health Advisory | 0.02 mg/L | EPA 1994
b. | EPA OW | Longer-term Health | 0.03 mg/L (child; 0.1 mg/L (adult) | EPA 1994
b. | EPA OW | Drinking water cancer classification | D (not assigned) | EPA 1995
c. | Other
c. | EPA | RfD | 3×10^−3^ mg/kg/day | IRIS 1997
[underlined: STATE]
Regulations and Guidelines:
a. | Air: | Average Acceptable Ambient Air Concentrations | | NATICH 1992
a. | CT | 8-hour | 4.00 μg/m^3^
a. | FL-Pinella | 8-hour | 2.00 μg/m^3^
a. | FL-Pinella | 24-hour | 0.48 μg/m^3^
a. | ND | 8-hour | 0.002 mg/m^3^
a. | ND | 1-hour | 0.006 mg/m^3^
a. | NV | 8-hour | 0.005 mg/m^3^
a. | TX | 30-minutes | 2.00 μg/m^3^
a. | TX | Annual | 0.20 μg/m^3^
a. | VA | Annual | 3.30 μg/m^3^
a. | WA-SWEST | 24-hour | 0.70 μg/m^3^
b. | Water: | [underlined: Water Quality: Human Health] | | FSTRAC 1990
b. | VT | Drinking Water Standard | 21 μg/L
b. | AR | [underlined: Water Quality Criteria: Human Health] | | CELDs 1994
b. | AR | Toxic Substances - Chronic Toxicity 4-day avg | 0.041 μg/L
b. | AR | Toxic Substances - Acute Toxicity - 1-hr avg | 0.083 μg/L
b. | HI | Toxic Substances Applicable to All Waters
b. | HI | Fresh water acute | 0.083 μg/L
b. | HI | Fresh water chronic | 0.041 μg/L
b. | HI | Saltwater acute | 0.011 μg/L
b. | HI | Saltwater chronic | 0.0056 μg/L
b. | HI | Fish consumption | NS
b. | | [underlined: Water Quality Criteria: Aquatic Life] | | CELDs 1994
b. | CO | Aquatic Life Segments Organic Compounds to Second Power
b. | CO | Standard acute | 0.083 μg/L
b. | CO | Standard chronic | 0.041 μg/L
b. | PR | Maximum Allowable Conc. for Organothiophosphorus and Other Non-Persistent Pesticides
b. | PR | Coastal estuaries | 0.0056 μg/L
b. | PR | Surface waters | 0.41 μg/L
b. | PR | Groundwaters | 0.041 μg/L
b. | OK | Numeric Criteria for Toxic Substances to Protect Fish and Wildlife
b. | OK | Acute | .083 μg/L
b. | OK | Chronic | .041 μg/L
b. | VT | WQ Criteria for Protection of Aquatic - Biota
b. | VT | Acute | .083 μg/L
b. | VT | Chronic | .041 μg/L
b. | | [underlined: Restricted Pesticides]
b. | NJ | | All conc. above 15% | CELDs 1994

ACGIH = American Conference of Governmental Industrial Hygienists; CELDs = Computer-assisted Environmental Legislative Database; EPA = Environmental Protection Agency; FSTRAC = Federal State Toxicology and Regulatory Alliance Committee; IRIS = Integrated Risk Information System; NATICH = National Air Toxics Information Clearinghouse; NIOSH = National Institute of Occupational Safety and Health; NPDES = National Pollutant Discharge Elimination System; RfD = Reference Dose; STEL = Short-term Exposure Limit; TLV = Threshold Limit Value; TWA = Time Weighted Average