# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of chlorpyrifos is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of chlorpyrifos is located in Table 3-2.

Table 3-1 Chemical Identity of Chlorpyrifos

Characteristic | Information | Reference
Chemical name | O,O-diethyl O-(3,5,6-trichloro-2-pyridyl) phosphorothioate | Merck 1989
Synonym(s) | Phosphorothioic acid O,O-diethyl O-(3,5,6-trichloro-2-pyridinyl) ester; chlorpyrifos-ethyl; chlorpyriphos | Merck 1989
Registered trade name(s) | Dowco 179; ENT 27311; Dursban; Lorsban; Pyrinex; DMS-0971 | Merck 1989
Chemical formula | C_9_H_11_CI_3_NO_3_PS | Merck 1989
Chemical structure | [image] | Merck 1989
Identification numbers:
CAS Registry | 2921–88–2 | Merck 1989
NIOSH RTECS | TF6300000 | HSDB 1994
EPA Hazardous Waste | 059101 | HSDB 1994
OHM/TADS | 7800025 | HSDB 1994
DOT/UN/NA/IMCO | NA 2783 Chlorpyrifos | HSDB 1994
HSDB | 389 | HSDB 1994
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of Chlorpyrifos

Property | Information | Reference
Molecular weight | 350.57 | Merck 1989
Color | White granular crystals | Merck 1989
Color | White to tan | EPA 1988
Color | Amber solid cake with amber oil | Verschueren 1983
Color | Colorless crystals | Worthing 1987
Physical state | Crystalline solid | EPA 1988
Melting point | 41–42 °C | Merck 1989
Boiling point | Decomposes at approximately 160 °C | Verschueren 1983
Density at 43.5 °C | 1.398 g/cm^3^ | Verschueren 1983
Odor | Mild mercaptan | EPA 1988
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20 °C | 0.7 mg/L | Bowman 1983
Water at 25 °C | 2 mg/L | Merck 1989
Organic solvent(s) | 79% w/w in isooctane | Merck 1989
Organic solvent(s) | 43% w/w in methanol
Organic solvent(s) | Readily soluble in other organic solvents
Partition coefficients:
Log K_ow_ | 4.82 | McCall et al. 1980
Log K_oc_ | 3.73
Vapor pressure at 20 °C | 1.87×10^−5^ mm Hg | Verschueren 1983
Vapor pressure at 25 °C | 1.87×10^−5^ mm Hg | Merck 1989
Henry’s law constant: at 25 °C | 1.23×10^−5^ atm-m^3^/mol | HSDB 1995
Autoignition temperature | No data
Flashpoint | None | EPA 1988b
Flammability limits at 25 °C | No data
Conversion factors (25 °C) | 1 ppm=14.3 mg/m^3^
Conversion factors (25 °C) | 1 mg/m^3^=0.070 ppm
Explosive limits | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances