# APPENDIX A ATSDR MINIMAL RISK LEVEL

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 994991, requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1-14 days), intermediate (15-364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## Chlorpyrifos Acute Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical name: | Chlorpyrifos
CAS number: | 508 15-00-4
Date: | August 1997
Profile status: | Final Post-public Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Key to figure: | 5
Species: | Human

MRL: 0.003 [X] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference]: Coulston et al. (1972)

[underlined: Exnerimental design]: 16 adult human male volunteers (4 per dose group) were treated with 0,0.014,0.03, or 0.10 mg/kg/day chlorpyrifos by capsule. Those subjects receiving 0.014 and 0.03 mg/kg/day were exposed for 20 days; those receiving 0.10 mg/kg/day were exposed for only 9 days.

[underlined: Effects noted in study and corresnonding doses]: Those subjects receiving 0.10 mg/kg/day were exposed for only 9 days because of blurred vision and a runny nose in one of the subjects. Plasma cholinesterase was decreased approximately 65% compared to controls in that group. No effect on plasma cholinesterase was seen at the lower doses and erythrocyte cholinesterase was unaffected by any of the chlorpyrifos doses. Thus, the NOAEL for chlorpyrifos plasma cholinesterase inhibition was 0.03 mg/kg/day. Based on this NOAEL, an MRL of 0.003 mg/kg was calculated: 0.03 mg/kg divided by an uncertainty factor of 10 for human variability. Please note that the combination of length of exposure period and the critical effect in this study enable it to be used for the derivation of both acute- and intermediate-duration oral exposure MRLs.

MRL = Human dose t Uncertainty factor = 0.03 mg/kg ÷ 10 = 0.003 mg/kg

[underlined: Dose endpoint used for MRL derivation]: Plasma cholinesterase inhibition

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty factors used in MRL derivation]:

[] 1 [ ] 3 [ ] 10(for use of a LOAEL)

[ ] 1 [ ] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [X] 10 (for human variability)

[underlined: Was a conversion factor used from num in food or water to a mg/body weight dose?] No.

If so, explain:

[underlined: If an inhalation study in animals. list conversion factors used in determining human eauivalent dose]:

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]:

[underlined: Was a conversion used from intermittent to continuous exposure?] No.

If so, explain:

[underlined: Other additional studies or pertinent information that lend support to this MRL]:

Deacon . (1980) Embryotoxicity and Fetotoxicity of Orally Administered Chlorpyrifos in Mice. Toxicology and Applied Pharmacology. 54, 31–40.6156524

The MRL study is further supported by a study by Deacon et al. (1980). Female CF-1 mice were exposed by gavage to 1, 10, or 2 mg/kg/day Dursban F® (96.8% chlorpyrifos) as a solution in cottonseed oil on gestation day (Gd) 6, Gds 610, or Gds 6-15. Controls received cottonseed oil alone. Five hours after the final dosing (Gds 6, 10, or 15) blood was obtained via cardiac puncture and plasma and erythrocyte cholinesterase activities determined. Plasma and erythrocyte cholinesterase levels were significantly decreased from control values among mice given 10 or 25 mg/kg chlorpyrifos on day 6 (plasma, 95 and 97%, respectively; erythrocyte, 40 and 20%, respectively) and, days 6-10 (plasma, 97 and 99%, respectively; erythrocyte, 43 and 71%, respectively), or Gds 6-15 (plasma, 96 and 98%, respectively; erythrocyte, 43 and 57%, respectively). Plasma cholinesterase levels were significantly reduced among mice given 1 mg/kg chlorpyrifos during the same time intervals (69, 78, and 85%, respectively). Erythrocyte cholinesterase levels were also reduced (43%) after 1 mg/kg chlorpyrifos, but only after exposure on Gds 6-10. In a concurrent study, no effects on plasma or erythrocyte cholinesterase activity were observed at 0.1 mg/kg chlorpyrifos.

[underlined: Agency Contact (Chemical Manager):] John F. Risher, Ph.D.

## Chlorpyrifos Intermediate Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical name: | Chlorpyrifos
CAS number: | 50815-00-4
Date: | July 1997
Profile status: | Final Post-public Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Key to figure: | 15
Species: | Human

MRL: 0.003 [X] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference]: Coulston et al. 1972.

[underlined: Experimental design]: 16 adult human male volunteers (4 per dose group) were treated with 0, 0.014, 0.03, or 0.10 mg/kg/day chlorpyrifos by capsule. Those subjects receiving 0.014 and 0.03 mg/kg/day were exposed for 20 days; those receiving 0.10 mg/kg/day were exposed for only 9 days.

[underlined: Effects noted in study and corresnonding doses]: Those subjects receiving 0.10 mg/kg/day were exposed for only 9 days because of blurred vision and a runny nose in one of the subjects. Plasma cholinesterase was decreased approximately 65% compared to controls in that group. No effect on plasma cholinesterase was seen at the lower doses and erythrocyte cholinesterase was unaffected by any of the chlorpyrifos doses. Thus, the NOAEL for chlorpyrifos plasma cholinesterase inhibition was 0.03 mg/kg/day. Based on this NOAEL, an MRL of 0.003 mg/kg was calculated: 0.03 mg/kg divided by an uncertainty factor of 10 for human variability. Please note that the combination of length of exposure period and the critical effect in this study enable it to be used for the derivation of both acute- and intermediate-duration oral exposure MRLs.

MRL = Human dose ÷ Uncertainty factor = 0.03 mg/kg × (1)/(10) = 0.003 mg/kg/day

[underlined: Dose endpoint used for MRL derivation]: Plasma cholinesterase inhibition

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty factors used in MRL derivation:]

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [X] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a ma/body weight dose?] No.

If so, explain:

[underlined: If an inhalation study in animals, list conversion factors used in determining. human equivalent dose:]

[underlined: Was a conversion used from intermittent to continuous exposure?] No.

If so, explain:

[underlined: Other additional studies or pertinent information that lend support to this MRL:]

Deacon . (1980) Embryotoxicity and Fetotoxicity of Orally Administered Chlorpyrifos in Mice. Toxicology and Applied Pharmacology. 54, 31–40.6156524

The MRL study is further supported by a study by Deacon et al. (1980). Female CF-1 mice were exposed by gavage to 1, 10, or 2 mg/kg/day Dursban F® (96.8% chlorpyrifos) as a solution in cottonseed oil on Gds 6, 6-10, or 6-15. Controls received cottonseed oil alone. Five hours after the final dosing (Gds 6, 10, or 15), blood was obtained via cardiac puncture and plasma and erythrocyte cholinesterase activities determined. Plasma and erythrocyte cholinesterase levels were significantly decreased from control values among mice given 10 or 25 mg/kg chlorpyrifos on day 6 (plasma, 95 and 97%, respectively; erythrocyte, 40 and 20%, respectively) and, days 6-10 (plasma, 97 and 99%, respectively; erythrocyte, 43 and 71%, respectively), or Gds 6-15 (plasma, 96 and 98%, respectively; erythrocyte, 43 and 57%, respectively). Plasma cholinesterase levels were significantly reduced among mice given 1 mg/kg chlorpyrifos during the same time intervals (69, 78, and 85%, respectively). Erythrocyte cholinesterase levels were also reduced (43%) after 1 mg/kg chlorpyrifos, but only after exposure on Gds 6-10. In a concurrent study, no effects on plasma or erythrocyte cholinesterase activity were observed at 0.1 mg/kg chlorpyrifos.

[underlined: Agency Contact (Chemical Manager):] John F. Risher, Ph.D.

## Chlorpyrifos Chronic Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical name: | Chlorpyrifos
CAS number: | 50815-00-4
Date: | July 1997
Profile status: | Final Post-public Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [] Intermediate [X] Chronic
Key to figure: | 42
Species: | Rat

MRL: 0.001 [X] mg/kg/day [ ] ppm [ ] mg/m^3^

[underlined: Reference]: McCollister et al. 1974

Experimental design: Sherman rats (25 males and 25 females) were dose fed chlorpyrifos at 0, 0.01, 0.03, 0.1, 1, or 3 mg/kg/day for 2 years beginning at 7-weeks of age. Additional groups of 5-7 rats of each sex at each dose level were set up to provide interim pathological examination and cholinesterase (ChE) determinations. Clinical observations, body weights, food consumption and mortality were monitored. At 6-month intervals, blood and urine samples were collected from selected rats receiving 0, 1, or 3 mg/kg/day. The packed cell volume, hemoglobin, erythrocyte count and total and differential leucocyte counts were determined in the blood. Urine was analyzed for total solids, pH, albumin, sugar, occult blood and ketones. The ChE activity of the plasma and red blood cells (RBC) was determined for all rats in the groups that were killed after receiving the test diets for 1 week, and 1, 3, 6, 9, 12, and 18 months, as well as for selected rats from those given each dose for 2 years. Brain ChE was measured in rats killed at 6, 12, 18, and 24 months. To characterize the recovery of the ChE activity in plasma, red cells and brain, some rats were maintained on the various diets containing chlorpyrifos for 12 months, and subsequently on the control diet for 7-8 weeks prior to sacrifice. Blood urea nitrogen (BUN), serum alkaline phosphatase (AP) and serum glutamic-pyruvic transaminase (SGPT) were determined on blood samples collected from rats killed at 12, 18, and 24 months. Necropsies were conducted on all rats killed at 12, 18, and 24 months and on those that received control feed for 7-8 weeks after having received chlorpyrifos diets for 12 months. These rats were fasted for 16 hours, decapitated, and weighed. The brain, heart, liver, kidney, spleen, and testes were removed and weighed. Portions of these tissues were preserved in 10% formalin, and histopathological examinations were performed on these tissues, as well as eye, pituitary, thyroid, and parathyroid glands, trachea, esophagus, lungs, aorta, stomach, pancreas, small intestine, colon, mesenteric lymph nodes, urinary bladder, accessory sex glands, ovaries, uterus, skeletal muscle, sciatic nerve, spinal cord, sternum, sternal bone marrow, adrenal gland, and any nodules or masses suggestive of tumor development or other pathological processes. Histopathological examinations were also conducted on the tissues of all rats exhibiting grossly visible nodules or masses, and on those killed in a moribund state or that died spontaneously, unless this was precluded by autolysis.

[underlined: Effects noted in study and corresponding doses:] Clinical observations did not detect evidence of a cholinergic overstimulation or any other compound-related effect. Brain cholinesterase (ChE) activity in both male and female rats displayed an overall reduction of 56% in rats fed 3 mg/kg/day chlorpyrifos during the 2-year study. No overall effect on brain ChE was observed at the lower doses. Plasma and RBC ChE activity were depressed for both male and female rats dosed with diets containing 1 or 3 mg/kg/day chlorpyrifos. At 1 mg/kg/day chlorpyrifos, plasma ChE was depressed 20-53%; RBC ChE activity was decreased 65-70% at that dose. Doses of 0.1 mg/kg/day and below had no effect on either plasma or RBC activity. Cholinesterase activities in plasma, RBC, and brain of rats fed chlorpyrifos-containing diets for 1 year returned to normal levels after switching to a control diet for 7-8 weeks. There was no effect of treatment on organ weights, histopathology, or number and types of tumors. It was concluded that 0.1 mg chlorpyrifos/kg/day fed in the diet for 2 years produced no significant toxicological effect in rats.

MRL = Human dose + Uncertainty factor ( UF = 10 for extrapolation from animal data; UF = 10 for human variability ) = 0.1 mg/kg/day × (1)/(10) × (1)/(10) = 0.001 mg/kg/day

[underlined: Dose endpoint used for MRL derivation:] Acetylcholinesterase inhibition

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty factors used in MRL derivation:]

[ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL)

[ ] 1 [ ] 3 [X] 10 (for extrapolation from animals to humans)

[ ] 1 [ ] 3 [X] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No.

If so, explain:

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose:]

[underlined: Was a conversion used from intermittent to continuous exposure?] No.

If so, explain:

[underlined: Other additional studies or pertinent information that lend support to this MRL:] No.

[underlined: Agency Contact (Chemical Manager):] John F. Risher, Ph.D.