# CHAPTER 8 REFERENCES

Abrahamsson K, Klick S. 1991. Degradation of halogenated phenols in anoxic natural marine sediments. Mar Pollut Bull 22(5):227–233.
ACGIH. 2019. TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Ahlborg UG, Larsson K. 1978. Metabolism of tetrachlorophenols in the rat. Arch Toxicol 40:63–74.580377
Aker AM, Johns L, McElrath TF, . 2018. Associations between maternal phenol and paraben urinary biomarkers and maternal hormones during pregnancy: A repeated measures study. Environ Int 113:341–349. 10.1016/j.envint.2018.01.006.29366524
Alexandersson R, Hedenstierna G. 1982. Pulmonary function after long-term exposure to trichlorophenol. Int Arch Occup Environ Health 49(3–4):275–280. 10.1007/bf00377936.7068239
Aly OM, Faust SD. 1964. Studies on the fate of 2,4-D and ester derivatives in natural surface waters. J Agric Food Chem 12:541–546.
Amer SM, Aly FA. 2001. Genotoxic effect of 2,4-dichlorophenoxy acetic acid and its metabolite 2,4-dichlorophenol in mouse. Mutat Res 494(1–2):1–12.11423340
Angerer J, Heinzow B, Reimann DO, . 1992. Internal exposure to organic substances in a municipal waste incinerator. Int Arch Occup Environ Health 64(4):265–273.1468796
Angerer J, Henizow B, Reimann DO, . 1993. Waste incineration: Estimation of the workers’ internal exposure to PCB, PAH, chlorophenols and other relevant agents. Proc SPIE 1716:418–426. 10.1117/12.140277.
Aoyama H, Hojo H, Takahashi KL, . 2005. A two-generation reproductive toxicity study of 2,4-dichlorophenol in rats. J Toxicol Sci 30:59–78.16641544
Armenante PM, Kafkewitz D, Lewandowski G, . 1992. Integrated anaerobic-aerobic process for the biodegradation of chlorinated aromatic-compounds. Environ Prog 11(2):113–122.
Armstrong MJ, Galloway SM, Ashby J. 1993. 2,4,6-Trichlorophenol (TCP) induces chromosome breakage and aneuploidy in vitro. Mutat Res 303(3):101–108. 10.1016/0165-7992(93)90021-m.7694125
Arrhenius E, Renberg L, Johanssori L, . 1977. Disturbance of microsomal detoxication mechanisms in liver by chlorophenol pesticides. Chem Biol Interact 18:35–46.890839
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2017. Chlorophenols. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
Audet-Delage Y, Ouellet N, Dallaire R, . 2013. Persistent organic pollutants and transthyretin-bound thyroxin in plasma of Inuit women of childbearing age. Environ Sci Technol 47(22):13086–13092. 10.1021/es4027634.24160776
Aung MT, Ferguson KK, Cantonwine DE, . 2019. Associations between maternal plasma measurements of inflammatory markers and urinary levels of phenols and parabens during pregnancy: A repeated measures study. Sci Total Environ 650(Pt 1):1131–1140. 10.1016/j.scitotenv.2018.08.356.30308801
Aydin H, Baran A, Aktas A, . 2009. Effects of soybean extract and L-tryptophan on 2,4-dichlorophenol induced testicular toxicity in mice. J Anim Vet Adv 8(4):774–778.
Azouz WM, Parke DV, Williams RT. 1953. Studies in detoxication. 51. The determination of catechols in urine, and the formation of catechols in rabbits receiving halogenobenzenes and other compounds: Dehydroxylation in vivo. Biochem J 55:146–151.13093631
Badée J, Qiu N, Collier AC, . 2019. Characterization of the ontogeny of hepatic UDP-glucuronosyltransferase enzymes based on glucuronidation activity measured in human liver microsomes. J Clin Pharmacol 59 Suppl 1:S42–S55. 10.1002/jcph.1493.31502688
Bae HS, Lee JM, Lee ST. 1996. Biodegradation of 4-chlorophenol via a hydroquinone pathway by Arthrobacter ureufuciens CPR706. FEMS Microbiol Lett 145:125–129.8931337
Bahig ME, Kraus A, Klein W. 1981. Excretion and metabolism of 2,4,6-trichlorophenol-^14^C in rats. Chemosphere 10:323–327.
Baker MD, Mayfield CI. 1980. Microbial and non-biological decomposition of chlorophenols and phenol in soil. Water Air Soil Pollut 13:411–424.
Baker MD, Mayfield CI, Inniss WE. 1980. Degradation of chlorophenol in soil, sediment and water at low temperature. Water Res 14:1765–1771.
Balfanz J, Rehm H. 1991. Biodegradation of 4-chlorophenol by adsorptive immobilized Alcaligenes sp. A7-2 in soil. Appl Microbiol Biotechnol 35(5):662–668.1367580
Banerjee S, Howard PH, Rosenberg AM, . 1984. Development of a general kinetic model for biodegradation and its application to chlorophenols and related compounds. Environ Sci Technol 18(6):416–422.22247942
Banna NR, Jabbur SJ. 1970. Increased transmitter release induced by convulsant phenols. Brain Res 20(3):471–473. 10.1016/0006-8993(70)90178-2.5433102
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barrows ME, Petrocelli SR, Macek KJ, . 1980. Bioconcentration and elimination of selected water pollutants by bluegill sunfish (Lepomis macrochirus). In: Haque R, ed. Dynamics, exposure and hazard assessment of toxic chemicals. Ann Arbor, MI: Ann Arbor Science Publishers Inc., 379–392.
Battersby NS, Wilson V. 1989. Survey of the anaerobic biodegradation potential of organic chemicals in digesting sludge. Appl Environ Microbiol 55(2):433–439.16347851
Bedient PB, Rodgers AC, Bouvette TC, . 1984. Groundwater quality at a creosote waste site. Ground Water 22:318–329.
Berger K, Coker E, Rauch S, . 2020. Prenatal phthalate, paraben, and phenol exposure and childhood allergic and respiratory outcomes: Evaluating exposure to chemical mixtures. Sci Total Environ 725:138418. 10.1016/j.scitotenv.2020.138418.32302842
Berger K, Hyland C, Ames JL, . 2021. Prenatal exposure to mixtures of phthalates, parabens, and other phenols and obesity in five-year-olds in the CHAMACOS cohort. Int J Environ Res Public Health 18(4) 10.3390/ijerph18041796.
Bello G, Dumancas G. 2017. Association of 2,4-dichlorophenol urinary concentrations and olfactory dysfunction in a national sample of middle-aged and older U.S. adults. Int J Environ Health Res 27(6):498–508. 10.1080/09603123.2017.1405245.29172666
Bercz JP, Robinson M, Jones L, . 1990. Subchronic toxicity studies of 2,4,6-trichlorophenol in Sprague-Dawley rats. J Am Coll Toxicol 9(5):497–506.
Berger K, Gunier RB, Chevrier J, . 2018. Associations of maternal exposure to triclosan, parabens, and other phenols with prenatal, maternal, and neonatal thyroid hormone levels. Environ Res 165:379–386. 10.1016/j.envres.2018.05.005.29803919
Billi SC, San Martin de Viale LC. 1985. Ability of several hexachlorobenzene metabolites to induce porphyrin accumulation in chick embryo liver “in ovo”. Acta Physiol Pharmacol Latinoam 35(4):399–407.2940801
Binder AM, Corvalan C, Pereira A, . 2018. Prepubertal and pubertal endocrine-disrupting chemical exposure and breast density among Chilean adolescents. Cancer Epidemiol Biomarkers Prev 27(12):1491–1499. 10.1158/1055-9965.EPI-17-0813.30158279
Blackburn K, Zenick H, Hope E, . 1986. Evaluation of the reproductive toxicology of 2,4,6-trichlorophenol in male and female rats. Fundam Appl Toxicol 6:233–239.3699313
Bleiberg J, Wallen M, Brodkin R, . 1964. Industrially acquired porphyria. Arch Dermatol 89:793–797.14164959
Bond GG, McLaren EA, Brenner FE, . 1989. Incidence of chloracne among chemical workers potentially exposed to chlorinated dioxins. J Occup Med 31(9):771–774.2529357
Borzelleca JF, Condie LW, Hayes JR. 1985a. Toxicological evaluation of selected chlorinated phenols. In: Water chlorination: Chemistry, environmental impact and health effects. Vol. 5. Chelsea, MI: Lewis Publishers, 331–343.
Borzelleca JF, Hayes JR, Condie LW, . 1985b. Acute toxicity of monochlorophenols, dichlorophenols and pentachlorophenol in the mouse. Toxicol Lett 29(1):39–42.4082204
Borzelleca J, Hayes JR, Condie LW, . 1985c. Acute and subchronic toxicity of 2,4-dichlorophenol in CD-1 mice. Fundam Appl Toxicol 5(3):478–486. 10.1016/0272-0590(85)90095-8.4007306
Boule P, Guyon C, Lemaire J. 1982. Photochemistry and environment. IV-Photochemical behavior of monochlorophenols in dilute aqueous solution. Chemosphere 11(12):1179–1188.
Boutwell RK, Bosch DK. 1959. The tumor-promoting action of phenol and related compounds for mouse skin. Cancer Res 19(4):413–424.13652126
Boyd SA, Shelton DR. 1984. Anaerobic biodegradation of chlorophenols in fresh and acclimated sludge. Appl Environ Microbiol 47(2):272–277.6712208
Bray HG, Humphris BG, Thorpe WV, . 1952a. Kinetic studies of the metabolism of foreign organic compounds. III. The conjugation of phenols with glucuronic acid. Biochem J 52:416–419.13018249
Bray HG, Humphris BG, Thorpe WV, . 1952b. Kinetic studies of the metabolism of foreign organic compounds. IV. The conjugation of phenols with sulphuric acid. Biochem J 52:419–423.13018250
Brown KW, Donnelly KC. 1988. An estimation of the risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Haz Waste Haz Mater 5:1–30.
BSRC. 2011. Simplified reproductive toxicity testing of oral p-chlorophenol dosage using rats. Biosafety Research Center. Pharmaceutical and Food Safety Bureau, Ministry of Health, Labour and Welfare of Japan. Test No: C539 (115-222).
Buikema AL, McGinniss MJ, Cairns J. 1979. Phenolics in aquatic ecosystems: A selected review of recent literature. Mar Environ Res 2:87–181.
Bukowska B. 2003. Effects of 2,4-D and its metabolite 2,4-dichlorophenol on antioxidant enzymes and level of glutathione in human erythrocytes. Comp Biochem Physiol 135(4):435–441.
Bukowska B. 2004. 2,4,5-T and 2,4,5-TCP induce oxidative damage in human erythrocytes: The role of glutathione. Cell Biol Int 28(7):557–563. 10.1016/j.cellbi.2004.04.013.15261164
Bukowska B, Wieteska P, Kwiatkowska M, . 2016. Evaluation of the effect of 2,4-dichlorophenol on oxidative parameters and viability of human blood mononuclear cells (in vitro). Hum Exp Toxicol 35(7):775–784. 10.1177/0960327115606789.26391574
Bull RJ, Robinson M, Larie RD. 1986. Association of carcinoma yield with early papilloma development in SENCAR mice. Environ Health Perspect 68:11–17.3780623
Burttschell RH, Rosen AA, Middleton FM, . 1959. Chlorine derivatives of phenol causing taste and odor. J Am Water Works Assoc 51:205–214.
Butte W, Juhl U, Schwarting W, . 1988. Evidence for the formation of a dihydroxychlorobiphenyl, hydroxychlorodiphenyl ethers and a hydroxychlorodibenzodioxin or hydroxychlorodiphnoquinone upon metabolism of 2,4,5-trichlorophenol by post-mitochondrial rat liver fractions (S-9). Chemosphere 17(6):1189–1196.
Buttke DE, Sircar K, Martin C. 2012. Exposures to endocrine-disrupting chemicals and age of menarche in adolescent girls in NHANES (2003-2008). Environ Health Perspect 120(11):1613–1618. 10.1289/ehp.1104748.23124194
Calvert GM, Sweeney MH, Morris JA, . 1991. Evaluation of chronic bronchitis, chronic obstructive pulmonary disease, and ventilatory function among workers exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin. Am Rev Respir Dis 144:1302–1306.1741543
Calvert GM, Hornung RW, Sweeney MH, . 1992. Hepatic and gastrointestinal effects in an occupational cohort exposed to 2,3,7,8-tetrachlorodibenxo-para-dioxin. JAMA 267(16):2209–2214.1348289
Camanzo J, Rice CP, Jude DJ, . 1987. Organic priority pollutants in nearshore fish from 14 Lake Michigan tributaries and embayments, 1983. J Great Lakes Res 13:296–309.
Carey JH, Fox ME, Hart JH. 1988. Identity and distribution of chlorophenols in the north arm of the Fraser River estuary. Water Pollut Res J Can 23(1):31–44.
Carlson GP. 1978. Effect of trichlorophenols on xenobiotic metabolism in the rat. Toxicology 11(2):145–151. 10.1016/s0300-483x(78)90939-3.102051
Carreon RE, Young JT, New MA, . 1980a. 2,4-Dichlorophenol (lot #MM08120): Acute percutaneous absorption potential in rabbits. Midland, MI: Dow Chemical USA.
Carreon RE, Young JT, New MA, . 1980b. 2,4-Dichlorophenol (lot #MM08120): Percutaneous absorption potential in rabbits. Midland, MI: Dow Chemical USA.
Cascorbi I, Ahlers J. 1989. Correlation between the lipophilicity of substituted phenols and their inhibition of the Na+/K+-ATPase of Chinese hamster ovary cells. Toxicology 58(2):197–210.2552618
CDC. 2000. Occupational fatalities associated with 2,4-dichlorophenol (2,4-DCP) exposure, 1980-1998. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep 49(23):516–518.10882291
CDC. 2009. Fourth national report on human exposure to environmental chemicals. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/index.html. December 18, 2019.
CDC. 2019. Fourth national report on human exposure to environmental chemicals updated tables, January 2019, Volume One. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/index.html. December 18, 2019.
CDC. 2021. Fourth national report on human exposure to environmental chemicals, updated tables, March 2021. Centers for Disease Control and Prevention. Vol. Two: NHANES 2011-2016, https://www.cdc.gov/exposurereport/pdf/FourthReport_UpdatedTables_Volume2_Mar2021-508.pdf. November 9, 2021.
Chen J, Jiang J, Zhang F, . 2004. Cytotoxic effects of environmentally relevant chlorophenols on L929 cells and their mechanisms. Cell Biol Toxicol 20(3):183–196.15250542
Chen L, Li N, Liu Y, . 2021. A new 3D model for genotoxicity assessment: EpiSkin Micronucleus Assay. Mutagenesis 36(1):51–61. 10.1093/mutage/geaa003.32067034
Chernoff N, Setzer RW, Miller DB, . 1990. Effects of chemically induced maternal toxicity on prenatal development in the rat. Teratology 42:651–658.2087686
Chiou CT, Freed VH, Peters LJ, . 1980. Evaporation of solutes from water. Environ Int 3:23l–236.
CITI. 2019. Bioaccumulation: Aquatic/sediment (CASRN: 95-57-8). Chemical Inspection and Testing Institute. https://www.nite.go.jp/chem/jcheck/detail.action?cno=95-57-8&mno=3-0895&request_locale=en. December 18, 2019.
Clerhata D, Kovacikova Z, Veningerova M, . 1996. The effect of 2,4-dichlorophenol on lipid peroxidation in tissues of guinea pigs with different ascorbic acid intake. Ind Health 34:415–419.8908852
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Coggon D, Pannett B, Winter P. 1991. Mortality and incidence of cancer at four factories making phenoxy herbicides. Br J Ind Med 48:173–178.2015208
Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Contr Fed 56:898–908.
Cook LW, Zach FW, Klosterman HJ, . 1983. Comparison of free and total residues of (2,4-dichlorophenoxy)acetic acid and 2,4-dichlorophenol in millet resulting from postemergence and preharvest treatment. J Agric Food Chem 31:268–271.6853854
Coombs HI, Hele TS. 1926. Studies in the sulphur metabolism of the dog. IV. The mechanism of mercapturic acid formation in the dog. Biochem J 20:606–612.16743699
Coughtrie MW. 2015. Ontogeny of human conjugating enzymes. Drug Metab Lett 9(2):99–108. 10.2174/1872312809666150602151213.26031463
Da Silva GN, De Camargo EA, Salvadori DM, . 2007. Genetic damage in human peripheral lymphocytes exposed to antimicrobial endodontic agents. Oral Surg Oral Med Oral Pathol Oral Radiol Endod 104(2):e58–61. 10.1016/j.tripleo.2007.02.009.
Dai J, Sloat AL, Wright MW, . 2005. Role of phenoxyl radicals in DNA adduction by chlorophenol xenobiotics following peroxidase activation. Chem Res Toxicol 18(4):771–779. 10.1021/tx0500023.15833038
Dai X, Qiu L, Rashida C, . 2021. 2,4-DCP compromises the fertilization capacity of mouse oocytes. J Cell Physiol 236(11):7605–7611. 10.1002/jcp.30403.33928643
Daniel FB, Robinson M, Olson GR, . 1993. Ten and ninety-day toxicity studies of 2-chlorophenol in Sprague-Dawley rats. Drug Chem Toxicol 16(3):277–291. 10.3109/01480549309081820.8404547
Dasappa SM, Loehr RC. 1991. Toxicity reduction in contaminated soil bioremediation processes. Water Res 25(9):1121–1130.
de Morais SM, Wells PG. 1988. Deficiency in bilirubin UDP-glucuronyl transferase as a genetic determinant of acetaminophen toxicity. J Pharmacol Exp Ther 247(1):323–331.3139868
de Morais SM, Uetrecht JP, Wells PG. 1992. Decreased glucuronidation and increased bioactivation of acetaminophen in Gilbert’s syndrome. Gastroenterology 102(2):577–586.1732127
de Morais P, Stoichev T, Basto MC, . 2012. Extraction and preconcentration techniques for chromatographic determination of chlorophenols in environmental and food samples. Talanta 89:1–11. 10.1016/j.talanta.2011.12.044.22284452
De Vault DS. 1985. Contaminants in fish from Great Lakes harbors and tributary mouths. Arch Environ Contam Toxicol 14:587–594.
Deichmann WB, Mergard EG. 1948. Comparative evaluation of methods employed to express the degree of toxicity of a compound. J Ind Hyg Toxicol 30(6):373–378.18100368
DeMarini DM, Brooks HG, Parkes DG, Jr. 1990. Induction of prophage lambda by chlorophenols. Environ Mol Mutagen 15(1):1–9.
Demers PA, Davies HW, Friesen MC, . 2006. Cancer and occupational exposure to pentachlorophenol and tetrachlorophenol (Canada). Cancer Causes Control 17(6):749–758. 10.1007/s10552-006-0007-9.16783603
Dodd DE, Pluta LJ, Sochaski MA, . 2012. Subchronic hepatotoxicity evaluation of 2,3,4,6-tetrachlorophenol in Sprague-Dawley rats. J Toxicol 2012:376246. 10.1155/2012/376246.22666246
Dodson RE, Boronow KE, Susmann H, . 2020. Consumer behavior and exposure to parabens, bisphenols, triclosan, dichlorophenols, and benzophenone-3: Results from a crowdsourced biomonitoring study. Int J Hyg Environ Health:113624. 10.1016/j.ijheh.2020.113624.33011057
Dodson RE, Setzer RW, Spengler JD, . 2021. Influence of living in the same home on biomonitored levels of consumer product chemicals. J Expo Sci Environ Epidemiol 10.1038/s41370-021-00368-8.
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 26, 2018.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/. July 26, 2018.
Dohi T, Terada H, Anarnura S, . 1989. The anti-inflammatory effects of phenolic dental medicaments as determined by mouse ear edema assay. Jpn J Pharmacol 49(4):535–639.2724693
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38.
Engst RN, Macho RM, Kujawa M, . 1976. The metabolism of lindane and its metabolites gamma-2,3,4,5,6-pentachlorocyclohexene, pentachlorobenzene, and pentachlorophenol in rats and the pathways of lindane metabolism. J Environ Sci Health B 11(2):95–l17.57975
EPA. 1979. Sources of toxic pollutants found in influents to sewage treatment plants. VI. Integrated interpresentation. Washington, DC: U.S. Environmental Protection Agency. EPA440481008.
EPA. 1980. Ambient water quality criteria for chlorinated phenols. Washington, DC: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100712V.txt. December 19, 2019.
EPA. 1982. Exposure and risk assessment for chlorinated phenols (2-chlorophenol, 2,4-dichlorophenol, 2,4,6-trichlorophenol). U.S. Environmental Protection Agency. EPA440485007. PB85211951.
EPA. 1986. 2,3,4,6-Tetrachlorophenol: 90-day subchronic oral toxicity study in rats. U.S. Environmental Protection Agency. Study No. 410-2522. (Formerly cited as American Biogenics)
EPA. 1987a. Teratologic evaluation of 2,3,4,6-tetrachlorophenol (CASRN 58-90-2) administered to CD rats on gestational days 6 through 15. Final report. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB88176151. EPA530SW88017A.
EPA. 1987b. Teratologic evaluation of 2,3,4,6-tetrachlorophenol (CASRN 58-90-2) administered to CD rats on gestational days 6 through 15. Appendices 1-9. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB88176151. EPA530SW88017A.
EPA. 1994. Emergency planning and community right-to-know EPCRA Section 313: List of toxic chemicals within the chlorophenols category. U.S. Environmental Protection Agency. EPA745B95004. PB95271268.
EPA. 2000. Method 526. Determination of selected semivolatile organic compounds in drinking water by solid phase extraction and capillary column gas chromatography/ mass spectrometry (GC/MS). Cincinnati, OH: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1005E6I.txt. December 16, 2019.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2007a. Provisional peer-reviewed toxicity values for 2,4,6-trichlorophenol (CASRN 88-06-2)). Washington, DC: U.S. Environmental Protection Agency. EPA690R07036F. https://cfpub.epa.gov/ncea/pprtv/documents/Trichlorophenol246.pdf. December 15, 2019.
EPA. 2007b. Provisional peer-reviewed toxicity values for 2-chlorophenol (CASRN 95-57-8). Washington, DC: U.S. Environmental Protection Agency. EPA690R07008F. https://cfpub.epa.gov/ncea/pprtv/documents/Chlorophenol2.pdf. December 15, 2019.
EPA. 2007c. Provisional peer-reviewed toxicity values for 2,4-dichlorophenol (CASRN 120-83-2). Washington, DC: U.S. Environmental Protection Agency. EPA690R07013F. https://cfpub.epa.gov/ncea/pprtv/documents/Dichlorophenol24.pdf. December 15, 2019.
EPA. 2007d. Provisional peer-reviewed toxicity values for 2,4,5-trichlorophenol (CASRN 95-95-4). Washington, DC: U.S. Environmental Protection Agency. EPA690R07035F. https://cfpub.epa.gov/ncea/pprtv/documents/Trichlorophenol245.pdf. December 15, 2019.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2012. Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface. (English)
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://semspub.epa.gov/work/HQ/100002014.pdf. July 25, 2018.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. June 5, 2019.
Eriksson M, Hardell L, Adami HO. 1990. Exposure to dioxins as a risk factor for soft tissue sarcoma: A population-based case-control study. J Natl Cancer Inst 82(6):486–490.2313720
Eriksson M, Hardell L, Berg N, . 1981. Soft-tissue sarcoma and exposure to chemical substances: A case- reference study. Br J Ind Med 38:27–33.7470401
Exon JH, Koller LD. 1982. Effects of transplacental exposure to chlorinated phenols. Environ Health Perspect 46:137–140.7151754
Exon JH, Koller LD. 1983a. Alteration of transplacental carcinogenesis by chlorinated phenols. In: Jolley RL, Brungs WA, Cotruvo WA, ., eds. Water chlorination: Environmental impact and health effects. Vol. 4, Book 2. Ann Arbor, MI: Ann Arbor Science, 1177–1188.
Exon JH, Koller LD. 1983b. Effects of chlorinated phenols on immunity in rats. Int J Immunopharmacol 5(2):131–136.6874166
Exon JH, Koller LD. 1985. Toxicity of 2-chlorophenol, 2,4-dichlorophenol and 2,4,6-trichlorophenol. In: Jolley RL, ed. Water chlorination: Chemistry, environmental impact and health effects. Vol. 5. Chelsea, MI: Lewis Publishers, 307–330.
Exon JH, Henningsen GM, Osborne CA, . 1984. Toxicologic, pathologic, and immunotoxic effects of 2,4-dichlorophenol in rats. J Toxicol Environ Health 14:723–730.6520883
Fahrig R, Nilsson C, Rappe C. 1978. Genetic activity of chlorophenols and chlorophenol impurities. Environ Sci Res 12:325–338.
Farquharson ME, Gage JC, Northover J. 1958. The biological action of chlorophenols. Br J Pharmacol 13:20–24.
FDA. 2021. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. February 3, 2021.
Feng H, Ruan Y, Wu R, . 2019. Occurrence of disinfection by-products in sewage treatment plants and the marine environment in Hong Kong. Ecotoxicol Environ Saf 181:404–411. 10.1016/j.ecoenv.2019.06.034.31220780
Fenske RA, Horstman SW, Bentley RK. 1987. Assessment of dermal exposure to chlorophenols in timber mills. Appl Ind Hyg 2(4):143–147.
Folke J, Lindgaard-Joergensen P. 1985. Organics in wheat and rye straw pulp bleaching and combined mill effluents. I. Chemical characterization and biodegradation studies. Toxicol Environ Chem 10:1–24.
Fragiadakis A, Sotiriou N, Korte F. 1981. Absorption, balance and metabolism of carbon-14-labeled 2,4,6-trichlorophenol in hydroponic tomato plants. Chemosphere 10:1315–1320.
Fu J, Zhang X, Chen P, . 2016. Endoplasmic reticulum stress is involved in 2,4-dichlorophenol-induced hepatotoxicity. J Toxicol Sci 41(6):745–756. 10.2131/jts.41.745.27853103
Fytianos K, Voudrias E, Kokkalis E. 2000. Sorption-desorption behaviour of 2,4-dichlorophenol by marine sediments. Chemosphere 40(1):3–6. 10.1016/s0045-6535(99)00214-3.10665437
Galloway SM, Armstrong MJ, Reuben C, . 1987. Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells: Evaluations of 108 chemicals. Environ Mol Mutagen 10:1–175.3319609
Galloway SM, Miller JE, Armstrong MJ, . 1998. DNA synthesis inhibition as an indirect mechanism of chromosome aberrations: Comparison of DNA-reactive and non-DNA-reactive clastogens. Mutat Res 400(1–2):169–186.9685628
Garabedian MJ, Hoppin JA, Tolbert PE, . 1999. Occupational chlorophenol exposure and non-Hodgkin’s lymphoma. J Occup Environ Med 41(4):267–272.10224592
Genthner BRS, Price WA, Pritchard PH. 1989. Anaerobic degradation of chloroaromatic compounds in aquatic systems under a variety of enrichment conditions. Appl Environ Microbiol 55:1466–1471.16347940
George SE, Whitehouse DA, Claxton LD. 1992. Genotoxicity of 2,4,5-trichlorophenoxyacetic acid biodegradation products in the Salmonella reversion and lambda prophage-induction bioassays. Environ Toxicol Chem 11:733–740.
Gomez MJ, Bruneau C, Soyer N, . 1988. Thermal degradation of chlorophenoxy acid herbicides. J Agric Food Chem 36:649–653.
Gossett RW, Brown DA, Young DR. 1983. Predicting the bioaccumulation of organic compounds in marine organisms using octanol/water partition coefficients. Mar Pollut Bull 14:387–392.
Grimvall A, Jonsson S, Karlsson S, . 1991. Organic halogens in unpolluted waters and large bodies of water receiving bleach plant effluents. TAPPI J 74(5):197–203.
Gu J, Zhou W, Jiang B, . 2016. Effects of biochar on the transformation and earthworm bioaccumulation of organic pollutants in soil. Chemosphere 145:431–437. 10.1016/j.chemosphere.2015.11.106.26694792
Gulcan HO, Liu Y, Duffel MW. 2008. Pentachlorophenol and other chlorinated phenols are substrates for human hydroxysteroid sulfotransferase hSULT2A1. Chem Res Toxicol 21(8):1503–1508. 10.1021/tx800133d.18656962
Guo J, Wu C, Zhang J, . 2019. Anthropometric measures at age 3 years in associations with prenatal and postnatal exposures to chlorophenols. Chemosphere 228:204–211. 10.1016/j.chemosphere.2019.04.127.31029966
Gurney BF, Lantenschlager DP. 1982. Nearly non-toxic parachlorophenol antiseptics. J Dent Assoc S Afr 37(12):815–818.6964189
Haggblom MM, Young LY. 1990. Chlorophenol degradation coupled to sulfate reduction. Appl Environ Microbiol 56(11):3255–3260.2094244
Hagiwara M, Watanabe E, Barrett JC, . 2006. Assessment of genotoxicity of 14 chemical agents used in dental practice: Ability to induce chromosome aberrations in Syrian hamster embryo cells. Mutat Res 603(2):111–120. 10.1016/j.mrgentox.2005.08.011.16406784
Haimi J, Sahninen J, Huhta V, . 1992. Bioaccumulation of organochlorine compounds in earthworms. Soil Biol Biochem 24(12):1699–1703.
Hallinger DR, Lindsay HB, Paul Friedman K, . 2020. Respirometric screening and characterization of mitochondrial toxicants within the toxcast phase I and II chemical libraries. Toxicol Sci 176(1):175–192. 10.1093/toxsci/kfaa059.32374859
Hamaguchi F, Tsutsui T. 2000. Assessment of genotoxicity of dental antiseptics: Ability of phenol, guaiacol, p-phenolsulfonic acid, sodium hypochlorite, p-chlorophenol, m-cresol or formaldehyde to induce unscheduled DNA synthesis in cultured Syrian hamster embryo cells. Jpn J Pharmacol 83(3):273–276.10952079
Hardell L, Eriksson M. 1988. The association between soft tissue sarcomas and exposure to phenoxyacetic acids. A new case-referent study. Cancer 62(3):652–656. 10.1002/1097-0142(19880801)62:3<652::aid-cncr2820620334>3.0.co;2-4.3390800
Hardell L, Eriksson M, Degerman A. 1995. Meta-analysis of 4 Swedish case-control studies on exposure to pesticides as risk-factor for soft-tissue sarcoma including the relation to tumor-localization and histopathological type. Int J Oncol 6(4):847–851.21556610
Hardell L, Eriksson M, Lenner P, . 1981. Malignant lymphoma and exposure to chemicals, especially organic solvents, chlorophenols and phenoxy acids: A case-control study. Br J Cancer 43:169–176.7470379
Harley KG, Berger KP, Kogut K, . 2019. Association of phthalates, parabens and phenols found in personal care products with pubertal timing in girls and boys. Hum Reprod 34(1):109–117. 10.1093/humrep/dey337.30517665
Harris RM, Kirk CJ, Waring RH. 2005. Non-genomic effects of endocrine disrupters: Inhibition of estrogen sulfotransferase by phenols and chlorinated phenols. Mol Cell Endocrinol 244(1–2):72–74. 10.1016/j.mce.2005.05.013.16266779
Harrison JW, Madonia JV. 1971. The toxicity of parachlorophenol. Oral Surg Oral Med Oral Pathol 32(1):90–99. 10.1016/0030-4220(71)90254-4.5281560
Hasegawa R, Hirata-Koizumi M, Takahashi M, . 2005. Comparative susceptibility of newborn and young rats to six industrial chemicals. Congenit Anom (Kyoto) 45(4):137–145. 10.1111/j.1741-4520.2005.00083.x.16359494
Hattula ML, Knuutinen J. 1985. Mutagenesis of mammalian cells in culture by chlorophenols, chlorocatechols and chloroguaiacols. Chemosphere 14:1617–1625.
Hattula ML, Wasenius VM, Krees R, . 1981. Acute and short-term toxicity of 2,3,4,6-tetrachlorophenol in rats. Bull Environ Contam Toxicol 26(6):795–800.7260450
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl 1):3–142.
Hencke JW, Lockwood DD. 1978. Acute toxicological properties and industrial handling hazards of 2,4-dichlorophenol. Midland, MI: Dow Chemical USA.
Hill RH, To T, Holler JS, . 1989. Residues of chlorinated phenols and phenoxy acid herbicides in the urine of Arkansas children. Arch Environ Contam Toxicol 18:469–474.2774664
Hilliard CA, Armstrong MJ, Bradt CI, . 1998. Chromosome aberrations in vitro related to cytotoxicity of nonmutagenic chemicals and metabolic poisons. Environ Mol Mutagen 31(4):316–326.9654240
Hites RA, Jungclaus GA, Lopez-Avila V, . 1979. Potentially toxic organic compounds in industrial wastewaters and river systems: Two case studies. ACS Symp Ser 94:63–90.
Hoak RD. 1957. The causes of tastes and odors in drinking water. Water Sewage Works 104:243–247.
Hodin F, Boren H, Grimvall A, . 1991. Formation of chlorophenols and related compounds in natural and technical chlorination processes. Water Sci Technol 24(3–4):403–410.
Holmes BE, Smeester L, Fry RC, . 2019. Disinfection byproducts bind human estrogen receptor-alpha. Environ Toxicol Chem 38(5):956–964. 10.1002/etc.4377.30698843
Hood RD, Patterson BL, Thacker GT, . 1979. Prenatal effects of 2,4,5-trichloropheno1 and phenoxyacetic acid in mice. J Environ Sci Health C Environ Carcinog Ecotoxicol Rev 13(3):189–204.
Hooiveld M, Heederik DJ, Kogevinas M, . 1998. Second follow-up of a Dutch cohort occupationally exposed to phenoxy herbicides, chlorophenols, and contaminants. Am J Epidemiol 147(9):891–901.9583720
Hoppin JA, Tolbert PE, Herrick RF, . 1998. Occupational chlorophenol exposure and soft tissue sarcoma risk among men aged 30-60 years. Am J Epidemiol 148(7):693–703.9778176
Horstman SW, Rossner A, Kalman DA, . 1989. Penetration of pentachlorophenol and tetrachlorophenol through human skin. J Environ Sci Health A Environ Sci Eng Toxic Hazard 24(3):229–242.
Hughes MF, Shrivastava SP, Fisher HL, . 1993. Comparative in vitro percutaneous-absorption of p-substituted phenols through rat skin using static and flow-through diffusion-systems. Toxicol in Vitro 71:221–227.
Huq AS, Ho NFH, Husari N, . 1986. Permeation of water contaminative phenols through hairless mouse skin. Arch Environ Contam Toxicol 15(5):557–566.3753043
Hwang HM, Hodson RE, Lee RF. 1986. Degradation of phenol and chlorophenols by sunlight and microbes in estuarine water. Environ Sci Technol 20(10):1002–1007. 10.1021/es00152a006.22257398
Hyun S, Lee LS. 2004. Hydrophilic and hydrophobic sorption of organic acids by variable charge soils: Effect of chemical acidity and acidic functional group. Environ Sci Technol 38(20):5413–5419. 10.1021/es0494914.15543745
IARC. 1999. Polychlorophenols and their sodium salts. IARC Monographs on the evaluation of carcinogenic risks to humans. Lyon, France: International Agency for Research on Cancer. Vol. 71, 769–828. http://publications.iarc.fr/89. December 15, 2019.
IARC. 2019. Pentachlorophenol and some related compounds. IARC Monographs on the evaluation of carcinogenic risks to humans. Lyon, France: International Agency for Research on Cancer. Vol. 117, 141–168. http://www.inchem.org/documents/iarc/iarcmono/v117iarc.pdf. December 6, 2019.
Ibeto C, Anekwe C, Ihedioha J. 2019. Human exposure risk to semivolatile organic compounds via soil in automobile workshops in Awka, South Eastern, Nigeria. Environ Sci Pollut Res Int 26(16):16249–16260. 10.1007/s11356-019-04981-x.30977002
Innes JRM, Ulland BM, Valero MG, . 1969. Bioassay of pesticides and industrial chemicals for tumorigenicity in mice: A preliminary note. J Natl Cancer Inst 42:1101–1104.5793189
IRIS. 1988. Chemical assessment summary: 2,3,4,6-Tetrachlorophenol (CASRN 58-90-2). Integrated Risk Information System. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0108_summary.pdf. December 19, 2019.
IRIS. 1990. Chemical assessment summary: 2,4,6-Trichlorophenol (CASRN 88-06-2). Integrated Risk Information System. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0122_summary.pdf#nameddest=woe. December 19, 2019.
IRIS. 2002a. Chemical assessment summary: 2-Chlorophenol (CASRN 95-57-8). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0303_summary.pdf. December 6, 2019.
IRIS. 2002b. Chemical assessment summary: 2,4-Dichlorophenol (CASRN 120-83-2). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0041_summary.pdf. December 6, 2019.
IRIS. 2002c. Chemical assessment summary: 2,4,5-Trichlorophenol (CASRN 95-95-4). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0121_summary.pdf. December 6, 2019.
IRIS. 2021. Alphabetical index. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris_drafts/atoz.cfm. February 3, 2021.
Isensee AR, Jones GE. 1971. Absorption and translocation of root and foliage applied 2,4-dichlorophenol, 2,7-dichlorodibenzo-p-dioxin, and 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Agric Food Chem 19(6):1210–1214. 10.1021/jf60178a045.5167247
Ismail RM, Salminen L, Korte F. 1977. Distribution of topically applied environmental chemicals in the rabbit eye. Chemosphere 6:797–802.
Izushi F, Mori T, Ogata M. 1988. Effect of phenol and halogenated phenols on energy transfer reactions of rat liver mitochondria. Acta Med Okayama 42(1):7–14. 10.18926/AMO/31035.2966543
Janik F, Wolf HU. 1992. The calcium transport-ATPase of human erythrocytes as an in vitro toxicity test system: Acute effects of some chlorinated compounds. J Appl Toxicol 12(5):351–358.1447481
Jansson K, Jansson V. 1986. Inability of chlorophenols to induce 6 thioguanine-resistant mutants in V79 Chinese hamster cells. Mutat Res 171(2–3):165–168.3748065
Jansson K, Jansson V. 1992. Genotoxicity of 2,4,6-trichlorophenol in V79 Chinese hamster cells. Mutat Res 280(3):175–179. 10.1016/0165-1218(92)90046-3.1381480
Jerschow E, Parikh P, McGinn AP, . 2014. Relationship between urine dichlorophenol levels and asthma morbidity. Ann Allergy Asthma Immunol 112(6):511–518 e511. 10.1016/j.anai.2014.03.011.24726197
Judis J. 1982. Binding of selected phenol derivatives to human serum proteins. J Pharm Sci 71(10):1145–1147. 10.1002/jps.2600711017.7143213
Juhl U, Blum K, Witte I. 1989. The in vitro metabolites of 2,4,6-trichlorophenol and their DNA strand breaking properties. Chem Biol Interact 69:333–344.2543510
Juhl U, Blum JK, Butte W, . 1991. The induction of DNA strand breaks and formation of semiquinone radicals by metabolites of 2,4,5-trichlorophenol. Free Radic Res Commun 11(6):295–305.2071027
Junk GA, Richard JJ, Avery MJ, . 1986. Organic compounds from coal combustion. ACS Symp Ser 319:109–123.
Kafkewitz D, Fava F, Armenante PM. 1996. Effect of vitamins on the aerobic degradation of 2-chlorophenol, 4-chlorophenol, and 4-chlorobiphenyl. Appl Microbiol Biotechnol 46(4):414–421. 10.1007/bf00166239.8987730
Kaioumova DF, Khabutdinova L. 1998. Cytogenetic characteristics of herbicide production workers in Ufa. Chemosphere 37(9–12):1755–1759.9828303
Karapally JC, Saha JG, Lee YW. 1973. Metabolism of lindane ^14^C in the rabbit: Ether soluble urinary metabolites. J Agric Food Chem 21:811–818.4126189
Karasek FW, Charbonneau GM, Reuel GJ, . 1987. Determination of organic compounds leached from municipal incinerator fly ash by water at different pH levels. Anal Chem 59(7):1027–1031. 10.1021/ac00134a021.3592212
Kavlock RJ. 1990. Structure-activity relationships in the developmental toxicity of substituted phenols: in vivo effects. Teratology 41(1):43–59. 10.1002/tera.1420410106.2305374
Kawaguchi H. 1992a. Determination of direct and indirect photolysis rates of 2-chlorophenol in humic acid solution and natural waters. Chemosphere 25(5):635–641.
Kawaguchi H. 1992b. Photolysis of 2-chlorophenol in natural waters. J Contam Hydrol 9:105–114.
Kelley AS, Banker M, Goodrich JM, . 2019. Early pregnancy exposure to endocrine disrupting chemical mixtures are associated with inflammatory changes in maternal and neonatal circulation. Sci Rep 9(1):5422. 10.1038/s41598-019-41134-z.30931951
Kilzer L, Scheunert I, Geyer H, . 1979. Laboratory screening of the volatilization rates of organic chemicals from water and soil. Chemosphere 8:751–761.
Kim S, Hwang SJ, Choi W. 2005. Visible light active platinum-ion-doped TiO2 photocatalyst. J Phys Chem B 109(51):24260–24267. 10.1021/jp055278y.16375422
Kimber I, Weisenberger C. 1991. Anamnestic responses to contact allergens: application in the murine local lymph node assay. J Appl Toxicol 11(2):129–133. 10.1002/jat.2550110211.2061551
Kinae N, Hashizume T, Makita T, . 1981. Studies on the toxicity of pulp and paper mill effluents. I. Mutagenicity. Water Res 15:17–24.
Kintz P, Tracqui A, Mangin P. 1992. Accidental death caused by the absorption of 2,4-dichlorophenol through the skin. Arch Toxicol 66:298–299.1514931
Kitchin KT, Brown JL. 1988. Biochemical effects of three chlorinated phenols in rat liver. Toxicol Environ Chem 16:165–172.
Kitunen V, Valo RJ, Salkinoja-Salonen M. 1985. Analysis of chlorinated phenols, phenoxyphenols and dibenzofurans around wood preserving facilities. Int J Anal Chem 20:13–28.
Kitunen VH, Valo RJ, Salkinoja-Salonen MS. 1987. Contamination of soil around wood-preserving facilities by polychlorinated aromatic compounds. Environ Sci Technol 21(1):96–101.
Kiyohara H, Hatta T, Ogawa Y, . 1992. Isolation of Pseudomonas pickettii strains that degrade 2,4,6-trichlorophenol and their dechlorination of chlorophenols. Appl Environ Microbiol 58(4):1276–1283.1599247
Kjeldsen P, Kjolholt J, Schultz B, . 1990. Sorption and degradation of chlorophenols, nitrophenols and organophosphorus pesticides in the subsoils under landfills: Laboratory studies. J Contam Hydrol 6(2):165–184.
Kleinman GD, Horstman SW, Kalman DA, . 1986. Industrial hygiene, chemical and biological assessments of exposures to a chlorinated phenolic sapstain control agent. Am Ind Hyg Assoc J 47(12):731–741.3799472
Knackmuss HJ, Hellwig M. 1978. Utilization and cooxidation of chlorinated phenols by Pseudomonas sp. B 13. Arch Microbiol 117(1):1–7. 10.1007/bf00689343.678009
Knight AW, Billinton N, Cahill PA, . 2007. An analysis of results from 305 compounds tested with the yeast RAD54-GFP genotoxicity assay (GreenScreen GC)-including relative predictivity of regulatory tests and rodent carcinogenesis and performance with autofluorescent and coloured compounds. Mutagenesis 22(6):409–416. 10.1093/mutage/gem036.17906314
Kobayashi S, Toida S, Kawamura H, . 1972. [Chronic toxicity of 2,4-dichlorophenol in mice: A simple design for the toxicity of residual metabolites of pesticides]. Toho Igakkai Zasshi 19:356–362 (Japanese)
Kochany J, Bolton JR. 1991. Mechanism of photodegradation of aqueous organic pollutants. 1. EPR spin-trapping technique for the determination of hydroxyl radical rate constants in the photooxidation of chlorophenols following the photolysis of hydrogen peroxide. J Phys Chem 95(13):5116–5120. 10.1021/j100166a039.
Kogevinas M, Saracci R, Bertazzi PA, . 1992. Cancer mortality from soft-tissue sarcoma and malignant lymphomas in an international cohort of workers exposed to chlorophenoxy herbicides and chlorophenols. Chemosphere 25(7–10):1071–1076.
Kogevinas M, Becher H, Benn T, . 1997. Cancer mortality in workers exposed to phenoxy herbicides, chlorophenols, and dioxins. An expanded and updated international cohort study. Am J Epidemiol 145(12):1061–1075.9199536
Kondo T, Yamamoto H, Tatarazako N, . 2005. Bioconcentration factor of relatively low concentrations of chlorophenols in Japanese medaka. Chemosphere 61(9):1299–1304. 10.1016/j.chemosphere.2005.03.058.15893358
Koransky W, Munch G, Noack G, . 1975. Biodegradation of alpha-hexachlorocyclohexane. V. Characterization of the major urinary metabolites. Naunyn Schmiedebergs Arch Pharmacol 288(1):65–78.51481
Korte F, Freitag D, Geyer H, . 1978. Ecotoxicologic profile analysis: A concept of establishing ecotoxicologic priority lists for chemicals. Chemosphere 7:79–102.
Krijgsheld KR, Van der gen A. 1986. Assessment of the impact of the emission of certain organochloride compounds on the aquatic environment. Part I. Monochlorophenols and 2,4-dichlorophenol. Chemosphere 15(7):825–860.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Ku Y, Leu RM, Lee KC. 1996. Decomposition of 2-chlorophenol in aqueous solution by UV irradiation with the presence of titanium dioxide. Water Res 30(11):2569–2578.
Kubu T, Urano K, Utsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554. 10.1248/jhs.48.545
Kusters E, Lauwerys R. 1990. Biological monitoring of exposure to monochlorobenzene. Int Arch Occup Environ Health 62(4):329–331. 10.1007/bf00640842.2379965
Kutz FW, Cook BT, Carter-Pokras OD, . 1992. Selected pesticide residues and metabolites in urine from a survey of the U.S. general population. J Toxicol Environ Health 37:277–291.1404486
Ladumor MK, Bhatt DK, Gaedigk A, . 2019. Ontogeny of hepatic sulfotransferases and prediction of age-dependent fractional contribution of sulfation in acetaminophen metabolism. Drug Metab Dispos 47(8):818–831. 10.1124/dmd.119.086462.31101678
Lampi P, Tuomisto J, Hakulinen T, . 2008. Follow-up study of cancer incidence after chlorophenol exposure in a community in southern Finland. Scand J Work Environ Health 34(3):230–233.18728913
Leuenberger C, Ligocki MP, Pankow JF. 1985. Trace organic compounds in rain. IV. Identities, concentrations, and scavenging mechanisms for phenols in urban air and rain. Environ Sci Technol 19:1053–1058.22288749
Lindross L, Koskinen H, Mutanen P, . 1987. Urinary chlorophenols in sawmill workers. Int Arch Occup Environ Health 59:463–467.3653991
Liu D, Pacepavicius G. 1990. A systematic study of the aerobic and anaerobic biodegradation of 18 chlorophenols and 3 cresols. Toxic Assess 5(4):367–388.
Liu NR, Yang K, Li WT, . 2020a. Evaluation of the inhibition of chlorophenols towards human cytochrome P450 3A4 and differences among various species. Sci Total Environ 724:138187. 10.1016/j.scitotenv.2020.138187.32408447
Liu J, Olson C, Qiu N, . 2020b. Differential cytotoxicity of haloaromatic disinfection byproducts and lead co-exposures against human intestinal and neuronal cells. Chem Res Toxicol 33(9):2401–2407. 10.1021/acs.chemrestox.0c00157.32803957
Liu Y, Zhu D, Zhao Z, . 2021. Comparative cytotoxicity studies of halophenolic disinfection byproducts using human extended pluripotent stem cells. Chemosphere 263:127899. 10.1016/j.chemosphere.2020.127899.33297007
Lou PH, Hansen BS, Olsen PH, . 2007. Mitochondrial uncouplers with an extraordinary dynamic range. Biochem J 407(1):129–140. 10.1042/BJ20070606.17608618
Lueken A, Juhl-Strauss U, Krieger G, . 2004. Synergistic DNA damage by oxidative stress (induced by H2O2) and nongenotoxic environmental chemicals in human fibroblasts. Toxicol Lett 147(1):35–43.14700526
Lynge E. 1985. A follow-up study of cancer incidence among workers in manufacture of phenoxy herbicides in Denmark. Br J Cancer 52:259–270.4027168
Ma Y, Liu C, Lam PK, . 2011. Modulation of steroidogenic gene expression and hormone synthesis in H295R cells exposed to PCP and TCP. Toxicology 282(3):146–153. 10.1016/j.tox.2011.01.024.21296122
Malloy TA, Goldfarb TD, Surico MTJ. 1993. PCDDs, PCDFs, PCBs, chlorophenols (CPs) and chlorobenzenes (CBzs) in samples from various types of composting facilities in the United States. Chemosphere 27(1–3):325–334.
Matsuoka A, Hayashi M, Sofuni T. 1998. In vitro clastogenicity of 19 organic chemicals found in contaminated water and 7 structurally related chemicals. Kenkyo Hen’igen Kenkyu 20(3):159–165.
Matus V, Vasquez M, Vicente M, . 1996. Microbial mineralization of 2,4,5-trichlorophenol in soil. Environ Sci Technol 30:1472–1476.
McCollister DD, Lockwood DT, Rowe VK. 1961. Toxicologic information on 2,4,5-trichlorophenol. Toxicol Appl Pharmacol 3:63–70.13773805
McGregor DB, Brown A, Cattanach P, . 1988. Responses of the LS 178Ytk+/tk− mouse lymphoma cell forward mutation assay. III. 72 Coded chemicals. Environ Mol Mutagen 12:85–154.3383842
Mehmood Z, Kelly DE, Kelly SL. 1997. Cytochrome P450 3A4 mediated metabolism of 2,4-dichlorophenol. Chemosphere 34(11):2281–2291.9192464
Merriman JC. 1988. Distribution of organic contaminants in water and suspended solids of the Rainy River (Canada, USA). Water Pollut Res J Can 23(4):590–601.
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299. 10.1016/0045-6535(93)90355-9.
Michalowicz J, Majsterek I. 2010. Chlorophenols, chlorocatechols and chloroguaiacols induce DNA base oxidation in human lymphocytes (in vitro). Toxicology 268(3):171–175. 10.1016/j.tox.2009.12.009.20025924
Mirabelli MC, Hoppin JA, Tolbert PE, . 2000. Occupational exposure to chlorophenol and the risk of nasal and nasopharyngeal cancers among U.S. men aged 30 to 60. Am J Ind Med 37(5):532–541.10723047
Mitsuda H, Murakami K, Kawai F. 1963. Effect of chlorophenol analogues on the oxidative phosphorylation in rat liver mitochondria. Agric Biol Chem 27:366–372.
Miyachi T, Tsutsui T. 2005. Ability of 13 chemical agents used in dental practice to induce sister-chromatid exchanges in Syrian hamster embryo cells. Odontology 93(1):24–29. 10.1007/s10266-005-0055-8.16170472
Mohammadi L, Bazrafshan E, Noroozifar M, . 2017. Removing 2,4-dichlorophenol from aqueous environments by heterogeneous catalytic ozonation using synthesized MgO nanoparticles. Water Sci Technol 76(11–12):3054–3068. 10.2166/wst.2017.479.29210691
Monsanto. 1975. Initial submission: Toxicologic evaluation of: ortho-chlorophenol (final report) with cover letter dated 112691. Younger Labs. Monsanto. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0534831. 88920000379. 8EHQ-1291-1734.
Monsanto. 1976. Initial submission: Toxicologic investigation of: 2,4-dichlorophenol-93% (final report) with cover letter dated 112691. Younger Labs. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0534822. 88920000370. 8EHQ-1291-1725.
Morales A, Birkhols DA, Hrudey SE. 1992. Analysis of pulp mill effluent contaminants in water, sediment, and fish muscle - Chlorophenols and related compounds. Water Environ Res 64(5):669–681.
Muller F, Caillard L. 2011. Chlorophenols. In: Ullmann’s encyclopedia of industrial chemistry. Vol. 9. 7th ed. Weinheim, Germany: Wiley-VCH. 10.1002/14356007.a07_001.pub2.
Murphy RS, Kutz FW, Strassman SC. 1983. Selected pesticide residues or metabolites in blood and urine specimens from a general population survey. Environ Health Perspect 48:81–86.6825639
Mussalo-Rauhamaa H, Pyysalo H, Antervo K. 1989. The presence of chlorophenols and their conjugates in Finnish human adipose and liver tissues. Sci Total Environ 83(1–2):161–172.2781264
Narasimhan TR, Mayura K, Clement BA, . 1992. Effects of chlorinated phenols on rat embryonic and hepatic mitochondrial oxidative phosphorylation. Environ Toxicol Chem 11(6):805–814.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
NCI. 1968. Evaluation of carcinogenic, teratogenic and mutagenic activities of selected pesticides and industrial chemicals. 1. Carcinogenic study. Bethesda, MD: National Cancer Institute. NCI-DCCP-CG-1973-1-1. PB223159.
NCI. 1979. Bioassay of 2,4,6-trichlorophenol for possible carcinogenicity: CAS No. 88-06-2. National Cancer Institute. NCI-CG-TR-155.
NIOSH. 2018. NIOSH pocket guide to chemical hazards. Index of Chemical Abstracts Service Registry Numbers (CAS No.). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgdcas.html. September 2, 2019.
NLM. 2003a. 2,3,4,5-Tetrachlorophenol. Hazardous Substances DataBank. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/6765. December 19, 2019.
NLM. 2003b. 2,3,4,6-Tetrachlorophenol. Hazardous Substances DataBank. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/1338. December 19, 2019.
NLM. 2003c. 2,3,5,6-Tetrachlorophenol. Hazardous Substances DataBank. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/6766. December 19, 2019.
NLM. 2009a. 2,4-Dichlorophenol. Hazardous Substances DataBank. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/1139. December 19, 2019.
NLM. 2009b. 2-Chlorophenol. Hazardous Substances DataBank. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/1415. December 19, 2019.
NLM. 2009c. 4-Chlorophenol. Hazardous Substances DataBank. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/1414. December 19, 2019.
NLM. 2015. 2,4,6-Trichlorophenol. Hazardous Substances DataBank. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/source/hsdb/4013. December 19, 2019.
NLM. 2019. 2,4,5-Trichlorophenol. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/7271. Decemer 19, 2019.
NLM. 2020a. 2,3-Dichlorophenol. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/11334. August 13, 2020.
NLM. 2020b. 2,5-Dichlorophenol. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/66. August 13, 2020.
NLM. 2020c. 3,4-Dichlorophenol. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/7258. August 13, 2020.
NLM. 2020d. 3,5-Dichlorophenol. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/11571. August 13, 2020.
NLM. 2020e. 2,3,4-Trichlorophenol. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/27582. August 13, 2020.
Noel J, Habib AR, Thamboo A, . 2017. Variables associated with olfactory disorders in adults: A U.S. population-based analysis. World J Otorhinolaryngol 3(1):9–16. 10.1016/j.wjorl.2017.02.005.
NTP. 1989. Toxicology and carcinogenesis studies of 2,4-dichlorophenol in F344/N rats and B6C3F1 mice (feed studies). Research Triangle Park, NC: National Toxicology Program. TR 353. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr353.pdf?utm_source=direct&utm_medium=prod&utm_campaign=ntpgolinks&utm_term=tr353. December 12, 2019.
NTP. 2016. 2,4,6-Trichlorophenol. Report on carcinogens, Fourteenth edition. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/trichlorophenol.pdf. December 6, 2019.
NTP. 2021. CASRN index. In: Report on carcinogens. 15th ed. National Toxicology Program, https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. January 10, 2022.
Oberg T, Warman K, Bergstrom J. 1989. Production of chlorinated aromatics in the post-combustion zone and boiler. Chemosphere 19(1–6):317–322.
Ogata M, Taguchi T, Hirota N, . 1991. Quantitation of urinary chlorobenzene metabolites by HPLC: Concentrations of 4-chlorocatcehol and chlorophenols in urine and of chlorobenzene in biological specimens of subjects exposed to chlorobenzene. Int Arch Occup Environ Health 63(2):121–128.1889881
OhioEPA. 2008. 2008 305(b) Report Ohio’s ground water quality. State of Ohio Environmental Protection Agency. https://www.epa.ohio.gov/Portals/28/documents/gwqcp/2008_305b.pdf. November 11, 2021.
Oikari A, Holmbom B, Anas E, . 1985. Ecotoxicological aspects of pulp and paper mill effluents discharged to an inland water system: Distribution in water and toxicant residues and physiological effects in caged fish (Salmo gairdneri). Aquat Toxicol 6:219–239.
Okada K, Hiroi T, Imaoka S, . 2005. Inhibitory effects of environmental chemicals on protein disulfide isomerase in vitro. Osaka City Med J 51(2):51–63.16617682
Onfelt A. 1987. Spindle disturbances in mammalian cells. III. Toxicity, c-mitosis and aneuploidy with 22 different compounds. Specific and unspecific mechanisms. Mutat Res 182(3):135–154.3587257
Ono Y, Somiya I, Kawaguchi T. 1992. Genotoxic evaluation on aromatic organochlorine compounds by using umu test. Water Sci Technol 26(1–2):61–69. 10.2166/wst.1992.0386.
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. December 16, 2021.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. December 16, 2021.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. December 16, 2021.
Ott MG, Olson RA, Cook RR, . 1987. Cohort mortality study of chemical workers with potential exposure to the higher chlorinated dioxins. J Occup Med 29(5):422–429.2439670
Paasivirta J, Heinola K, Humppi T, . 1985. Polychlorinated phenols, guaiacols and catechols in environment. Chemosphere 14:469–491.
Parastar S, Ebrahimpour K, Hashemi M, . 2018. Association of urinary concentrations of four chlorophenol pesticides with cardiometabolic risk factors and obesity in children and adolescents. Environ Sci Pollut Res Int 25(5):4516–4523. 10.1007/s11356-017-0771-y.29188597
Pascal-Lorber S, Despoux S, Jamin EL, . 2012. Metabolic fate of 2,4-dichlorophenol and related plant residues in rats. J Agric Food Chem 60(7):1728–1736. 10.1021/jf203666k.22276578
Patel N, Shahane S, Bhunia B, . 2021. Biodegradation of 4-chlorophenol in batch and continuous packed bed reactor by isolated Bacillus subtilis. J Environ Manage 301:113851. 10.1016/j.jenvman.2021.113851.34597952
Pekari K, Boudene C, Aitio A. 1986. Kinetics of 2,4,6-trichlorophenol in different organs of the rat. Arch Toxicol 59:41–44.3741142
Pekari K, Luotamo M, Jaervisalo J, . 1991. Urinary excretion of chlorinated phenols in saw-mill workers. Int Arch Occup Environ Health 63(1):57–62.1856025
Persson PE. 1984. Uptake and release of environmentally occurring odorous compounds by fish a review. Water Res 18(10):1263–1272.
Pesqué D, March-Rodriguez Á, Dahlin J, . 2021. Bikini textile contact dermatitis: A Sherlockian approach revealing 2.4-dichlorophenol as a potential textile contact allergen. Contact Dermatitis 10.1111/cod.13946.
Peuravuori J, Paaso N, Pihlaja K. 2002. Sorption behaviour of some chlorophenols in lake aquatic humic matter. Talanta 56(3):523–538.18968525
Philippat C, Mortamais M, Chevrier C, . 2012. Exposure to phthalates and phenols during pregnancy and offspring size at birth. Environ Health Perspect 120(3):464–470. 10.1289/ehp.1103634.21900077
Philippat C, Wolff MS, Calafat AM, . 2013. Prenatal exposure to environmental phenols: Concentrations in amniotic fluid and variability in urinary concentrations during pregnancy. Environ Health Perspect 121(10):1225–1231. 10.1289/ehp.1206335.23942273
Phornchirasilp S, DeSouza JJ, Feller DR. 1989a. In vivo and in vitro studies of the hepatoxic effects of 4-chlorophenol in mice. Biochem Pharmacol 38(6):961–972.2930597
Phornchirasilp S, Pate ST, Hanson JM, . 1989b. Pharmacologic effects of 4-chlorophenol in rats: Comparison to clofibrate. Proc Soc Exp Biol Med 191(2):139–146.2726779
Piwoni MD, Wilson JT, Walters DM, . 1986. Behavior of organic pollutants during rapid-infiltration of wastewater into soil. I. Processes, definition, and characterization using a microcosm. Haz Waste Haz Mater 3:43–55.
Plumb RH. 1991. The occurrence of Appendix IX organic constituents in disposal site ground water. Ground Water Monit Remed 11(2):157–164.
Pollack AZ, Mumford SL, Krall JR, . 2018. Exposure to bisphenol A, chlorophenols, benzophenones, and parabens in relation to reproductive hormones in healthy women: A chemical mixture approach. Environ Int 120:137–144. 10.1016/j.envint.2018.07.028.30092451
Pollack AZ, Mumford SL, Krall JR, . 2020. Urinary levels of environmental phenols and parabens and antioxidant enzyme activity in the blood of women. Environ Res 186:109507. 10.1016/j.envres.2020.109507.32325294
Probst GS, McMahon RE, Hill LE, . 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: A comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3:11–32.7021142
Rapson WH, Nazar MA, Bulsky VV. 1980. Mutagenicity produced by aqueous chlorination of organic compounds. Bull Environ Contam Toxicol 24:590–596.6991030
Rasanen L, Hattula ML, Arstila AU. 1977. Mutagenicity of MCPA and its soil metabolites, chlorinated phenols, catechols and some widely used slimicides in Finland. Bull Environ Contam Toxicol 18:565–571.338061
Ravanel P, Taillandier G, Tissut M. 1989. Uncoupling properties of a chlorophenol series on Acer cell suspensions: A QSAR study. Ecotoxicol Environ Saf 18(3):337–345.2612425
Ravanel P, Taillandier G, Tissut M, . 1985. Effect of chlorophenols on isolated plant mitochondria activities: A QSAR study. Ecotoxicol Environ Saf 9(3):300–320.4006830
Renner G, Mucke W. 1986. Transformations of pentachlorophenol. Part I: Metabolism in animals and man. Toxicol Environ Chem 11(1):9–29.
RePORTER. 2021. Chlorophenols. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. January 17, 2022.
Rhone-Poulenc. 1978. Initial submission: Skin corrosion test of para-chlorophenol in rabbits with cover letter dated 060592. Rhodia, Inc. Rhone-Poulenc, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0537521. 88920003565. 8EHQ-0692-4919.
Rhone-Poulenc. 1981. Initial submission: Skin corrosion test of o-chlorophenol in rabbits with cover letter dated 061992. Bioassay System Corporation. Rhone-Poulenc, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0542021. 88920003775. 8EHQ-0692-5219.
Rhone-Poulenc. 1991. Initial submission: 4-hour, acute inhalation toxicity study with ortho chlorophenol (C1648) in rats (final report) with attachements and cover letter dated 112791. Research and Consulting Company AG. Rhone-Poulenc, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0534816. 88920000364. 8EHQ-1291-1719.
Ribeiro DA, Marques ME, Salvadori DM. 2004. Lack of genotoxicity of formocresol, paramonochlorophenol, and calcium hydroxide on mammalian cells by comet assay. J Endod 30(8):593–596.15273643
Ribeiro DA, Scolastici C, De Lima PL, . 2005. Genotoxicity of antimicrobial endodontic compounds by single cell gel (comet) assay in Chinese hamster ovary (CHO) cells. Oral Surg Oral Med Oral Pathol Oral Radiol Endod 99(5):637–640. 10.1016/j.tripleo.2004.07.010.15829890
Richardson DB, Terschuren C, Hoffmann W. 2008. Occupational risk factors for non-Hodgkin’s lymphoma: A population-based case-control study in Northern Germany. Am J Ind Med 51(4):258–268. 10.1002/ajim.20552.18213641
Roberts MS, Anderson RA, Swarbrick J. 1977. Permeability of human epidermis to phenolic compounds. J Pharm Pharmacol 29:677–683.22602
Rocha BA, Asimakopoulos AG, Honda M, . 2018. Advanced data mining approaches in the assessment of urinary concentrations of bisphenols, chlorophenols, parabens and benzophenones in Brazilian children and their association to DNA damage. Environ Int 116:269–277. 10.1016/j.envint.2018.04.023.29704805
Rodwell DE, Wilson RD, Nemec MD, . 1989. Teratogenic assessment of 2,4-dichlorophenol in Fischer 344 rats. Fundam Appl Toxicol 13:635–640.2620787
Rooney MR, Lutsey PL, Bhatti P, . 2018. Urinary 2,5-dicholorophenol and 2,4-dichlorophenol concentrations and prevalent disease among adults in the National Health and Nutrition Examination Survey (NHANES). Occup Environ Med 10.1136/oemed-2018-105278.
Ruth JH. 1986. Odor thresholds and irritation levels of several chemical substances: A review. Am Ind Hyg Assoc J 47(3):A142–151. 10.1080/15298668691389595.3706135
Sakagami Y, Yamazaki H, Ogasawara N, . 1988. The evaluation of genotoxic activities of disinfectants and their metabolites by umu test. Mutat Res 209(3–4):155–160.3143068
Saracci R, Kogevinas M, Bertazzi PA, . 1991. Cancer mortality in workers exposed to chlorophenoxy herbicides and chlorophenols. Lancet 338(8774):1027–1032.1681353
Schellenberg K, Leuenberger C, Schwarzenbach RP. 1984. Sorption of chlorinated phenols by natural sediments and aquifer materials. Environ Sci Technol 18(9):652–657.
Schmied-Tobies MIH, Murawski A, Schmidt L, . 2021. Pentachlorophenol and nine other chlorophenols in urine of children and adolescents in Germany - Human biomonitoring results of the German Environmental Survey 2014-2017 (GerES V). Environ Res 196:110958. 10.1016/j.envres.2021.110958.33676952
Schummer C, Sadiki M, Mirabel P, . 2006. Analysis of t-butyldimethylsilyl derivatives of chlorophenols in the atmosphere of urban and rural areas in east of France. Chromatographia 63(3–4):189–195. 10.1365/s10337-006-0721-1.
Schwarzenbach RP, Westall J. 1985. Sorption of hydrophobic trace organic compounds in groundwater systems. Water Sci Technol 17(9):39–56.
Schwetz BA, Keeler PA, Gehring PJ. 1974. Effects of purified and commercial grade tetrachlorophenol on rat embryonal and fetal development. Toxicol Appl Pharmacol 28(1):146–150.4851689
Scully FE, Hoigne J. 1987. Rate constants for reactions of singlet oxygen with phenols and other compounds in water. Chemosphere 16:681–694.
Seidler A, Raum E, Arabin B, . 1999. Maternal occupational exposure to chemical substances and the risk of infants small-for-gestational-age. Am J Ind Med 36(1):213–222.10361609
Seuferer SL, Braymer HD, Dunn JJ. 1979. Metabolism of diflubenzuron by soil microorganisms and mutagenicity of the metabolites. Pestic Biochem Physiol 10:174–180.
Seyler DE, East JM, Condie LW, . 1984. The use of in vitro methods for assessing reproductive toxicity. Dichlorophenols. Toxicol Lett 20(3):309–315.6701917
Shafik TM, Sullivan HC, Enos HR. 1973. Multiresidue procedure for halo- and nitrophenols: Measurement of exposure to biodegradable pesticides yielding these compounds as metabolites. J Agric Food Chem 21:295–298.4688914
Shang-Zhis SG. 1983. High-performance liquid chromatographic analysis of chlorophenols in cardboard food containers and related materials. J Chromatogr 267(1):183–189.6630367
Shannon RD, Boardman GD, Dietrich AM, . 1991. Mitochondrial response to chlorophenols as a short-term toxicity assay. Environ Toxicol Chem 10(1):57–66.
Shehata M, Durner J, Thiessen D, . 2012. Induction of DNA double-strand breaks by monochlorophenol isomers and ChKM in human gingival fibroblasts. Arch Toxicol 86(9):1423–1429. 10.1007/s00204-012-0861-z.22614568
Shen SY, Villeneuve DC, Chu I, . 1983. Acute dermal toxicity of tetrachlorophenols in the rat. Bull Environ Contam Toxicol 31(6):680–685.6661582
Shi J, Feng M, Zhang X, . 2013. Acute oral toxicity and liver oxidant/antioxidant stress of halogenated benzene, phenol, and diphenyl ether in mice: A comparative and mechanism exploration. Environ Sci Pollut Res Int 20(9):6138–6149. 10.1007/s11356-013-1622-0.23546852
Shiu WY, Ma KC, Varhanickova D, . 1994. Chlorophenols and alkylphenols: A review and correlation of environmentally relevant properties and fate in an evaluative environment. Chemosphere 29(6):1155–1224.
Shiue I. 2014. Higher urinary heavy metal, phthalate, and arsenic but not parabens concentrations in people with high blood pressure, U.S. NHANES, 2011-2012. Int J Environ Res Public Health 11(6):5989–5999. 10.3390/ijerph110605989.24905244
Shiue I, Hristova K. 2014. Higher urinary heavy metal, phthalate and arsenic concentrations accounted for 3-19% of the population attributable risk for high blood pressure: US NHANES, 2009-2012. Hypertens Res 37(12):1075–1081. 10.1038/hr.2014.121.25077919
Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. Dev Toxicol Environ Sci 2:249–258.
Sithole BB, Williams DT. 1986. Halogenated phenols in water at forty canadian potable water treatment facilities. J Assoc Off Anal Chem 69(5):807–810.3771452
Sittig M. 1985. Chlorophenols. In: Handbook of toxic and hazardous chemicals and carcinogens. 2nd ed. Park Ridge, NJ: Noyes Data Corp., 889.
Smith AE. 1985. Identification of 2,4-dichloroanisole and 2,4-dichlorophenol as soil degradation products of ring-labelled [^14^C]2,4-D. Bull Environ Contam Toxicol 34:150–157.3978252
Sofuni T, Matsuoka A, Sawada M, . 1990. A comparison of chromosome aberration induction by 25 compounds tested by two Chinese hamster cell (CHL and CHO) systems in culture. Mutat Res 241(2):175–214.2345556
Solomon K, Bergman H, Huggett R. 1994. A review and assessment of the ecological risks associated with the use of chlorine dioxide for the bleaching of pulp. Pulp bleaching 1994 international conference. Canadian Pulp & Paper Association. 145–161.
Somani SM, Khalique A. 1982. Distribution and metabolism of 2,4-dichlorophenol in rats. J Toxicol Environ Health 9:889–897.7120515
Somani SM, Smart T, Khalique A. 1984. Metabolism of 2,4-dichlorophenol by isolated perfused rat liver. J Toxicol Environ Health 13:787–798.6492200
Spencer B, Williams RT. 1950. The metabolism of halogenobenzenes: A comparison of the glucuronic acid, ethereal sulphate and mercapturic acid conjugations of chloro-, bromo-, and iodo-benzenes and of the o-, m-, and p-chlorophenols: Biosynthesis of o-, m-, and p-chlorophenylglucuronides. Biochem J 47:279–284.14800881
Staples CA, Werner A, Hoogheem T. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
Steiert JG, Crawford RL. 1985. Microbial degradation of chlorinated phenols. Trends Biotechnol 3(12):1986).
Steiert JG, Pignatello JJ, Crawford RL. 1987. Degradation of chlorinated phenols by a pentachlorophenol-degrading bacterium. Appl Environ Microbial 53:907–910.
Stockdale M, Selwyn MJ. 1971. Effects of ring substituents on the activity of phenols as inhibitors and uncouplers of mitochondrial respiration. Eur J Biochem 21(4):565–574.4255574
Stoner GD, Conran PB, Greisiger EA, . 1986. Comparison of two routes of chemical administration on the lung adenoma response in strain A/J mice. Toxicol Appl Pharmacol 82:19–31.3945940
Strobel K, Grummt T. 1987. Aliphatic and aromatic halocarbons as potential mutagens in drinking water. Part II. Chlorinated phenols. Toxicol Environ Chem 14:143–156.
Stryer L. 1988. Oxidative phosphorylation. In: Biochemistry. 3rd ed. New York, NY: Freeman and Co., 397–426.
Sugiura K, Aoki M, Kaneki S, . 1984. Fate of 2,4,6-trichlorophenol, pentachlorophenol, p-chlorobiphenyl, and hexachlorobenzene in an outdoor experimental pond: Comparison between observations and predictions based on laboratory data. Arch Environ Contam Toxicol 13:745–758.
Sutton PA, Barker JF. 1985. Migration and attenuation of selected organics in a sandy aquifer - A natural gradient experiment. Ground Water 23:l0–16.
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Contr Fed 53:1503–1518.
Tegethoff K, Herbold BA, Bomhard EM. 2000. Investigations on the mutagenicity of 1,4-dichlorobenzene and its main metabolite 2,5-dichlorophenol in vivo and in vitro. Mutat Res 470(2):161–167.11027971
Themel K, Sparling R, Oleszkiewicz J. 1996. Anaerobic dehalogenation of 2-chlorophenol by mixed bacterial cultures in absence methanogenesis. Environ Technol 17:869–875.
Tratnyek PG, Hoigne J. 1991. Oxidation of substituted phenols in the environment: A QSAR analysis of rate constants for reaction with singlet oxygen. Environ Sci Technol 25:1596–1604.
TRI20. 2021. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. November 8, 2021.
Truffin D, Garcon G, Hannothiaux MH, . 2003. Involvement of oxidative sress in the toxicity of 4-monochlorophenol in Hep G2 cells in culture. J Appl Toxicol 23(2):109–114. 10.1002/jat.895.12666155
Twum C, Wei Y. 2011. The association between urinary concentrations of dichlorophenol pesticides and obesity in children. Rev Environ Health 26(3):215–219.22206198
USGS. 1998a. Water quality in the Western Lake Michigan drainages. Denver, CO: U.S. Geological Survey. Circular 1156. https://pubs.er.usgs.gov/publication/cir1156. November 11, 2021.
USGS. 1998b. Water quality in the Lower Susquehanna River Basin. Denver, CO: U.S. Geological Survey. Circular 1168. https://pubs.usgs.gov/circ/circ1168/circ1168.pdf. November 11, 2021.
Vaishnav DD, Korthals ET. 1988. Comparison of chemical biodegradation rates in BOD dilution and natural waters. Bull Environ Contam Toxicol 41:291–298.3207911
Valencia R, Mason JM, Woodruff RC, . 1985. Chemical mutagenesis testing in Drosophila. III. Results of 48 coded compounds tested for the National Toxicology Program. Environ Mutagen 7:325–348.3930234
Valo R, Kitunen V, Salkinjoa-Salonen M, . 1984. Chlorinated phenols as contaminants of soil and water in the vicinity of two Finnish sawmills. Chemosphere 13(8):835–844.
Veith GD, Macek KJ, Petrocelli SR, . 1980. An evaluation of using partition coefficients and water solubility to estimate bioconcentration factors for organic chemicals in fish. In: Eaton JG, Parrish RP, Hendricks AC, eds. Aquatic toxicology. West Conshohocken, PA: ASTM International, 116–129. 10.1520/STP27411S.
Viau AC, Studak SM, Karasek FW. 1984. Comparative analysis of hazardous compounds on fly-ash from municipal waste incineration by gas chromatography/mass spectrometry. Can J Chem 62:2140–2145.
Vindenes HK, Svanes C, Lygre SHL, . 2021. Exposure to environmental phenols and parabens, and relation to body mass index, eczema and respiratory outcomes in the Norwegian RHINESSA study. Environ Health 20(1):81. 10.1186/s12940-021-00767-2.34256787
Vlastos D, Antonopoulou M, Konstantinou I. 2016. Evaluation of toxicity and genotoxicity of 2-chlorophenol on bacteria, fish and human cells. Sci Total Environ 551–552:649–655. 10.1016/j.scitotenv.2016.02.043.
Wang YJ, Lin JK. 1995. Estimation of selected phenols in drinking water with in situ acetylation and study on the DNA damaging properties of polychlorinated phenols. Arch Environ Contam Toxicol 28(4):537–542.7755407
Wang N, Wang Y, Zhang H, . 2020. Association of bone mineral density with nine urinary personal care and consumer product chemicals and metabolites: A national-representative, population-based study. Environ Int 142:105865. 10.1016/j.envint.2020.105865.32585503
Wang Z, Liu Y, Li T, . 2021. Wood preservatives in children’s wooden toys from China: Distribution, migration, oral exposure, and risk assessment. Ecotoxicol Environ Saf 209:111786. 10.1016/j.ecoenv.2020.111786.33340956
Watkins DJ, Ferguson KK, Anzalota Del Toro LV, . 2015. Associations between urinary phenol and paraben concentrations and markers of oxidative stress and inflammation among pregnant women in Puerto Rico. Int J Environ Health Res 218(2):212–219. 10.1016/j.ijheh.2014.11.001.
Wegman RCC, Van Den Broek HH. 1983. Chlorophenols in river sediment in the Netherlands. Water Res 17(2):227–230.
Wei Y, Zhu J. 2016a. Associations between urinary concentrations of 2,5-dichlorophenol and metabolic syndrome among non-diabetic adults. Environ Sci Pollut Res Int 23(1):581–588. 10.1007/s11356-015-5291-z.26330318
Wei Y, Zhu J. 2016b. Urinary concentrations of 2,5-dichlorophenol and diabetes in US adults. J Expo Sci Environ Epidemiol 26(3):329–333. 10.1038/jes.2015.19.25827312
Wei Y, Zhu J, Nguyen A. 2014. Urinary concentrations of dichlorophenol pesticides and obesity among adult participants in the U.S. National Health and Nutrition Examination Survey (NHANES) 2005-2008. Int J Hyg Environ Health 217(2–3):294–299. 10.1016/j.ijheh.2013.07.003.23899931
Wei D, Dong H, Wu N, . 2016. A fluorescence approach to assess the production of soluble microbial products from aerobic granular sludge under the stress of 2,4-dichlorophenol. Sci Rep 6:24444. 10.1038/srep24444.27075778
Weinbach EC, Garbus J. 1965. The interaction of uncoupling phenols with mitochondria and with mitochondrial protein. Biol Chem 240(4):1811–1819.
Welch BM, Keil AP, Bommarito PA, . 2021. Longitudinal exposure to consumer product chemicals and changes in plasma oxylipins in pregnant women. Environ Int 157:106787. 10.1016/j.envint.2021.106787.34314981
WHO. 1989. Chlorophenols other than pentachlorophenol. Environmental Health Criteria 93. Geneva, Switzerland: World Health Organization. http://wedocs.unep.org/handle/20.500.11822/29407. March 2, 2020.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality: Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wieser M, Wagner B, Eberspacher J, . 1997. Purification and characterization of 2,4,6-trichlorophenol-4- monooxygenase, a dehalogenating enzyme form Azotobacter sp. Strain GP1. J Bacteriol 179(1):202–208.8981999
WIL Research Laboratories. 1982. Acute oral toxicity study in Fischer 344 female rats with 2,4-dichlorophenol. Cincinnati, OH: Wil Research Laboratories, Inc. Project #WlL-22001.
Williams DT, LeBel GL, Junkins E. 1984. A comparison of organochlorine residues in human adipose tissue autopsy samples from two Ontario municipalities. J Toxicol Environ Health 13(1):19–29. 10.1080/15287398409530478.6716511
Wolff MS, Teitelbaum SL, McGovern K, . 2015. Environmental phenols and pubertal development in girls. Environ Int 84:174–180. 10.1016/j.envint.2015.08.008.26335517
Wolff MS, Pajak A, Pinney SM, . 2017. Associations of urinary phthalate and phenol biomarkers with menarche in a multiethnic cohort of young girls. Reprod Toxicol 67:56–64. 10.1016/j.reprotox.2016.11.009.27851993
Woods SL, Ferguson JF, Benjamin MM. 1989. Characterization of chlorophenol and chloromethoxybenzene biodegradation during anaerobic treatment. Environ Sci Technol 23(1):62–68.
Wu B, Jiang Y, Jin X, . 2020. Using three statistical methods to analyze the association between exposure to 9 compounds and obesity in children and adolescents: NHANES 2005-2010. Environ Health 19(1):94. 10.1186/s12940-020-00642-6.32867766
Xiao F, Zhang X, Zhai H, . 2012. New halogenated disinfection byproducts in swimming pool water and their permeability across skin. Environ Sci Technol 46(13):7112–7119. 10.1021/es3010656.22697042
Xie Y, Jiang L, Qiu J, . 2019. A comparative evaluation of the immunotoxicity and immunomodulatory effects on macrophages exposed to aromatic trihalogenated DBPs. Immunopharmacol Immunotoxicol 41(2):319–326. 10.1080/08923973.2019.1608444.31046488
Xu X, Nembhard WN, Kan H, . 2011. Urinary trichlorophenol levels and increased risk of attention deficit hyperactivity disorder among US school-aged children. Occup Environ Med 68(8):557–561. 10.1136/oem.2010.063859.21540483
Yamaguchi F, Tsutsui T. 2003. Cell-transforming activity of fourteen chemical agents used in dental practice in Syrian hamster embryo cells. J Pharmacol Sci 93(4):497–500.14737023
Yang X, Ou W, Zhao S, . 2021. Human transthyretin binding affinity of halogenated thiophenols and halogenated phenols: An in vitro and in silico study. Chemosphere 280:130627. 10.1016/j.chemosphere.2021.130627.33964751
Ye X, Kuklenyik Z, Needham LL, . 2006. Measuring environmental phenols and chlorinated organic chemicals in breast milk using automated on-line column-switching-high performance liquid chromatography-isotope dilution tandem mass spectrometry. J Chromatogr B Analyt Technol Biomed Life Sci 831(1–2):110–115. 10.1016/j.jchromb.2005.11.050.
Yoshida M, Sunaga M, Hara I. 1986. Urinary metabolite levels in workers exposed to chlorobenzene. Ind Health 24(4):255–258.3818367
Yoshida T, Andoh K, Fukuhara M. 2002. Urinary 2,5-dichlorophenol as biological index for p-dichlorobenzene exposure in the general population. Arch Environ Contam Toxicol 43(4):481–485. 10.1007/s00244-002-1228-x.12399920
Yu C, Wang C, Lu Z, . 2019. The endocrine-disrupting potential of four chlorophenols by in vitro and in silico assay. Chemosphere 218:941–947. 10.1016/j.chemosphere.2018.11.199.30609499
Zeiger E. 1990. Mutagenicity of 42 chemicals in Salmonella. Environ Mol Mutagen 16 (suppl 18):32–54. 10.1002/em.2850160504.
Zeiger E, Anderson B, Haworth S, . 1988. Salmonella mutagenicity tests. IV. Results from the testing of 300 chemicals. Environ Mol Mutagen 11(suppl 12):1–158.
Zeiger E, Anderson B, Haworth S, . 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 21:2–141.
Zendehdel R, Tayefeh-Rahimian R, Kabir A. 2014. Chronic exposure to chlorophenol related compounds in the pesticide production workplace and lung cancer: a meta-analysis. Asian Pac J Cancer Prev 15(13):5149–5153.25040966
Zhang Y, Yang DJ, Fang CR. 1997. Monitoring of organochlorine pesticide residues-the GEMS/food program in China. Biomed Environ Sci 10(1):102–106.9099432
Zhu Y, Xu G, Wang X, . 2021. Passive sampling of chlorophenols in water and soils using diffusive gradients in thin films based on β-cyclodextrin polymers. Sci Total Environ:150739. 10.1016/j.scitotenv.2021.150739.34619202