# VERSION HISTORY

Date | Description
June 2022 | Final toxicological profile released
July 2021 | Draft for public comment toxicological profile released
July 1999 | Final toxicological profile released