# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding chlorophenols in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for chlorophenols.

Table 7-1 Regulations and Guidelines Applicable to Chlorophenols

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated/Not derived | IRIS, 1988, 1990, 2002a, 2002b, 2002c, 2021
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | | EPA 2018a
EPA | 2-CP | 0.5 mg/L | EPA 2018a
EPA | 2,4-DCP | 0.03 mg/L | EPA 2018a
EPA | 2,4,6-TCP | 0.03 mg/L | EPA 2018a
EPA | 10-Day health advisory (10-kg child) | | EPA 2018a
EPA | 2-CP | 0.5 mg/L | EPA 2018a
EPA | 2,4-DCP | 0.03 mg/L | EPA 2018a
EPA | 2,4,6-TCP | 0.03 mg/L | EPA 2018a
EPA | DWEL | | EPA 2018a
EPA | 2-CP | 0.2 mg/L | EPA 2018a
EPA | 2,4-DCP | 0.1 mg/L | EPA 2018a
EPA | 2,4,6-TCP | 0.01 mg/L | EPA 2018a
EPA | Lifetime health advisory | | EPA 2018a
EPA | 2-CP | 0.04 mg/L | EPA 2018a
EPA | 2,4-DCP | 0.02 mg/L | EPA 2018a
EPA | 2,4,6-TCP | No data | EPA 2018a
EPA | 10^−4^ Cancer risk | | EPA 2018a
EPA | 2-CP | No data | EPA 2018a
EPA | 2,4-DCP | No data | EPA 2018a
EPA | 2,4,6-TCP | 0.3 mg/L | EPA 2018a
EPA | National primary drinking water regulations | Not listed | EPA 2009
EPA | RfD | | IRIS 2021
EPA | 2-CP | 5×10^−3^ mg/kg/day | IRIS 2002a
EPA | 2,4-DCP | 3×10^−3^ mg/kg/day | IRIS 2002b
EPA | 2,4,5-TCP | 1×10^−1^ mg/kg/day | IRIS 2002c
EPA | 2,3,4,6-TeCP | 3×10^−2^ mg/kg/day | IRIS 1988
EPA | Provisional RfD - Chronic
EPA | 2,4,6-TCP | 1×10^−3^ mg/kg/day | EPA 2007a
EPA | Provisional RfD - Subchronic
EPA | 2-CP | 8×10^−3^ mg/kg/day | EPA 2007b
EPA | 2,4-DCP | 2×10^−2^ mg/kg/day | EPA 2007c
EPA | 2,4,5-TCP | 3 ×10^−1^ mg/kg/day | EPA 2007d
WHO | Drinking water quality guidelines | | WHO 2017
WHO | Guideline value^a^ | | WHO 2017
WHO | 2,4,6-TCP | 0.2 mg/L | WHO 2017
FDA | Substances Added to Food | No data^b^ | FDA 2021
Cancer
HHS | Carcinogenicity classification
HHS | 2,4,6-TCP | Reasonably anticipated to be a human carcinogen (based on sufficient evidence in animal bioassays) | NTP 2021
EPA | Carcinogenicity classification | | IRIS 2021
EPA | 2,4,6-TCP | Probably carcinogenic to humans—Group B2 (based on sufficient evidence in animal bioassays) | IRIS 1990
EPA | Provisional carcinogenicity classification^c^ | | EPA 2007b, EPA 2007d
EPA | 2,4-DCP | Not likely to be carcinogenic to humans via oral exposure; inadequate information to assess the carcinogenic potential to humans via inhalation exposure | EPA 2007c
IARC | Carcinogenicity classification
IARC | Polychlorophenols or their sodium salts (combined exposures) | Possibly carcinogenic to humans—Group 2B (based on sufficient evidence in animal bioassays) | IARC 1999
IARC | 2,4-DCP | Evidence suggesting lack of carcinogenicity of 2,4-DCP in experimental animals
IARC | 2,4,5-TCP | Inadequate evidence in experimental animals for carcinogenicity
IARC | 2,4,6-TCP | Possibly carcinogenic to humans—Group 2B (based on sufficient evidence in animal bioassays) | IARC 2019
Occupational
ACGIH | TLV (TWA) | No data | ACGIH 2019
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction | No data | OSHA 2021a, 2021b, 2021c
NIOSH | REL (up to 10-hour TWA) | No data | NIOSH 2018
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018b
DOE | PACs-air^d^ | | DOE 2018a
DOE | 2-CP | | DOE 2018a
DOE | PAC-1 | 2.3 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 25 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 150 mg/m^3^ | DOE 2018a
DOE | 3-CP | | DOE 2018a
DOE | PAC-1 | 2.1 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 23 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 140 mg/m^3^ | DOE 2018a
DOE | 4-CP | | DOE 2018a
DOE | PAC-1 | 1.5 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 17 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 99 mg/m^3^ | DOE 2018a
DOE | 2,4-DCP | | DOE 2018a
DOE | PAC-1 | 0.2 ppm | DOE 2018a
DOE | PAC-2 | 2 ppm | DOE 2018a
DOE | PAC-3 | 20 ppm | DOE 2018a
DOE | 2,6-DCP | | DOE 2018a
DOE | PAC-1 | 8.8 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 97 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 580 mg/m^3^ | DOE 2018a
DOE | 2,3,6-TCP | | DOE 2018a
DOE | PAC-1 | 1.8 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 20 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 120 mg/m^3^ | DOE 2018a
DOE | 2,4,5-TCP | | DOE 2018a
DOE | PAC-1 | 2.5 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 27 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 160 mg/m^3^ | DOE 2018a
DOE | 2,4,6-TCP | | DOE 2018a
DOE | PAC-1 | 2.5 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 27 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 160 mg/m^3^ | DOE 2018a

a Available data inadequate to permit derivation of health-based guideline values for 2-CP and 2,4-DCP.

b The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

c For 2-CP and 2,4,5-TCP, available data were deemed inadequate for assessment of human carcinogenic potential.

d Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; CP = chlorophenol; DCP = dichlorophenol; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TCP = trichlorophenol; TeCP = tetrachlorophenol; TLV = threshold limit value; TWA = time-weighted average; WHO = World Health Organization