# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of the chlorophenols is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of the chlorophenols is located in Table 4-2. Except for 2-CP, which is a liquid at room temperature, all of the chlorophenols discussed in this profile are solids at room temperature.

Table 4-1 Chemical Identity of Chlorophenol Compounds

Characteristic | Information
Chemical name | 2-Chlorophenol | 4-Chlorophenol | 2,3-Dichlorophenol | 2,4-Dichlorophenol
Synonym(s) and registered trade name(s) | 2-CP, 2-chloro-1-hydroxybenzene, 2-hydroxychlorobenzene, o-chlorophenol | 4-CP, 4-chloro-1-hydroxybenzene, 4-hydroxychlorobenzene, p-chlorophenol | 2,3-DCP | 2,4-DCP, 2,4-dichlorohydroxybenzene
Chemical formula | C_6_H_5_ClO | C_6_H_5_ClO | C_6_H_4_Cl_2_O | C_6_H_4_Cl_2_O
Chemical structure | Chemical structure | Chemical structure | Chemical structure | Chemical structure
CAS Registry Number | 95-57-8 | 106-48-9 | 576-24-9 | 120-83-2

Characteristic | Information
Chemical name | 2,5-Dichlorophenol | 3,4-Dichlorophenol | 3,5-Dichlorophenol
Synonym(s) and registered trade name(s) | 2,5-DCP, 2,5-dichloro-1-hydroxybenzene, 1-Hydroxy-2,5-dichlorobenzene | 3,4-DCP, 4,5-dichlorophenol | 3,5-DCP, 1-Hydroxy-3,5-dichlorobenzene
Chemical formula | C_6_H_4_Cl_2_O | C_6_H_4_Cl_2_O | C_6_H_4_Cl_2_O
Chemical structure | Chemical structure | Chemical structure | Chemical structure
CAS Registry Number | 583-78-8 | 95-77-2 | 591-35-5

Characteristic | Information
Chemical name | 2,3,4-Trichlorophenol | 2,4,5-Trichlorophenol | 2,4,6-Trichlorophenol
Synonym(s) and registered trade name(s) | 2,3,4-TCP | 2,4,5-TCP | 2,4,6-TCP, Omal, Phenachlor
Chemical formula | C_6_H_3_Cl_3_O | C_6_H_3_Cl_3_O | C_6_H_3_Cl_3_O
Chemical structure | [image] | Chemical structure | Chemical structure
CAS Registry Number | 15950-66-0 | 95-95-4 | 88-06-2

Characteristic | Information
Chemical name | 2,3,4,5-Tetrachlorophenol | 2,3,4,6-Tetrachlorophenol | 2,3,5,6-Tetrachlorophenol
Synonym(s) and registered trade name(s) | 2,3,4,5-TeCP | 2,3,4,6-TeCP | 2,3,5,6-TeCP
Chemical formula | C_6_H_2_Cl_4_O | C_6_H_2_Cl_4_O | C_6_H_2_Cl_4_O
Chemical structure | [image] | Chemical structure | Chemical structure
CAS Registry Number | 4901-51-3 | 58-90-2 | 935-95-5

CAS = Chemical Abstracts Service

Sources: NLM (2003a, 2003b, 2003c, 2009a, 2009b, 2009c, 2015, 2019, 2020a, 2020b, 2020c, 2020d, 2020e)

Table 4-2 Physical and Chemical Properties of Chlorophenol Compounds^a^

Characteristic | 2-Chlorophenol | 4-Chlorophenol | 2,3-Dichlorophenol | 2,4-Dichlorophenol
Molecular weight | 128.56 | 128.56 | 163.00 | 163.00
Color | Light amber | White to pink crystals | Brown | White
Physical state | Liquid | Solid | Solid | Solid
Melting point | 9.3°C | 43.2–43.7°C | 58°C | 45°C
Boiling point | 174.9°C | 220°C | 206°C | 210°C
Density at 20°C | 1.2634 | 1.2238 at 78°C/4°C | No data | 1.383 at 60°C/25°C
Odor | Unpleasant, medicinal odor | Medicinal odor | No data | Strong medicinal odor
Odor threshold:
Water at 30°C^b^ | 0.33 μg/L | 33 μg/L | No data | 0.65 μg/L
Air^c^ | 0.0189 mg/m^3^ | 0.0189 mg/m^3^ | No data | 1.40 mg/m^3^
Solubility:
Water at 25°C^d^ | 20,000 ppm | 27,000 ppm at pH 5.1 | 8,215 ppm at pH 4.9 | 4,500 ppm
Organic solvents | Acetone, alcohol, benzene | Alcohol, glycerol, ether, chloroform, fixed and volatile oils, benzene | Alcohol, ethyl ether, benzene, ligroin | Alcohol, carbon tetrachloride, ethyl ether, benzene, chloroform
Partition coefficients:
Log K_ow_ | 2.17^d^ | 2.4^d^ | 2.84 | 3.06
Log K_oc_^d^ | 1.25–3.7 | 1.2–2.7 | 2.63 | 2.42–3.98
Vapor pressure at 25°C^d^ | 0.99 mmHg at 25°C | 0.23 mmHg at 25°C | 0.058 mmHg at 25°C^a^ | 0.14 mmHg at 25°C
Henry’s law constant at 25°C^d^ | 6.8×10^−6^ atm-m^3^/mol | 9.2×10^−7^ atm-m^3^/mol | 1.6×10^−6^ atm-m^3^/mol (calculated) | 4.3×10^−6^ atm-m^3^/mol
pKa^f^ | 8.52 | 9.37 | 7.71 | 7.90
Autoignition temperature | No data | No data | No data | No data
Flashpoint | 64°C | 121°C | No data | 114°C
Flammability limits | No data | No data | No data | No data
Conversion factors | 1 ppm=5.3 mg/m^3^ at 25°C, 1 atm | 1 ppm=5.3 mg/m^3^ at 25°C, 1 atm | 1 ppm=6.7 mg/m^3^ at 25°C, 1 atm | 1 ppm=6.7 mg/m^3^ at 25°C, 1 atm
Explosive limits | No data | No data | No data | No data

Characteristic | 2,5-Dichlorophenol | 3,4-Dichlorophenol | 3,5-Dichlorophenol
Molecular weight | 163.00 | 163.00 | 163.00
Color | White | Brown or yellow | Pink
Physical state | Solid | Solid | Solid
Melting point | 59°C | 68°C | 68°C
Boiling point | 211°C | 253°C | 233°C
Density at 20°C | No data | No data | No data
Odor | No data | No data | No data
Odor threshold:
Water at 30°C^b^ | 3.3 μg/L | No data | No data
Air^c^ | No data | No data | No data
Solubility:
Water at 25°C^d^ | 2,000 ppm at unknown pH^a^ | 9,256 ppm at pH 5.1 | 7,394 ppm at pH 4.7
Organic solvents | Alcohol, ethyl ether, benzene, petroleum ether | Alcohol, ethyl ether, benzene, petroleum ether | Alcohol, ethyl ether, petroleum ether
Partition coefficients:
Log K_ow_ | 3.06 | 3.33 | 3.62
Log K_oc_ | 2.78 (estimated)^e^ | 2.93 (estimated)^e^ | 3.1 (estimated)^e^
Vapor pressure at 25°C | 0.0562 mmHg at 25°C | 0.00173 mmHg at 25°C (estimated)^e^ | 0.00842 mmHg at 25°C^d^
Henry’s law constant at 25°C | 6.0×10^−6^ atm-m^3^/mol (calculated)^d^ | 3.1×10^−7^ atm-m^3^/mol (estimated)^e^ | 2.4×10^−7^ atm-m^3^/mol (calculated)^d^
pKa^f^ | 7.51 | 8.62 | 8.25
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors | 1 ppm=6.7 mg/m^3^ at 25°C, 1 atm | 1 ppm=6.7 mg/m^3^ at 25°C, 1 atm | 1 ppm=6.7 mg/m^3^ at 25°C, 1 atm
Explosive limits | No data | No data | No data

Characteristic | 2,3,4-Trichlorophenol | 2,4,5-Trichlorophenol | 2,4,6-Trichlorophenol
Molecular weight | 197.45 | 197.46 | 197.45
Color | Peach | Gray | Yellow
Physical state | Solid | Solid | Solid
Melting point | 83.5°C | 67°C | 69°C
Boiling point | 252°C | 235°C | 246°C
Density at 20°C | No data | 1.678 at 25°C/4°C | 1.4901
Odor | Strong disinfectant odor | Strong phenolic odor | Strong phenolic odor
Odor threshold:
Water at 30°C^b^ | No data | 11 μg/L | 100 μg/L
Air^c^ | No data | No data | No data
Solubility:
Water at 25°C^d^ | 915 ppm at pH 5.1 | 948 ppm at pH 5.1 | 434 ppm at pH 5.1
Organic solvents | No data | Acetone, benzene, carbon tetrachloride, ether, denatured alcohol, methanol, liquid petroleum, toluene | Acetone, benzene, carbon tetrachloride, diacetone alcohol, methanol, Stoddard solvent, toluene, turpentine, ether
Partition coefficients:
Log K_ow_^d^ | 3.80 | 3.72 | 3.69
Log K_oc_^d^ | No data | 2.55–3.98 | 1.94–3.34
Vapor pressure at 25°C^d^ | 0.0027 mmHg at 25°C (estimated) | 0.05 mmHg at 25°C | 0.03 mmHg at 25°C
Henry’s law constant at 25°C | 3.9×10^−6^ atm-m^3^/mol^d^ | 2.21×10^−6^ atm-m^3^/mol (estimated)^e^ | 6.8×10^−6^ atm-m^3^/mol^d^
pKa^f^ | 6.97 | 6.72 | 5.99
Autoignition temperature | No data | No data | No data
Flashpoint | 62°C | No data | 64°C
Flammability limits | No data | No data | No data
Conversion factors | 1 ppm=8.1 mg/m^3^ at 25°C, 1 atm | 1 ppm=8.1 mg/m^3^ at 25°C, 1 atm | 1 ppm=8.1 mg/m^3^ at 25°C, 1 atm
Explosive limits | No data | No data | No data

Characteristic | 2,3,4,5-Tetrachlorophenol | 2,3,4,6-Tetrachlorophenol | 2,3,5,6-Tetrachlorophenol
Molecular weight | 231.89 | 231.89 | 231.89
Color | No data | Light brown | No data
Physical state | Solid | Solid | Solid
Melting point | 116–117°C | 70°C | 115°C
Boiling point | Sublimes | 64°C | No data
Density at 20°C | No data | 1.83 at 25°C/4°C | No data
Odor | No data | Strong odor | No data
Odor threshold:
Water at 30°C^b^ | No data | 915 μg/L | No data
Air^c^ | No data | No data | No data
Solubility:
Water at 25°C^d^ | 166 ppm at pH 4.9 | 183 ppm at pH 5.3 | 100 ppm at pH 5.0
Organic solvents | Alcohol | Acetone, alcohol, benzene, chloroform, ligroin | Benzene
Partition coefficients:
Log K_ow_^d^ | 4.8 | 4.45 | 4.9
Log K_oc_^d^ | 2.9–4.14 | 3.2–4.21 | No data
Vapor pressure at 25°C^d^ | 0.0059 mmHg at 25°C | 0.0059 mmHg at 25°C | 0.0059 mmHg at 25°C
Henry’s law constant at 25°C | 3.5×10^−7^ atm-m^3^/mol (estimated)^e^ | 4.3×10^−6^ atm-m^3^/mol^d^ | 5.1×10^−6^ atm-m^3^/mol^d^
pKa^f^ | 5.64 | 5.22 | 5.03
Autoignition temperature | No data | No data | No data
Flashpoint | 121°C | 114°C | No data
Flammability limits | No data | No data | No data
Conversion factors | 1 ppm=9.5 mg/m^3^ at 25°C, 1 atm | 1 ppm=9.5 mg/m^3^ at 25°C, 1 atm | 1 ppm=9.5 mg/m^3^ at 25°C, 1 atm
Explosive limits | No data | No data | No data

a Data from NLM (2003a, 2003b, 2003c, 2009a, 2009b, 2009c, 2015, 2019, 2020a, 2020b, 2020c, 2020d, 2020e) except where noted.

b Hoak 1957.

c Ruth 1986.

d Shiu et al. 1994.

e EPA 2012.

f Muller and Caillard 2011.