# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR CHLOROPHENOLS

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to chlorophenols.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for chlorophenols. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of chlorophenols have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of chlorophenols are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals; Potential for human exposure; Releases to the environment; Air; Water; Soil; Environmental fate; Transport and partitioning; Transformation and degradation; Environmental monitoring; Air; Water; Sediment and soil; Other media; Biomonitoring; General populations; Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for chlorophenols released for public comment in 2021; thus, the literature search was restricted to studies published between January 2018 and November 2021. The following main databases were searched in November 2021:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for chlorophenols. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to chlorophenols were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
11/2021 | ((Chlorophenols[mh:noexp] AND (chlorophenols/to[mh] OR chlorophenols/ae[mh] OR chlorophenols/po[mh] OR chlorophenols/pk[mh] OR chlorophenols/bl[mh] OR chlorophenols/cf[mh] OR chlorophenols/ur[mh] OR chlorophenols/ai[mh] OR (“chlorophenols”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“chlorophenols”[mh] AND toxicokinetics[mh:noexp]) OR (“chlorophenols”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“chlorophenols”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“chlorophenols/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“chlorophenols”[majr] AND cancer[sb]))) OR ((“1,3,5-Trichloro-2-hydroxybenzene”[tw] OR “1,3-Dichloro-4-hydroxybenzene”[tw] OR “1-Chloro-2-hydroxybenzene”[tw] OR “1-Hydroxy-2,3,4,6-tetrachlorobenzene”[tw] OR “1-Hydroxy-2,4-dichlorobenzene”[tw] OR “2,3,4,5-Tetrachlorophenate”[tw] OR “2,3,4,5-Tetrachlorophenol”[tw] OR “2,3,4,6-Tetrachlorophenate”[tw] OR “2,3,4,6-Tetrachlorophenol”[tw] OR “2,3,4,6-Tetrachlorphenol”[tw] OR “2,3,4,6-tetraclorofenol”[tw] OR “2,3,5,6-Tetrachlorophenate”[tw] OR “2,3,5,6-Tetrachlorophenol”[tw] OR “2,4,-Dichlorophenol”[tw] OR “2,4,5,6-Tetrachlorophenol”[tw] OR “2,4,5-Trichlorophenol”[tw] OR “2,4,5-Trichlorphenol”[tw] OR “2,4,5-triclorofenol”[tw] OR “2,4,6-Trichlorfenol”[tw] OR “2,4,6-Trichlorophenol”[tw] OR “2,4,6-Trichlorphenol”[tw] OR “2,4,6-triclorofenol”[tw] OR “2,4-Dichlorohydroxybenzene”[tw] OR “2,4-Dichlorophenic acid”[tw] OR “2,4-Dichlorophenol”[tw] OR “2,4-Dichlorphenol”[tw] OR “2,4-diclorofenol”[tw] OR “2-Chloro-1-hydroxybenzene”[tw] OR “2-Chlorophenol”[tw] OR “2-Chlorphenol”[tw] OR “2-clorofenol”[tw] OR “2-Hydroxychlorobenzene”[tw] OR “2-Monochlorophenol”[tw] OR “2.4,5-Trichlorophenic acid”[tw] OR “4,6-Dichlorophenol”[tw] OR “4-Chloro-1-hydroxybenzene”[tw] OR “4-Chlorophenol”[tw] OR “4-Chlorphenol”[tw] OR “4-clorofenol”[tw] OR “4-Hydroxychlorobenzene”[tw] OR “4-Monochlorophenol”[tw] OR “Chlorophenol”[tw] OR “Chlorophenol, 2-”[tw] OR “Chlorophenol, 4-”[tw] OR “Chlorophenol, o-”[tw] OR “Chlorophenol, p-”[tw] OR “Chlorophenols”[tw] OR “Chlorophenols, liquid”[tw] OR “Chlorophenols, solid”[tw] OR “Collunosol”[tw] OR “Dichlorophenol (2,4-)”[tw] OR “Dichlorophenol, 2,4-”[tw] OR “Monochlorophenol (mixed isomers)”[tw] OR “Monochlorophenols (all isomers)”[tw] OR “Monochlorophenols (total)”[tw] OR “o,p-Dichlorophenol”[tw] OR “o-Chlorophenic acid”[tw] OR “o-Chlorophenol”[tw] OR “o-Chlorphenol”[tw] OR “ortho,para-Dichlorophenol”[tw] OR “ortho-Chlorophenol”[tw] OR “p-Chlorophenic acid”[tw] OR “p-Chlorophenol”[tw] OR “Parachlorophenol”[tw] OR “Phenachlor”[tw] OR “Phenaclor”[tw] OR “Phenol, 2,3,4,5-tetrachloro-”[tw] OR “Phenol, 2,3,4,6-tetrachloro-”[tw] OR “Phenol, 2,3,5,6-tetrachloro-”[tw] OR “Phenol, 2,4,5-trichloro-”[tw] OR “Phenol, 2,4,6-trichloro-”[tw] OR “Phenol, 2,4-dichloro-”[tw] OR “Phenol, 2-chloro-”[tw] OR “Phenol, 4-chloro-”[tw] OR “Phenol, chloro-”[tw] OR “Phenol, o-chloro-”[tw] OR “Phenol, p-chloro-”[tw] OR “Phenol, tetrachloro-”[tw] OR “Pine-O Disinfectant”[tw] OR “Tetrachlorophenol”[tw] OR “Tetrachlorophenol, 2,3,4,5-”[tw] OR “Tetrachlorophenol, 2,3,4,6-”[tw] OR “Tetrachlorophenol, 2,3,5,6-”[tw] OR “Tetrachlorophenol, isomer”[tw] OR “Tetrachlorophenols”[tw] OR “Trichlorophenol (2,4,5-)”[tw] OR “Trichlorophenol, 2,4,5-”[tw] OR “Trichlorophenol, 2,4,6-”[tw] OR “2,4,5-TCP”[tw] OR “2,4,6-T”[tw] OR “2,4,6-TCP”[tw] OR “2,4-DCP”[tw] OR “Applied 3-78”[tw] OR “BTS 45186”[tw] OR “Dowicide 2”[tw] OR “Dowicide 2S”[tw] OR “Dowicide 6”[tw] OR “Preventol I”[tw] OR “Septi-Kleen”[tw] OR “2,3-Dichlorophenol”[tw] OR “2,3-Dichlorphenol”[tw] OR “Dichlorophenol, 2,3-”[tw] OR “Phenol, 2,3-dichloro-”[tw] OR “1-Hydroxy-2,5-dichlorobenzene”[tw] OR “2,5-Dichlorophenol”[tw] OR “2,5-Dichlorphenol”[tw] OR “Dichlorophenol, 2,5-”[tw] OR “PHENOL, 1,4-DICHLORO-”[tw] OR “Phenol, 2,5-dichloro-”[tw] OR “1,4-DICHLOROPHENOL”[tw] OR “3,4-Dichlorophenol”[tw] OR “3,4-Dichlorphenol”[tw] OR “4,5-Dichlorophenol”[tw] OR “Dichlorophenol, 3,4-”[tw] OR “Phenol, 3,4-dichloro-”[tw] OR “1-Hydroxy-3,5-dichlorobenzene”[tw] OR “3,5-Dichlorophenol”[tw] OR “3,5-Dichlorphenol”[tw] OR “Dichlorophenol, 3,5-”[tw] OR “Phenol, 3,5-dichloro-”[tw] OR “2,3,4-Trichlorophenol”[tw] OR “Phenol, 2,3,4-trichloro-”[tw] OR “Trichlorophenol, 2,3,4-”[tw]) NOT medline[sb])) AND (2018:3000[dp] OR 2019/02/01:3000[edat] OR 2019/02/01:3000[crdt] OR 2019/02/01:3000[mhda])
NTRL
11/2021 | “1,3,5-Trichloro-2-hydroxybenzene” OR “1,3-Dichloro-4-hydroxybenzene” OR “1-Chloro-2-hydroxybenzene” OR “1-Hydroxy-2,3,4,6-tetrachlorobenzene” OR “1-Hydroxy-2,4-dichlorobenzene” OR “2,3,4,5-Tetrachlorophenate” OR “2,3,4,5-Tetrachlorophenol” OR “2,3,4,6-Tetrachlorophenate” OR “2,3,4,6-Tetrachlorophenol” OR “2,3,4,6-Tetrachlorphenol” OR “2,3,4,6-tetraclorofenol” OR “2,3,5,6-Tetrachlorophenate” OR “2,3,5,6-Tetrachlorophenol” OR “2,4,-Dichlorophenol” OR “2,4,5,6-Tetrachlorophenol” OR “2,4,5-Trichlorophenol” OR “2,4,5-Trichlorphenol” OR “2,4,5-triclorofenol” OR “2,4,6-Trichlorfenol” OR “2,4,6-Trichlorophenol” OR “2,4,6-Trichlorphenol” OR “2,4,6-triclorofenol” OR “2,4-Dichlorohydroxybenzene” OR “2,4-Dichlorophenic acid” OR “2,4-Dichlorophenol” OR “2,4-Dichlorphenol” OR “2,4-diclorofenol” OR “2-Chloro-1-hydroxybenzene” OR “2-Chlorophenol” OR “2-Chlorphenol” OR “2-clorofenol” OR “2-Hydroxychlorobenzene” OR “2-Monochlorophenol” OR “2.4,5-Trichlorophenic acid” OR “4,6-Dichlorophenol” OR “4-Chloro-1-hydroxybenzene” OR “4-Chlorophenol” OR “4-Chlorphenol” OR “4-clorofenol” OR “4-Hydroxychlorobenzene” OR “4-Monochlorophenol” OR “Chlorophenol” OR “Chlorophenol, 2-” OR “Chlorophenol, 4-” OR “Chlorophenol, o-” OR “Chlorophenol, p-” OR “Chlorophenols” OR “Chlorophenols, liquid” OR “Chlorophenols, solid” OR “Collunosol” OR “Dichlorophenol (2,4-)” OR “Dichlorophenol, 2,4-” OR “Monochlorophenol (mixed isomers)” OR “Monochlorophenols (all isomers)” OR “Monochlorophenols (total)” OR “o,p-Dichlorophenol” OR “o-Chlorophenic acid” OR “o-Chlorophenol” OR “o-Chlorphenol” OR “ortho,para-Dichlorophenol” OR “ortho-Chlorophenol” OR “p-Chlorophenic acid” OR “p-Chlorophenol” OR “Parachlorophenol” OR “Phenachlor” OR “Phenaclor” OR “Phenol, 2,3,4,5-tetrachloro-” OR “Phenol, 2,3,4,6-tetrachloro-” OR “Phenol, 2,3,5,6-tetrachloro-” OR “Phenol, 2,4,5-trichloro-” OR “Phenol, 2,4,6-trichloro-” OR “Phenol, 2,4-dichloro-” OR “Phenol, 2-chloro-” OR “Phenol, 4-chloro-” OR “Phenol, chloro-” OR “Phenol, o-chloro-” OR “Phenol, p-chloro-” OR “Phenol, tetrachloro-” OR “Pine-O Disinfectant” OR “Tetrachlorophenol” OR “Tetrachlorophenol, 2,3,4,5-” OR “Tetrachlorophenol, 2,3,4,6-” OR “Tetrachlorophenol, 2,3,5,6-” OR “Tetrachlorophenol, isomer” OR “Tetrachlorophenols” OR “Trichlorophenol (2,4,5-)” OR “Trichlorophenol, 2,4,5-” OR “Trichlorophenol, 2,4,6-” OR “2,4,5-TCP” OR “2,4,6-T” OR “2,4,6-TCP” OR “2,4-DCP” OR “Applied 3-78” OR “BTS 45186” OR “Dowicide 2” OR “Dowicide 2S” OR “Dowicide 6” OR “Preventol I” OR “Septi-Kleen” OR “2,3-Dichlorophenol” OR “2,3-Dichlorphenol” OR “Dichlorophenol, 2,3-” OR “Phenol, 2,3-dichloro-” OR “1-Hydroxy-2,5-dichlorobenzene” OR “2,5-Dichlorophenol” OR “2,5-Dichlorphenol” OR “Dichlorophenol, 2,5-” OR “PHENOL, 1,4-DICHLORO-” OR “Phenol, 2,5-dichloro-” OR “1,4-DICHLOROPHENOL” OR “3,4-Dichlorophenol” OR “3,4-Dichlorphenol” OR “4,5-Dichlorophenol” OR “Dichlorophenol, 3,4-” OR “Phenol, 3,4-dichloro-” OR “1-Hydroxy-3,5-dichlorobenzene” OR “3,5-Dichlorophenol” OR “3,5-Dichlorphenol” OR “Dichlorophenol, 3,5-” OR “Phenol, 3,5-dichloro-” OR “2,3,4-Trichlorophenol” OR “Phenol, 2,3,4-trichloro-” OR “Trichlorophenol, 2,3,4-”
Toxcenter
11/2021 | FILE ‘TOXCENTER’ ENTERED AT 15:14:31 ON 01 NOV 2021; CHARGED TO COST=EH038.12.03.LB.04; L1 20852 SEA FILE=TOXCENTER 88-06-2 OR 120-83-2 OR 95-95-4 OR 95-57-8 OR 4901-51-3 OR 935-95-5 OR 58-90-2 OR 106-48-9 OR 25167-80-0 OR 25167-83-3 OR 576-24-9 OR 583-78-8 OR 95-77-2 OR 591-35-5 OR 15950-66-0; L2 17979 SEA FILE=TOXCENTER L1 NOT PATENT/DT; L3 17891 SEA FILE=TOXCENTER L2 NOT TSCATS/FS; L4 1829 SEA FILE=TOXCENTER L3 AND ED>=20190201; DIS TOXQUERY/Q; ACT TOXQUERY/Q; ---------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L35 QUE L33 OR L34; ---------; L36 598 SEA FILE=TOXCENTER L4 AND L35; L37 47 SEA FILE=TOXCENTER L36 AND MEDLINE/FS; L38 551 SEA FILE=TOXCENTER L36 NOT MEDLINE/FS; L39 559 DUP REM L37 L38 (39 DUPLICATES REMOVED); ANSWERS ‘1-559’ FROM FILE TOXCENTER; L*** DEL 47 S L36 AND MEDLINE/FS; L*** DEL 47 S L36 AND MEDLINE/FS; L40 47 SEA FILE=TOXCENTER L39; L*** DEL 551 S L36 NOT MEDLINE/FS; L*** DEL 551 S L36 NOT MEDLINE/FS; L41 512 SEA FILE=TOXCENTER L39; L42 512 SEA FILE=TOXCENTER (L40 OR L41) NOT MEDLINE/FS; D SCAN L42

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
11/2021 | Compounds searched: 88-06-2, 120-83-2, 95-95-4, 95-57-8, 4901-51-3, 935-95-5, 58-90-2, 106-48-9, 25167-80-0, 25167-83-3, 576-24-9, 583-78-8, 95-77-2, 591-35-5, 15950-66-0
NTP
11/2021 | 88-06-2; 120-83-2; 95-95-4; 95-57-8; 4901-51-3; 935-95-5; 58-90-2; 106-48-9; 25167-80-0; 25167-83-3; 576-24-9; 583-78-8; 95-77-2; 591-35-5; 15950-66-0; chlorophenol; dichlorophenol; trichlorophenol; tetrachlorophenol; “1-Hydroxy-3,5-dichlorobenzene” “1-Hydroxy-2,5-dichlorobenzene”
Regulations.gov
11/2021 | 88-06-2; 120-83-2; 95-95-4; 95-57-8; 4901-51-3; 935-95-5; 58-90-2; 106-48-9; 25167-80-0; 25167-83-3; 576-24-9; 583-78-8; 95-77-2; 591-35-5; 15950-66-0; chlorophenol; dichlorophenol; trichlorophenol; tetrachlorophenol; “1-Hydroxy-3,5-dichlorobenzene”; “1-Hydroxy-2,5-dichlorobenzene”
NIH RePORTER
01/2022 | Search Criteria Fiscal Year: Active Projects; Text Search: “1,3,5-Trichloro-2-hydroxybenzene” OR “1,3-Dichloro-4-hydroxybenzene” OR “1-Chloro-2-hydroxybenzene” OR “1-Hydroxy-2,3,4,6-tetrachlorobenzene” OR “1-Hydroxy-2,4-dichlorobenzene” OR “2,3,4,5-Tetrachlorophenate” OR “2,3,4,5-Tetrachlorophenol” OR “2,3,4,6-Tetrachlorophenate” OR “2,3,4,6-Tetrachlorophenol” OR “2,3,4,6-Tetrachlorphenol” OR “2,3,4,6-tetraclorofenol” OR “2,3,5,6-Tetrachlorophenate” OR “2,3,5,6-Tetrachlorophenol” OR “2,4,-Dichlorophenol” OR “2,4,5,6-Tetrachlorophenol” OR “2,4,5-Trichlorophenol” OR “2,4,5-Trichlorphenol” OR “2,4,5-triclorofenol” OR “2,4,6-Trichlorfenol” OR “2,4,6-Trichlorophenol” OR “2,4,6-Trichlorphenol” OR “2,4,6-triclorofenol” OR “2,4-Dichlorohydroxybenzene” OR “2,4-Dichlorophenic acid” OR “2,4-Dichlorophenol” OR “2,4-Dichlorphenol” OR “2,4-diclorofenol” OR “2-Chloro-1-hydroxybenzene” OR “2-Chlorophenol” OR “2-Chlorphenol” OR “2-clorofenol” OR “2-Hydroxychlorobenzene” OR “2-Monochlorophenol” OR “2.4,5-Trichlorophenic acid” OR “4,6-Dichlorophenol” OR “4-Chloro-1-hydroxybenzene” OR “4-Chlorophenol” OR “4-Chlorphenol” OR “4-clorofenol” OR “4-Hydroxychlorobenzene” OR “4-Monochlorophenol” OR “Chlorophenol” OR “Chlorophenol, 2-” OR “Chlorophenol, 4-” OR “Chlorophenol, o-” OR “Chlorophenol, p-” OR “Chlorophenols” OR “Chlorophenols, liquid” OR “Chlorophenols, solid” OR “Collunosol” OR “Dichlorophenol (2,4-)” OR “Dichlorophenol, 2,4-” OR “Monochlorophenol (mixed isomers)” OR “Monochlorophenols (all isomers)” OR “Monochlorophenols (total)” OR “o,p-Dichlorophenol” OR “o-Chlorophenic acid” OR “o-Chlorophenol” OR “o-Chlorphenol” OR “ortho,para-Dichlorophenol” OR “ortho-Chlorophenol” OR “p-Chlorophenic acid” OR “p-Chlorophenol” OR “Parachlorophenol” OR “Phenachlor” OR “Phenaclor” OR “Phenol, 2,3,4,5-tetrachloro-” OR “Phenol, 2,3,4,6-tetrachloro-” OR “Phenol, 2,3,5,6-tetrachloro-” OR “Phenol, 2,4,5-trichloro-” OR “Phenol, 2,4,6-trichloro-” OR “Phenol, 2,4-dichloro-” OR “Phenol, 2-chloro-” OR “Phenol, 4-chloro-” OR “Phenol, chloro-” OR “Phenol, o-chloro-” OR “Phenol, p-chloro-” OR “Phenol, tetrachloro-” OR “Pine-O Disinfectant” OR “Tetrachlorophenol” OR “Tetrachlorophenol, 2,3,4,5-” OR “Tetrachlorophenol, 2,3,4,6-” OR “Tetrachlorophenol, 2,3,5,6-” OR “Tetrachlorophenol, isomer” OR “Tetrachlorophenols” OR “Trichlorophenol (2,4,5-)” OR “Trichlorophenol, 2,4,5-” OR “Trichlorophenol, 2,4,6-” OR “2,4,5-TCP” OR “2,4,6-T” OR “2,4,6-TCP” OR “2,4-DCP” OR “Applied 3-78” OR “BTS 45186” OR “Dowicide 2” OR “Dowicide 2S” OR “Dowicide 6” OR “Preventol I”; (advanced)Limit to: Project Title, Project Terms, Project Abstracts; Search Criteria Fiscal Year: Active Projects; Text Search: “Septi-Kleen” OR “2,3-Dichlorophenol” OR “2,3-Dichlorphenol” OR “Dichlorophenol, 2,3-” OR “Phenol, 2,3-dichloro-” OR “1-Hydroxy-2,5-dichlorobenzene” OR “2,5-Dichlorophenol” OR “2,5-Dichlorphenol” OR “Dichlorophenol, 2,5-” OR “PHENOL, 1,4-DICHLORO-” OR “Phenol, 2,5-dichloro-” OR “1,4-DICHLOROPHENOL” OR “3,4-Dichlorophenol” OR “3,4-Dichlorphenol” OR “4,5-Dichlorophenol” OR “Dichlorophenol, 3,4-” OR “Phenol, 3,4-dichloro-” OR “1-Hydroxy-3,5-dichlorobenzene” OR “3,5-Dichlorophenol” OR “3,5-Dichlorphenol” OR “Dichlorophenol, 3,5-” OR “Phenol, 3,5-dichloro-” OR “2,3,4-Trichlorophenol” OR “Phenol, 2,3,4-trichloro-” OR “Trichlorophenol, 2,3,4-”; (advanced)Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2021 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 930
- Number of records identified from other strategies: 44
- Total number of records to undergo literature screening: 974

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on chlorophenols:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 974
- Number of studies considered relevant and moved to the next step: 95

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 95
- Number of studies cited in the pre-public draft of the toxicological profile: 394
- Total number of studies cited in the profile: 416

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 November 2021 Literature Search Results and Screen for Chlorophenols

Figure B-1 description