# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

## 2-Chlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Chlorophenol
CAS Numbers: | 95-57-8
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 2-CP because the available studies evaluated limited endpoints and reported little detail.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. Available animal data consist of two rat studies of 2-CP with exposures for 4 or 6 hours (Monsanto 1975; Rhone-Poulenc 1991). These studies reported limited experimental details and evaluated limited endpoints. The only effects reported were clinical signs (tachypnea, restlessness, hunched posture) in the study by Rhone-Poulenc (1991). These data are not adequate for derivation of an acute-duration inhalation MRL.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2-Chlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Chlorophenol
CAS Numbers: | 95-57-8
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 2-CP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2-Chlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Chlorophenol
CAS Numbers: | 95-57-8
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 2-CP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2-Chlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Chlorophenol
CAS Numbers: | 95-57-8
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 2-CP, because the only study that reported a LOAEL for effects other than death was very poorly reported.

Rationale for Not Deriving an MRL: No dose-response data are available for humans. Only two acute-duration studies (Borzelleca et al. 1985a; Daniel et al. 1993) examined toxicological endpoints other than death in animals exposed to 2-CP (see Table A-1). Daniel et al. (1993) exposed Sprague-Dawley rats (10/sex/dose) to 2-CP in corn oil by gavage at doses of 0, 13, 64, 129, and 257 mg/kg/day for 10 days. Endpoints evaluated in all animals included mortality, body weight, clinical signs, food and water consumption, hematology, clinical chemistry, gross necropsy, and organ weights. Histopathology was performed on a comprehensive list of tissues and organs in the control and high-dose groups. No effects were observed at any dose (Daniel et al. 1993). Borzelleca et al. (1985a) administered 2-CP (0, 35, 69, or 175 mg/kg/day) in corn oil by gavage to CD-1 ICR mice (12/sex/dose) for 14 days. Evaluations included mortality, clinical signs, body weight, hematology and clinical chemistry, hepatic microsomal mixed function oxidase activity, cell-mediated and humoral immune responses, organ weights, and gross pathology. All animals receiving 175 mg/kg/day died prior to scheduled sacrifice. In female mice, brain, liver, and spleen weights were reportedly reduced (magnitude of change and affected doses not reported). Body weights were reportedly reduced at 69 mg/kg/day on days 1, 8 and 15, but the publication did not provide any further detail. Hyperactivity was reported to occur in mice at both 35 and 69 mg/kg/day; this endpoint formed the basis for the LOAEL. The study by Borzelleca et al. (1985a) was very poorly reported; results were given qualitatively in tabular form, without any discussion of the incidence or severity of effects.

Table A-1 Summary of Acute-Duration Oral Studies of 2-Chlorophenol

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Neurological effects
CD-1 Mouse | 14 days; (GO) | ND | 35 | Hyperactivity | Borzelleca et al. 1985a
Body weight effects
CD-1 Mouse | 14 days; (GO) | 35 | 69 | Reduced body weight (magnitude not reported) | Borzelleca et al. 1985a
Death
CD-1 Mouse | 14 days; (GO) | 69 | 175 | 20/20 mice died | Borzelleca et al. 1985a
Sprague-Dawley rat | 9 days; PNDs 4–12; (GO) | ND | 500 | 12/12 rats died by 9^th^ day of dosing in range finding study | Hasegawa et al. 2005
Other
Sprague-Dawley rat | 10 days; (GO) | 257 | ND | None | Daniel et al. 1993

(GO) = gavage in oil vehicle; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day

The finding of hyperactivity in mice exposed to 2-CP is not supported by other data for this compound or other chlorophenols (including 4-CP, 2,4-DCP, and tetrachlorophenols) that induce central nervous system depression, lethargy, tremors, and convulsions in humans (Kintz et al. 1992) and/or animals after oral or dermal exposure (Carreon et al. 1980a, 1980b; Hasegawa et al. 2005; Monsanto 1976; NTP 1989; Phornchirasilp et al. 1989b; Rhone-Poulenc 1991; Shen et al. 1983; Spencer and Williams 1950). Borzelleca et al. (1985a) also reported decreased body weight at the next higher dose (69 mg/kg/day), but the authors did not indicate the magnitude or statistical significance of this change, precluding its use as the basis for an acute-duration oral MRL.

The freestanding NOAEL of 257 mg/kg/day identified for the rat study by Daniel et al. (1993) is not a suitable basis for the oral MRL as it is higher than the dose that was lethal to all mice (175 mg/kg/day) in the study by Borzelleca et al. (1985a).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2-Chlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Chlorophenol
CAS Numbers: | 95-57-8
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.08 mg/kg/day
Critical Effect: | Decreased litter size
References: | Exon and Koller 1982, 1983a, 1983b, 1985
Point of Departure: | NOAEL of 7.6 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 5
Species: | Rats

MRL Summary: An intermediate-duration oral MRL of 0.08 mg/kg/day was derived for 2-CP based on a NOAEL of 7.6 mg/kg/day and LOAEL of 76 mg/kg/day for reproductive effects in rats administered 2-CP for 10 weeks premating and through mating and parturition (Exon and Koller 1982, 1983a, 1983b, 1985). A total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) was applied to the NOAEL of 7.6 mg/kg/day.

Selection of the Critical Effect: No dose-response data are available for humans. Table A-2 summarizes results from candidate intermediate-duration oral studies in laboratory animals.

Table A-2 Summary of NOAELs and LOAELs from Candidate Intermediate-Duration Studies in Laboratory Animals Orally Exposed to 2-Chlorophenol

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Reproductive effects
Rat (Sprague-Dawley) | Dams: from weaning through mating at PND 90, gestation, and lactation Offspring: from conception through weaning (PND 21) and for additional 12 weeks (W) | 7.6 | 76 | Increased percent of fetuses stillborn; decrease in litter size | Exon and Koller 1982, 1983a, 1983b, 1985
Neurological effects
Rat (Sprague-Dawley) | 18 days; PNDs 4–21 (GO) | 50 | 300 | Tremors | Hasegawa et al. 2005
Rat (Sprague-Dawley) | 4 weeks (GO) | 500 | 1,000 | Tremors, hypoactivity, ataxia | Hasegawa et al. 2005
Kidney effects
Rat (Sprague-Dawley) | 18 days; PNDs 4–21 (GO) | 50 | 300 | Renal basophilic tubules | Hasegawa et al. 2005
Other
Rat (Sprague-Dawley) | 13 weeks (GO) | 150 | ND | No effects on comprehensive parameters | Daniel et al. 1993

(GO) = gavage in oil vehicle; (W) = water; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day

The lowest LOAEL was identified based on decreased litter size and increased percent stillborn in the study reported by Exon and Koller (1982, 1983a, 1983b, 1985).

Selection of the Principal Study: The study by Exon and Koller (1982, 1983a, 1983b, 1985) was selected as the principal study. This study identified the lowest LOAEL for an endpoint (decreased litter size; increased percent stillborn pups) that has been observed for several other chlorophenols (2,4-DCP and 2,4,6-TCP).

Summary of the Principal Study:

Exon JH, Koller LD. 1982. Effects of transplacental exposure to chlorinated phenols. Environ Health Perspect 46:137–140.7151754

Exon JH, Koller LD. 1983a. Alteration of transplacental carcinogenesis by chlorinated phenols. In: Jolley RL, Brungs WA, Cotruvo WA, ., eds. Water chlorination: Environmental impact and health effects. Vol. 4, Book 2. Ann Arbor, MI: Ann Arbor Science, 1177–1188.

Exon JH, Koller LD. 1983b. Effects of chlorinated phenols on immunity in rats. Int J Immunopharmacol 5(2):131–136.6874166

Exon JH, Koller LD. 1985. Toxicity of 2-chlorophenol, 2,4-dichlorophenol and 2,4,6-trichlorophenol. In: Jolley RL, ed. Water chlorination: Chemistry, environmental impact and health effects. Vol. 5. Chelsea, MI: Lewis Publishers, 307–330.

2-CP (97% pure) was administered in the drinking water of female Sprague-Dawley rats (12–20 rats/group) at concentrations of 0, 5, 50, or 500 ppm (0, 0.76, 7.6, or 76 mg/kg/day, respectively). Treatment with 2-CP was initiated at 3 weeks of age (weaning) and continued through mating (with untreated males at 90 days of age) and gestation. The treated dams were allowed to deliver. The reproductive/developmental parameters evaluated included conception, mean litter size, number of stillborn, birth and weaning pup weights, and survival of pups to weaning. At weaning, hematology evaluations (erythrocyte, leukocyte, hematocrit, hemoglobin, and mean corpuscular volume) were conducted in the offspring. After weaning, randomly selected offspring were exposed for an additional 12 weeks. Immune parameters (antibody production, delayed-type hypersensitivity response, and phagocytic activity) were measured in 3–4 offspring/sex per group. At termination at the end of exposure, thymus, spleen, and liver weights of offspring were measured, and histological examinations of these organs were completed.

No changes in maternal body weight were observed. Mean litter size was reduced in rats treated at 76 mg/kg/day. The conception rate, pup birth and weaning weights, and survival of pups to weaning were similar in control and treated rats. No changes in hematological parameters were observed in the offspring at weaning. Treatment had no effect on any measure of humoral or cell-mediated immunity in offspring. In addition, there were no treatment-related changes in offspring liver, thymus, or spleen weights or histology. A LOAEL of 76 mg/kg/day and a NOAEL of 7.6 mg/kg/day were identified based on reduced litter size and increased percent of stillborn fetuses.

Selection of the Point of Departure for the MRL: The publications describing the principal study provided slightly different results for the litter size endpoint, as shown in Table A-3.

Table A-3 Litter Size and Percent Stillborn when Female Rats exposed to 2-Chlorophenol from Weaning through Mating (PND 90) to Parturition

Endpoint (reference) | Dose (mg/kg/day)
Endpoint (reference) | 0 | 0.76 | 7.6 | 76
Number pregnant dams | 8 | 9 | 9 | 12
Litter size (mean ± standard error); (Exon and Koller 1983b, 1985) | 11.4±1.1 | 11.6±1.0 | 10.1±1.0 | 9.1±0.9^a^
Litter size (mean ± standard deviation); (Exon and Koller 1982) | 11.4±1.2 | 11.7±3.5 | 10.1±2.3 | 9.2±4.3^b^
Percent stillborn (incidence of affected fetuses); (Exon and Koller 1982, 1985) | 0 (0/91) | 2 (2/105) | 0 (0/91) | 5 (6/110)^c,d^
Percent stillborn (incidence of affected fetuses); (Exon and Koller 1983b) | 0 (0/91) | 2 (2/105) | 0 (0/91) | 5 (6/100)^c,d^

a p≤0.1 compared with controls based on analysis of variance (ANOVA) and least squares means performed by the study authors (Exon and Koller 1985).

b Exon and Koller (1982) reported that “Litter size was significantly (p≤0.05) decreased in groups of dams treated with high levels of 2-CP;” however, the statistical test was not reported, and the accompanying table did not flag the dose level(s) at which the decrease was statistically significant.

c p≤0.1 compared with controls based on ANOVA and chi-square analysis performed by the study authors (Exon and Koller 1985).

d p≤0.05 (one-sided) compared with controls based on Fisher exact test performed for this review.

Italics indicates values reported inconsistently across the publications.

Sources: Exon and Koller 1982, 1983a, 1983b, 1985

Because of the subtle inconsistencies in the data on litter size and percent stillborn, benchmark dose (BMD) modeling was not undertaken for these data. However, the reported information was considered adequate to define the middle dose (7.6 mg/kg/day) as a NOAEL; this value was used as the basis for the intermediate-duration oral MRL for 2-CP.

Uncertainty Factor: The NOAEL was divided by a total uncertainty factor (UF) of 100:

- 10 UF for extrapolation from animals to humans
- 10 UF for human variability

- MRL = NOAEL ÷ (UF)
- 7.6 mg/kg/day ÷ (10 × 10) = 0.076 mg/kg/day ≈ 0.08 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Decreases in litter size or the number of live pups per litter were reported in animals exposed to other chlorophenols, including 4-CP (BSRC 2011), 2,4-DCP and 2,4,6-TCP (Exon and Koller 1985).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2-Chlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Chlorophenol
CAS Numbers: | 95-57-8
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 2-CP because the only available chronic study examined a limited number of endpoints.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. Only one chronic animal study of oral exposure to 2-CP was available (Exon and Koller 1985). Groups of 12–14 female Sprague-Dawley rats were exposed for 10 weeks before mating, and during gestation and lactation to one of three 2-CP concentrations (0, 5, 50, or 500 ppm, yielding estimated doses of 0.62, 6.2, or 62 mg/kg/day) in drinking water. Offspring (48–56/group) from these litters were kept on the same treatment regimen until death or 24 months of age. Hematological assessment of red and white cell counts, hemoglobin concentration, mean corpuscular volume (MCV), and packed-cell volume (PCV) was conducted on the offspring every two months. At termination, the animals were examined for tumors. In males and females exposed to 500 ppm, PCV, MCV, and the numbers of red cells were increased; this effect was especially pronounced after 14 months of exposure. Treatment with 2-CP had no effect on tumor incidence, latency, or type in males or females. No other endpoints were evaluated. These data are not considered adequate for use in deriving a chronic-duration oral MRL due to limitations in the evaluations conducted (only hematology and tumor assessments).

Agency Contacts (Chemical Managers): Malcolm Williams

## 4-Chlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Chlorophenol
CAS Numbers: | 106-48-9
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 4-CP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 4-Chlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Chlorophenol
CAS Numbers: | 106-48-9
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 4-CP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 4-Chlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Chlorophenol
CAS Numbers: | 106-48-9
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 4-CP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 4-Chlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Chlorophenol
CAS Numbers: | 106-48-9
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 4-CP because the available studies examined limited endpoints, and because the lowest LOAEL was a serious LOAEL for mortality.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. Acute-duration oral studies of 4-CP are limited to a 2-week study examining hepatic endpoints (Phornchirasilp et al. 1989b) and a single-dose developmental toxicity screening study (Kavlock 1990), both conducted in Sprague-Dawley rats. Table A-4 summarizes the available data.

Table A-4 Summary of Acute-Duration Oral Studies of 4-Chlorophenol

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Liver effects
Rat (Sprague-Dawley) | 2 weeks; 7 days/week; (GO) | 2.58 | ND | No adverse hepatic effects (see text) | Phornchirasilp et al. 1989b
Body weight effects
Rat (Sprague-Dawley) | Once on GD 11; (GO) | 667 | 1,000 | Maternal body weight loss of 10 g | Kavlock 1990
Death
Rat (Sprague-Dawley) | 12 days (GO) | ND | 1,000 (serious LOAEL) | Death (11/24 rats) | BSRC 2011

GD = gestation day; (GO) = gavage in oil vehicle); LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

In the developmental toxicity study, Kavlock (1990) exposed groups of 12–13 female Sprague-Dawley rats by gavage on GD 11 and allowed them to deliver their litters. These authors examined maternal weight, clinical signs, implantations, and weight and viability of offspring through PND 6, and gross or external malformations detected until weaning. At 1,000 mg/kg, the dams lost an average of 10 g of body weight in the 24 hours postdosing; at 667 mg/kg, dams lost an average of 3 g. There were no effects on other parameters examined. In an intermediate-duration study (BSRC 2011), deaths were observed in the first 12 days of dosing at 1,000 mg/kg/day.

Phornchirasilp et al. (1989b) administered 4-CP in corn oil by gavage to groups of 4–6 male Sprague-Dawley rats for 1–2 weeks and examined hepatic microsomal protein and cytochrome P-450 levels, and electron microscopy of the liver. No changes in liver weights were seen. Hepatic microsomal protein levels were increased at doses ≥0.32 mg/kg/day, and cytochrome P-450 enzyme activities were increased at doses ≥0.64 mg/kg/day. After 2 weeks of exposure to 2.58 mg/kg/day, rats exhibited ultrastructural changes in the liver, consisting of foamy cytoplasm and clustering of intracellular organelles. Microscopy findings were reported qualitatively (incidences and severity not reported). These effects were of uncertain significance because they were not supported by a later intermediate-duration study of Sprague-Dawley rats exposed to much higher doses (Hasegawa et al. 2005) in which no adverse hepatic effects (clinical chemistry, liver weight, or histopathological findings) were observed at doses up to 300 mg/kg/day for 18 days or 500 mg/kg/day for 4 weeks.

In summary, the lowest LOAEL (1,000 mg/kg/day) was also a serious LOAEL for mortality (BSRC 2011), and the other available studies ( Kavlock 1990; Phornchirasilp et al. 1989b) examined limited endpoints (Kavlock 1990; Phornchirasilp et al. 1989b and) or exposed animals only once (Kavlock 1990). Thus, the data are not considered to be adequate for acute duration oral MRL derivation.

Agency Contacts (Chemical Managers): Malcolm Williams

## 4-Chlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Chlorophenol
CAS Numbers: | 106-48-9
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.9 mg/kg/day
Critical Effect: | Decreased live births/litter
Reference: | BSRC 2011
Point of Departure: | BMDL_1SD_ of 85.77 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 9
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.9 mg/kg/day was derived for 4-CP based on a BMDL_1SD_ of 85.77 mg/kg/day for reproductive effects (decreased number of live births per litter) in Sprague-Dawley rats given 4-CP by daily gavage in a 42–53-day reproductive and developmental toxicity screening study (BSRC 2011). A total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) was applied.

Selection of the Critical Effect: No dose-response data are available for humans. Table A-5 summarizes results from candidate intermediate-duration oral studies in experimental animals.

Phornchirasilp et al. (1989b) administered 4-CP in corn oil by gavage to groups of 4–6 male Sprague-Dawley rats for 4–8 weeks for examination of the liver by electron microscopy. Exposure for at least 4 weeks to 0.64 mg/kg/day resulted in morphological changes in hepatic ultrastructure (foamy cytoplasm and the proliferation and clustering of mitochondria and endoplasmic reticulum). Microscopy findings were reported qualitatively (incidences and severity not reported). These effects are of uncertain significance because a later study of Sprague-Dawley rats exposed to much higher doses (Hasegawa et al. 2005) did not observe any adverse hepatic effects (clinical chemistry, liver weight, or histopathological findings by light microscopy) at doses up to 300 mg/kg/day for 18 days (neonatal rats) or 500 mg/kg/day for 4 weeks (starting at 5–6 weeks of age). The lowest effect level was identified in the study by BSRC (2011) for reproductive effects.

Table A-5 Summary of Intermediate-Duration Oral Studies of 4-Chlorophenol

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Liver effects
Rat (Sprague-Dawley) | 4–8 weeks; 7 days/week; (GO) | 0.64 | ND | No adverse hepatic effects (see text) | Phornchirasilp et al. 1989b
Reproductive effects
Rat (Sprague-Dawley) | 41–53 days (GO) | 40 | 200 | Significantly reduced number live births; reduced number implantation sites | BSRC 2011
Neurological effects
Rat (Sprague-Dawley) | 18 days, PNDs 4–21 (GO) | 100 | 300 (serious LOAEL) | Tremors, hyperventilation, salivation | Hasegawa et al. 2005
Rat (Sprague-Dawley) | 4 weeks; (GO) | 100 | 500 (serious LOAEL) | Tremors, hyperventilation, salivation | Hasegawa et al. 2005

(GO) = gavage in oil vehicle; LOAEL = lowest observed adverse effect level; NOAEL = no-observed-adverse-effect level; PND = postnatal day

Selection of the Principal Study: Of the four available studies of 4-CP, the lowest effect level was identified by BSRC (2011).

Summary of the Principal Study:

BSRC. 2011. Simplified reproductive toxicity testing of oral p-chlorophenol dosage using rats. Biosafety Research Center. Pharmaceutical and Food Safety Bureau, Ministry of Health, Labour and Welfare of Japan. Test No: C539 (115-222).

A reproductive/developmental toxicity screening study was conducted in Crl:CD (SD) rats (BSRC 2011). This study was unpublished and originally reported in Japanese; this summary is based on an official translation. Groups of 12 rats/sex/dose were given 4-CP (99.8% pure) in corn oil by gavage at doses of 0, 40, 200, or 1,000 mg/kg/day. Dosing began 14 days before mating and continued through a 14-day mating period (males) or until successfully mated (females). Males continued to be dosed for 14 additional days (total of 42 days) after mating, while females were dosed during gestation and through 3 days postpartum (total of 41–53 days). Evaluations in parental animals included clinical signs, body weight (weekly during most of the study), food intake, gross necropsy, reproductive organ weights, and histopathology (sites of gross anomalies, dead animals, animals that did not copulate, and males that did not impregnate females or females that did not become pregnant). Reproductive and developmental parameters were evaluated, including sperm formation cycle, estrus cyclicity, copulation index, fertility, gestation period, and implantations, litter size, offspring viability and weight, and external abnormalities.

Mortalities occurred in the high dose group (6/12 male and 5/12 female) but not in other groups; the deaths occurred within the first 12 days of dosing (BSRC 2011). Animals in this group exhibited a variety of clinical signs including salivation, prone position, lateral position, tremor, and clonic convulsion within a half hour of dosing and continuing up to 2 hours after dosing. Other clinical signs seen in this group (1,000 mg/kg/day) included dyspnea, abnormal respiratory noises, ptosis, and soiling of fur in the anogenital area. Salivation occurred at low frequency in males of the 200 mg/kg/day group. Body weights and food intake were decreased at the high dose but not affected at 200 mg/kg/day. Relative organ weight changes in the high dose group were attributable to the body weight changes. Gross and microscopic findings in parental animals were limited to the gastrointestinal tract and liver; these consisted of squamous epithelial hyperplasia and erosion or ulcers of the forestomach, ulcers in the esophagus, and centrilobular hepatocellular hypertrophy. These findings were observed in the high dose group; however, the low and mid-dose groups were not examined for histopathology. The number of live offspring at birth was significantly reduced in the 200 mg/kg/day group and lower at 1,000 mg/kg/day (although not statistically significant, possibly due to the small number of survivors). Decreases in the numbers of implantation sites and offspring delivered were also seen at 200 mg/kg/day but were not significantly different from controls. No treatment-related effects were seen on other reproductive or developmental parameters. A LOAEL of 200 mg/kg/day and NOAEL of 40 mg/kg/day are identified for this study based on reduced numbers of live births and implantation sites.

Selection of the Point of Departure for the MRL: The BMDL_1SD_ of 85.77 mg/kg/day for decreased live births/litter was selected as the basis of the MRL.

The numbers of live births/litter were subjected to BMD modeling to obtain a point of departure (POD) for MRL derivation. Numbers of implantations were not modeled because the changes were not statistically significant. The data on numbers of live births per litter were fit to all available continuous models in EPA’s Benchmark Dose Software (BMDS, version 3.1.2). Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined benchmark response (BMR). Among all of the models providing adequate fit to the data, the lowest BMDL (95% lower confidence limit on the benchmark dose) was selected as the POD when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen. For BMD modeling, the high dose group was omitted due to the substantial mortality in that group. A BMR of one standard deviation from the control mean was selected in the absence of a biologically-based BMR. The data as modeled are reported in Table A-6.

Table A-6 Live Births/litter in Sprague-Dawley Rats Exposed to 4-Chlorophenol by Gavage in Reproductive/ Developmental Toxicity Screening Study

Dose | Number/group | Live births/litter
Dose | Number/group | Mean | SD
0 | 12 | 15.2 | 1.7
40 | 12 | 15.1 | 1.1
200 | 9 | 13.2 | 1.3

Source: BSRC 2011

The model predictions are shown in Table A-7.

Table A-7 Results from BMD Analysis (Constant Variance) of Live Births per Litter in Sprague-Dawley Rats Exposed to 4-Chlorophenol via Gavage in a Reproductive/Developmental Toxicity Screening Study (BSRC 2011)

Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Scaled residuals^d^ | | | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Exponential (model 2)^e^ | 0.01 | 0.31 | 0.52 | 0.50 | −0.13 | 0.50 | 119.03 | 124.81 | 80.81
Exponential (model 3)^e^ | 0.01 | 0.31 | NA | −1.1×10^−5^ | −5.7 ×10^−5^ | −9.12 ×10^−5^ | 120.61 | 159.55 | 83.24
Exponential (model 4)^e^ | 0.01 | 0.31 | 0.52 | 0.50 | −0.13 | 0.50 | 119.03 | 124.80 | 80.81
Exponential (model 5)^e^ | 0.01 | 0.31 | <0.0001 | −2.01 ×10^−6^ | −9.98 ×10^−6^ | −5.0 ×10^−5^ | 122.61 | 158.91 | 40.92
Hill^e^ | 0.01 | 0.31 | <0.0001 | −0.0003 | 8.05 ×10^−5^ | −0.0003 | 122.61 | 54.43 | 41.50
Polynomial (2-degree)^e^ | 0.01 | 0.31 | NA | 1.85 ×10^−6^ | −1.92 ×10^−8^ | −1.88 ×10^−6^ | 120.61 | 162.09 | 87.75
Power^e^ | 0.01 | 0.31 | NA | 0.004 | −0.0002 | 0.004 | 120.61 | 160.45 | 87.75
Linear ^f^ | 0.01 | 0.31 | 0.55 | 0.46 | −0.11 | 0.46 | 118.97 | 127.96 | 85.77

a Values >0.05 fail to meet conventional goodness-of-fit criteria.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Values <0.1 fail to meet conventional goodness-of-fit criteria.

d Scaled residuals at doses immediately below and above the benchmark dose; also the largest residual at any dose.

e Restricted model.

f Recommended model (lowest AIC). The variance model assuming constant variance was an adequate fit. The Exponential 2, exponential 4, and linear models provided adequate fit to the means. The BMDLs of the fit models were sufficiently close (<3-fold); therefore, the model with the lowest AIC was selected (Linear).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control)

The best-fitting model was the linear model with constant variance; this model yielded BMD_1SD_ and BMDL_1SD_ values of 127.95 and 85.77 mg/kg/day. The fit of the selected model (linear, constant variance) is shown in Figure A-1.

Figure A-1 Fit of Linear Model (Constant Variance) to Data on Live Births/Litter in Rats Administered 4-Chlorophenol by Gavage Before Mating and During Mating and Gestation

Figure A-1 description

Uncertainty Factor: The BMDL_1SD_ is divided by a total uncertainty factor of 100:

- UF of 10 for extrapolation from animals to humans
- UF of 10 for human variability

- MRL = BMDL_1SD_ ÷ (UF)
- 85.77 mg/kg/day ÷ (10 × 10) = 0.8577 mg/kg/day ≈ 0.9 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: While the data on reproductive toxicity of 4-CP are limited, other chlorophenols exhibit similar reproductive effects. In animals exposed to chlorophenols by oral administration, decreases in implantations, litter size, and/or live births per litter have been reported after intermediate-duration exposure to 2,4-DCP (46 mg/kg/day) (Exon and Koller 1985; Exon et al. 1984), and 2,4,6-TCP (46 mg/kg/day) (Exon and Koller 1985). 2,4-DCP also induced decreased numbers of implantation sites in a 2-generation study in Wistar-Hanover rats (Aoyama et al. 2005). Exposure of rats to 2,4,5-TCP on GD 14 resulted in an increased incidence of prenatal mortalities and resorptions (Hood et al. 1979).

Agency Contacts (Chemical Managers): Malcolm Williams

## 4-Chlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Chlorophenol
CAS Numbers: | 106-48-9
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 4-CP.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. No chronic-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3-Dichlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3-Dichlorophenol
CAS Numbers: | 576-24-9
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 2,3-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3-Dichlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3-Dichlorophenol
CAS Numbers: | 576-24-9
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 2,3-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3-Dichlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3-Dichlorophenol
CAS Numbers: | 576-24-9
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 2,3-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3-Dichlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3-Dichlorophenol
CAS Numbers: | 576-24-9
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 2,3-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. The only information on the health effects of 2,3-DCP following oral exposure in animals was acute lethality data following single exposures (Borzelleca et al. 1985b).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3-Dichlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3-Dichlorophenol
CAS Numbers: | 576-24-9
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for 2,3-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3-Dichlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3-Dichlorophenol
CAS Numbers: | 576-24-9
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 2,3-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. No chronic-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4-Dichlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-Dichlorophenol
CAS Numbers: | 120-83-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 2,4-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4-Dichlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-Dichlorophenol
CAS Numbers: | 120-83-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 2,4-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4-Dichlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-Dichlorophenol
CAS Numbers: | 120-83-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 2,4-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4-Dichlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-Dichlorophenol
CAS Numbers: | 120-83-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 2,4-DCP because the lowest effect level represents a serious LOAEL in the absence of an identified NOAEL.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. Table A-8 summarizes results from candidate acute-duration oral studies in experimental animals.

Table A-8 Summary of Acute-Duration Studies in Experimental Animals Orally Exposed to 2,4-Dichlorophenol

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Reproductive effects
Mouse (BALB/c) | 14 days; (W) | ND | 270 (serious LOAEL) | Increased necrotic cell counts in seminiferous tubules, >3-fold increase in percent abnormal sperm, and decreased sperm motility | Aydin et al. 2009
Body weight effects
Rat (Fischer 344) | 10 days; GDs 6–15; (GO) | 200 | 375 (serious LOAEL) | Maternal toxicity: 23% decrease in weight gain; hair loss; red discharge from eyes, nose, and mouth | Rodwell et al. 1989
Rat (Fischer 344) | 14 days; (F) | 500 | 1,000 | 19% decrease in body weight | NTP 1989

(F) = feed; GD = gestation day; (GO) = gavage in oil vehicle; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; (W) = water

It is not appropriate to derive an acute-duration oral MRL for 2,4-DCP because the lowest effect level (270 mg/kg/day; Aydin et al. 2009) represents a serious LOAEL in the absence of an identified NOAEL.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4-Dichlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-Dichlorophenol
CAS Numbers: | 120-83-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.02 mg/kg/day
Critical Effect: | Decreased delayed-type immunological hypersensitivity response
References: | Exon and Koller 1985; Exon et al. 1984
Point of Departure: | BMDL_1SD_ of 2.07 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 8
Species: | Rats

MRL Summary: An intermediate-duration oral MRL of 0.02 mg/kg/day was derived for 2,4-DCP based on immunotoxicity in rats exposed from conception through weaning via maternal exposure and in drinking water for an additional 15 weeks (Exon and Koller 1985; Exon et al. 1984). BMD analysis of the data for delayed-type hypersensitivity response yielded a BMDL_1SD_ of 2.07 mg/kg/day that was used as the POD. A total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) was applied to the BMDL_1SD_.

Selection of the Critical Effect: No dose-response data are available for humans. Table A-9 summarizes results from candidate intermediate-duration oral studies in laboratory animals.

Table A-9 Summary of Candidate Critical Effects for the Intermediate-Duration Oral MRL for 2,4-DCP

Species (Strain) | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Immune system effects
Rat (Sprague-Dawley) | Dams: from weaning through mating at PND 90, gestation, and lactation Offspring: from conception through weaning (PND 21) and for additional 15 weeks (W) | 0.46 | 4.6 | Decreased delayed-type immunological hypersensitivity response | Exon and Koller 1985; Exon et al. 1984
Reproductive effects
Rat (Sprague-Dawley) | Dams: from weaning through mating at PND 90, gestation, and lactation Offspring: from conception through weaning (PND 21) and for additional 15 weeks (W) | 4.6 | 46 | Decreased mean litter size | Exon and Koller 1985; Exon et al. 1984
Mouse (CD-1) | 90 days (W) | 500 | ND | No adverse effect on sperm motility or acrosome integrity, or ovum penetration | Seyler et al. 1984
Liver effects
Mouse (ICR, ddN) | 6 months; (F) | 100 | 230 | Hepatocyte swelling | Kobayashi et al. 1972
Mouse (B6C3F1) | 13 weeks (F) | ND | 325 | Minimal hepatocellular necrosis | NTP 1989
Hematological effects
Rat (Fischer 344) | 13 weeks (F) | 250 | 500 (serious LOAEL) | Bone marrow atrophy | NTP 1989
Body weight effects
Rat (Wistar) | 10 weeks premating through gestation and lactation until weaning of 3^rd^ generation (F) | 134 | 543 | Decreased body weights in parental and F1 generations | Aoyama et al. 2005
Other
Mouse (CD-1) | 13 weeks (W) | 383 | ND | No adverse effects noted | Borzelleca et al. 1985a, 1985c

(F) = feed; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day; (W) = water

Selection of the Principal Study: The lowest LOAEL (4.6 mg/kg/day) was identified for immunotoxicity in Sprague-Dawley rats exposed to 2,4-DCP from conception through weaning via maternal exposure and for an additional 15 weeks after weaning. No other LOAEL was within a factor of 10 of the lowest value; thus, this study was considered the principal study for intermediate-duration oral MRL derivation.

Summary of the Principal Study:

Exon JH, Koller LD. 1985. Toxicity of 2-chlorophenol, 2,4-dichlorophenol and 2,4,6-trichlorophenol. In: Jolley RL, ed. Water chlorination: Chemistry, environmental impact and health effects. Vol. 5. Chelsea, MI: Lewis Publishers, 307–330.

Exon JH, Henningsen GM, Osborne CA, . 1984. Toxicologic, pathologic, and immunotoxic effects of 2,4-dichlorophenol in rats. J Toxicol Environ Health 14:723–730.6520883

2,4-DCP (99% pure) was administered in the drinking water of female Sprague-Dawley rats (12–20 rats/group) at concentrations of 0, 3, 30, or 300 ppm (0, 0.46, 4.6, or 46 mg/kg/day, respectively). Treatment with 2,4-DCP was initiated at 3 weeks of age (weaning) and continued through mating (with untreated males at 90 days of age) and gestation. The treated dams were allowed to deliver. The reproductive/developmental parameters evaluated included conception, mean litter size, number of stillborn, birth and weaning pup weights, and survival of pups to weaning. At weaning, hematology evaluations (erythrocyte, leukocyte, hematocrit, hemoglobin, and mean corpuscular volume) were conducted in the offspring. After weaning, randomly selected offspring were exposed for an additional 12 weeks. Immune parameters (antibody production, delayed-type hypersensitivity response, phagocytic activity) were measured in 3–4 offspring/sex per group. At termination at the end of exposure, thymus, spleen, and liver weights of offspring were measured, and histological examinations of these organs were completed.

The conception rate, pup birth weight, and survival of pups to weaning were similar in control and treated rats. The percent of stillborn pups was increased in all treatment groups, but this increase was not statistically significant. Mean litter size was similar in rats treated with up to 0, 0.46, or 4.6 mg/kg/day; however, mean litter size was significantly reduced (p<0.1) in rats of the 46 mg/kg/day group (6.3±1.6 versus 9.8±1.3 in controls). No effects on body weight or thymus weight were observed. Delayed-type hypersensitivity was significantly (p<0.05) decreased at 4.6 and 46 mg/kg/day. Delayed-type hypersensitivity was evaluated by sensitizing the rats with a subcutaneous injection of bovine serum albumin and then administering a challenge injection of bovine serum albumin in the left rear footpad 1 week later. The right rear footpad received a sham injection of saline. The difference in footpad swelling between the left and right footpads is a measure of the immune response to bovine serum albumin. A decrease in footpad swelling indicates suppression of cell-mediated immunity. Antibody production was significantly (p<0.05) increased at 46 mg/kg/day. No effects on phagocytic activity were observed. Spleen and liver weights were significantly (p<0.05) increased at 46 mg/kg/day. 2,4-DCP treatment did not result in any microscopic changes in the liver, spleen or thymus. A LOAEL of 4.6 mg/kg/day and a NOAEL of 0.46 mg/kg/day were identified based on effects on cell-mediated immunity (reduced delayed-type hypersensitivity response).

Selection of the Point of Departure for the MRL: The data for decreased delayed-type hypersensitivity response (measured as footpad swelling in response to bovine serum albumin injection) are shown in Table A-10.

Table A-10 Cell-mediated Immunity Effects in Rats Exposed to 2,4-DCP from Conception Through Weaning and for an Additional 15 Weeks

| | Footpad swelling (mm)
Concentration in water | Dose (mg/kg/day) | Number of rats | Mean | Standard error of the mean | Standard deviation (calculated)
0 | 0 | 10 | 1.1 | 0.13 | 0.41
3 | 0.46 | 10 | 0.85 | 0.11 | 0.35
30 | 4.6 | 10 | 0.67 | 0.11 | 0.35
300 | 46 | 10 | 0.63 | 0.11 | 0.35

Sources: Exon and Koller 1985; Exon et al. 1984

These data were subjected to BMD modeling to obtain a POD for MRL derivation. Data were fit to all available continuous models in EPA’s BMDS (version 3.1.2). Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL was selected as the POD when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest AIC was chosen. A BMR of 1 standard deviation from the control mean was used.

In modeling of the data, the p-value for test 1 was 0.11, which exceeds the threshold of 0.05 and suggests lack of evidence for a dose-response. This result probably stems from the large standard deviations on the data points. The study authors reported a statistical difference (p≤0.05) between the high- and control-groups using analysis of variance and least squares means, and a t-test estimated for this document using the provided means and standard errors also showed a significant difference (two-tailed p = 0.0129). Therefore, the data were considered to show a dose-response despite the test 1 p-value. The model predictions for footpad swelling are shown in Table A-11 and the fit of the selected (Exponential 4) model is shown in Figure A-2.

Table A-11 Results from BMD Analysis (Constant Variance) of Delayed Type Hypersensitivity (Footpad Swelling) in Female Sprague-Dawley Rats Exposed to 2,4-Dichlorophenol

Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Scaled residuals^d^ | | | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Exponential (model 2)^e^ | 0.11 | 0.94 | 0.05 | 0.23 | ND | 1.73 | 41.07 | 63.11 | 27.59
Exponential (model 3)^e^ | 0.11 | 0.94 | 0.05 | 0.23 | ND | 1.73 | 41.07 | 63.11 | 27.59
Exponential (model 4) ^e^ ^,^ ^f^ | 0.11 | 0.94 | 0.49 | −0.05 | 0.19 | −0.89 | 36.29 | 5.15 | 2.07
Exponential (model 5)^e^ | 0.11 | 0.94 | 0.49 | −0.05 | 0.19 | −0.89 | 36.29 | 5.15 | 2.07
Hill^e^ | 0.11 | 0.94 | 0.97 | −0.01 | 0.03 | 0.03 | 36.88 | 1.15 | 0.00
Polynomial (2-degree)^e^ | 0.11 | 0.94 | 0.04 | 0.16 | ND | 1.77 | 41.21 | 61.80 | 33.33
Polynomial (3-degree)^e^ | 0.11 | 0.94 | 0.04 | 0.16 | ND | 1.77 | 41.21 | 61.80 | 33.33
Power^e^ | 0.11 | 0.94 | 0.04 | 0.16 | ND | 1.77 | 41.21 | 61.80 | 33.33
Linear | 0.11 | 0.94 | 0.04 | 0.16 | ND | 1.77 | 41.21 | 61.80 | 33.33

a Values >0.05 fail to meet conventional goodness-of-fit criteria.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Values <0.1 fail to meet conventional goodness-of-fit criteria.

d Scaled residuals at doses immediately below and above the benchmark dose; also the largest residual at any dose.

e Restricted model.

f Recommended model. There was an adequate fit to the variance when assuming constant variance. Only the Exponential 4, Exponential 5, and Hill models provided adequate fit to the means; however, the Hill model predicted a BMDL of 0 so it was not considered further. The Exponential models provided identical BMDs, BMDLs, and AICs.

The p-value for the test for significant difference was >0.05; there may not be a dose-response.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control)

Figure A-2 Fit of Exponential 4 Model to Data on Decreased Delayed-Type Hypersensitivity Response (Footpad Swelling) in Rats Administered 2,4-Dichlorophenol from Conception Through Weaning and for 12 Additional Weeks in Drinking Water

Figure A-2 description

The BMDL_1SD_ from the selected (Exponential 4) model was 2.07 mg/kg/day; this value was selected as the POD for derivation of the intermediate-duration oral MRL.

Uncertainty Factor: The BMDL_1SD_ of 2.07 mg/kg/day was divided by a total uncertainty factor (UF) of 100:

- 10 UF for extrapolation from animals to humans
- 10 UF for human variability

- MRL = BMDL_1SD_ ÷ (UF)
- 2.07 mg/kg/day ÷ (10 × 10) = 0.0207 mg/kg/day ≈ 0.02 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: In addition to effects on cell-mediated immunity, 2,4-DCP exposure resulted in increased serum antibodies to keyhole limpet hemocyanin in rats exposed to higher doses (46 mg/kg/day) in the principal study (Exon and Koller 1985; Exon et al. 1984).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4-Dichlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4-Dichlorophenol
CAS Numbers: | 120-83-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 2,4-DCP; the available chronic studies identified higher effect levels than the intermediate duration studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. Table A-12 summarizes results from candidate chronic-duration oral studies in experimental animals that identified the lowest NOAELs and/or LOAELs.

Table A-12 Summary of NOAELs and LOAELs from Candidate Chronic-Duration Studies in Experimental Animals Orally Exposed to 2,4-Dichlorophenol

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Respiratory effects
Rat (Fischer 344) | 103 weeks (F) | ND | 210 | Nasal lesions; multifocal degeneration of respiratory epithelium | NTP 1989
Body weight effects
Mouse (B6C3F1) | 103 weeks (F) | 430 | 820 | Maximum 19% decrease in body weight relative to controls | NTP 1989

(F) = feed; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

The lowest effect level identified in the chronic studies by NTP (1989) was the LOAEL of 210 mg/kg/day based on nasal and respiratory tract lesions in rats. This value is higher than intermediate-duration LOAELs identified for immunotoxicity (decreased delayed-type hypersensitivity response at 4.6 mg/kg/day) (Exon and Koller 1985; Exon et al. 1984) and reproductive toxicity (decreased mean litter size at 46 mg/kg/day) (Exon and Koller 1985; Exon et al. 1984; see Table A-9 above). As the available chronic studies did not evaluate these sensitive endpoints and identified higher effect levels than the intermediate-duration studies, they are not considered adequate for derivation of a chronic oral MRL for 2,4-DCP.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,5-Dichlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,5-Dichlorophenol
CAS Numbers: | 583-78-8
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 2,5-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,5-Dichlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,5-Dichlorophenol
CAS Numbers: | 583-78-8
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 2,5-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,5-Dichlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,5-Dichlorophenol
CAS Numbers: | 583-78-8
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 2,5-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,5-Dichlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,5-Dichlorophenol
CAS Numbers: | 583-78-8
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 2,5-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans The only information on the health effects of 2,5-DCP following oral exposure in animals was acute lethality data following single exposures (Borzelleca et al. 1985b).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,5-Dichlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,5-Dichlorophenol
CAS Numbers: | 583-78-8
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for 2,5-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,5-Dichlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,5-Dichlorophenol
CAS Numbers: | 583-78-8
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 2,5-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. No chronic-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,4-Dichlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,4-Dichlorophenol
CAS Numbers: | 95-77-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 3,4-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,4-Dichlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,4-Dichlorophenol
CAS Numbers: | 95-77-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 3,4-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,4-Dichlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,4-Dichlorophenol
CAS Numbers: | 95-77-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 3,4-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,4-Dichlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,4-Dichlorophenol
CAS Numbers: | 95-77-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 3,4-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. The only information on the health effects of 3,4-DCP following oral exposure in animals was acute lethality data following a single exposure (Borzelleca et al. 1985b).

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,4-Dichlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,4-Dichlorophenol
CAS Numbers: | 95-77-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for 3,4-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,4-Dichlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,4-Dichlorophenol
CAS Numbers: | 95-77-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 3,4-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. No chronic-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,5-Dichlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,5-Dichlorophenol
CAS Numbers: | 591-35-5
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 3,5-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,5-Dichlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,5-Dichlorophenol
CAS Numbers: | 591-35-5
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 3,5-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,5-Dichlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,5-Dichlorophenol
CAS Numbers: | 591-35-5
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 3,5-DCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,5-Dichlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,5-Dichlorophenol
CAS Numbers: | 591-35-5
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 3,5-DCP. The only acute-duration study that evaluated effects other than lethality was available only as an abstract and the full study report could not be located.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans for 3,5-DCP. The only information on the health effects of 3,5-DCP following oral exposure in animals was acute lethality data following a single exposure (Borzelleca et al. 1985b).

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,5-Dichlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,5-Dichlorophenol
CAS Numbers: | 591-35-5
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for 3,5-DCP due to the lack of intermediate-duration studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans for 3,5-DCP. No intermediate-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 3,5-Dichlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3,5-Dichlorophenol
CAS Numbers: | 591-35-5
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 3,5-DCP due to the lack of chronic-duration studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. No chronic-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4-Trichlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4-Trichlorophenol
CAS Numbers: | 15950-66-0
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 2,3,4-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4-Trichlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4-Trichlorophenol
CAS Numbers: | 15950-66-0
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 2,3,4-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4-Trichlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4-Trichlorophenol
CAS Numbers: | 15950-66-0
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 2,3,4-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4-Trichlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4-Trichlorophenol
CAS Numbers: | 15950-66-0
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 2,3,4-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. No acute-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4-Trichlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4-Trichlorophenol
CAS Numbers: | 15950-66-0
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for 2,3,4-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4-Trichlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4-Trichlorophenol
CAS Numbers: | 15950-66-0
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 2,3,4-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. No chronic-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,5-Trichlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,5-Trichlorophenol
CAS Numbers: | 95-95-4
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 2,4,5-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,5-Trichlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,5-Trichlorophenol
CAS Numbers: | 95-95-4
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 2,4,5-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,5-Trichlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,5-Trichlorophenol
CAS Numbers: | 95-95-4
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 2,4,5-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,5-Trichlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,5-Trichlorophenol
CAS Numbers: | 95-95-4
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 2,4,5-TCP, as the available studies examined limited endpoints and/or reported doses imprecisely.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans for 2,4,5-TCP. Available acute-duration animal studies of oral exposure to 2,4,5-TCP include a single dose acute lethality study in rats (McCollister et al. 1961), a 1- or 3-day developmental toxicity study in mice (Hood et al. 1979), a 14-day developmental toxicity study in rats (Chernoff et al. 1990), and a 14-day gavage study (Carlson 1978). In the 3-day developmental toxicity study, an increase in prenatal mortalities and resorptions occurred when pregnant mice were dosed with 800–900 mg/kg on GD 14 but not when dosed with 250–300 mg/kg/day on GDs 13–15. Maternal mortalities occurred at the only tested dose, 650 mg/kg/day in the 14-day developmental toxicity study in rats (Chernoff et al. 1990). No effects were observed on hepatic enzyme levels, the only endpoints evaluated, at doses up to 400 mg/kg/day in the 14-day gavage study in rats (Carlson 1978). These data are not considered adequate for acute-duration MRL derivation due to the limited evaluations in the study by Carlson (1978), mortalities in the 14-day developmental toxicity study (Chernoff et al. 1990), and imprecise doses and brief exposure duration (1 or 3 days) in the mouse developmental study by Hood et al. (1979).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,5-Trichlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,5-Trichlorophenol
CAS Numbers: | 95-95-4
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 1 mg/kg/day
Critical Effect: | Degenerative changes in the kidneys and liver
Reference: | McCollister et al. 1961
Point of Departure: | NOAEL of 100 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 3
Species: | Rats

MRL Summary: An intermediate-duration oral MRL of 1 mg/kg/day was derived for 2,4,5-TCP based on degenerative changes in the kidneys and liver of rats administered 300 mg/kg/day in feed for 98 days (McCollister et al. 1961). A total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) was applied to the NOAEL of 100 mg/kg/day.

Selection of the Critical Effect: No dose-response data are available for humans. McCollister et al. (1961) is the only adequate intermediate-duration oral study of 2,4,5-TCP. A series of studies in animals exposed orally to 2,4,5-TCP was performed by McCollister et al. 1961; these included an oral LD_50_ study in rats, a study of rats exposed to doses up to 1,000 mg/kg/day by gavage on 18 of 24 days, a study of rabbits exposed to doses up to 500 mg/kg by gavage on 20 of 28 days, and a 98-day rat study using dietary administration at doses up to 1,000 mg/kg/day. McCollister et al. (1961) reported temporary weight loss and a 15% increase in relative kidney weight in the rats exposed by gavage for 18 doses of 1,000 mg/kg. The authors reported very slight kidney changes in rabbits exposed to 100 mg/kg, and very slight kidney and liver changes at 500 mg/kg; no further details were provided on the nature of these changes. Only the 98-day study was reported with enough detail to identify effect levels; the rat and rabbit gavage studies were described briefly with limited information on results.

Selection of the Principal Study: Only the 98-day study was reported with enough detail to identify effect levels; the rat and rabbit gavage studies were described briefly with limited information on results.

Summary of the Principal Study:

McCollister DD, Lockwood DT, Rowe VK. 1961. Toxicologic information on 2,4,5-trichlorophenol. Toxicol Appl Pharmacol 3:63–70.13773805

2,4,5-TCP was administered to 10 male and 10 female rats in the diet at 0, 0.01, 0.03, 0.1, 0.3, or 1% for 98 days. Doses of 0, 10, 30, 100, 300, and 1,000 mg/kg/day (respectively) were provided by the authors. Body weights were measured regularly and animals were observed for clinical signs of toxicity. Food intake was recorded for the first month of the experiment. At termination, hematological parameters (hematocrit, hemoglobin, white blood cell counts) and BUN were measured in a subgroup of female rats (number not reported). Organ weights (lungs, heart, liver, kidneys, spleen, testes, and brain) were recorded, and histologic examinations of these organs along with the pancreas and adrenal glands were completed. At 100 mg/kg/day, there were no adverse effects in either sex. At doses of 300 and 1,000 mg/kg/day, rats showed diarrhea and pathologic changes in the liver and kidneys. In the highest dose group, the changes in the kidneys were described as moderate degenerative changes in the epithelial lining of the convoluted tubules and early proliferation of the interstitial tissue, and the changes in the liver were described as cloudy swelling with occasional areas of focal necrosis, slight proliferation of the bile ducts and early portal cirrhosis. These liver and kidney changes in the 300 mg/kg/day group were described as similar but milder in severity than in the high-dose group. At the 1,000 mg/kg/day level, there was also a significant retardation (24% decrease in body weight gain) of growth in females. Relative kidney and liver weights were not affected by treatment, nor was BUN; no other clinical chemistry parameters were evaluated. A LOAEL of 300 mg/kg/day and NOAEL of 100 mg/kg/day were identified for degenerative changes in the kidneys and liver (incidences not reported) and diarrhea.

Selection of the Point of Departure for the MRL: The NOAEL of 100 mg/kg/day for degenerative changes in the liver and kidney was selected as the POD. BMD modeling of the data in the study by McCollister et al. (1961) was not possible because the study findings were reported qualitatively.

Uncertainty Factor: The NOAEL was divided by a total UF of 100:

- 10 UF for extrapolation from animals to humans
- 10 UF for human variability

- MRL = NOAEL ÷ (UF × MF)
- 100 mg/kg/day ÷ (10 × 10) = 1 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The liver is a well-established target of chlorophenol toxicity in laboratory animals. Hepatic effects including clinical chemistry changes, increased liver weight, hepatocellular hypertrophy, and necrosis have been observed in rats or mice after oral exposure to 2-CP, 4-CP, 2,4-DCP, 2,4,6-TCP, and 2,3,4,6-TeCP (Aydin et al. 2009; Bercz et al. 1990; BSRC 2011; Dodd et al. 2012; Exon and Koller 1985; Exon et al. 1984; Hasegawa et al. 2005; Kobayashi et al. 1972; NCI 1979; NTP 1989).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,5-Trichlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,5-Trichlorophenol
CAS Numbers: | 95-95-4
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 2,4,5-TCP due to the lack of chronic duration studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. No chronic-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,6-Trichlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,6-Trichlorophenol
CAS Numbers: | 88-06-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 2,4,6-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,6-Trichlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,6-Trichlorophenol
CAS Numbers: | 88-06-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 2,4,6-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,6-Trichlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,6-Trichlorophenol
CAS Numbers: | 88-06-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 2,4,6-TCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,6-Trichlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,6-Trichlorophenol
CAS Numbers: | 88-06-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 2,4,6-TCP, as the only available study examined limited endpoints.

Rationale for Not Deriving an MRL: The acute-duration oral data were not considered adequate for derivation of an acute-duration oral MRL for 2,4,6-TCP.

No adequate exposure-response data were available for humans. Only one acute-duration animal study of oral exposure to 2,4,6-TCP was located. In that study (Carlson 1978), no effects were observed on hepatic enzyme levels, the only endpoints evaluated, in rats exposed to doses up to 400 mg/kg/day administered by gavage for 14 days (Carlson 1978). These data were not considered adequate for MRL derivation due to the limited evaluations performed and the lack of information needed to identify the critical effect.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,6-Trichlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,6-Trichlorophenol
CAS Numbers: | 88-06-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.005 mg/kg/day (5 μg/kg/day)
Critical Effect: | Increased absolute liver weight
Reference: | Exon and Koller 1985
Point of Departure: | NOAEL of 0.46 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 6
Species: | Rats

MRL Summary: An intermediate-duration oral MRL of 0.005 mg/kg/day (5 μg/kg/day) was derived for 2,4,6-TCP based on increased absolute liver weight in rats exposed to 2,4,6-TCP from conception through weaning (via maternal exposure) and for 12 additional weeks in drinking water (Exon and Koller 1985). The NOAEL of 0.46 mg/kg/day was used as the POD. A total uncertainty factor of 100 (10 for interspecies extrapolation and 10 for human variability) was applied to the NOAEL to obtain the intermediate-duration oral MRL.

Selection of the Critical Effect: No dose-response data are available for humans. Table A-13 summarizes results from candidate intermediate-duration oral studies in laboratory animals. The lowest LOAEL was for increased absolute liver weight in the rat study by Exon and Koller (1985). Exon and Koller (1985) did not evaluate clinical chemistry or histopathology. Bercz et al. (1990) did not observe liver effects at a much higher dose (80 mg/kg/day) in the same strain of rat. However, Exon and Koller (1985) exposed Sprague-Dawley rats beginning at conception, while Bercz et al. (1990) exposed Sprague-Dawley rats beginning at 49 days of age. Thus, the lower dose at which liver effects were seen by Exon and Koller (1985) may reflect greater sensitivity of younger rats. The liver is a well-established target organ for chlorophenol toxicity, supporting the selection of this endpoint for the critical effect. Hepatic effects including clinical chemistry changes, increased liver weights, hepatocellular hypertrophy, vacuolation, and necrosis have been observed in rats or mice after oral exposure to 2-CP, 4-CP, 2,4-DCP, 2,4,5-TCP, and 2,3,4,6-TeCP (Aydin et al. 2009; BSRC 2011; Dodd et al. 2012; Exon and Koller 1985; Exon et al. 1984; Hasegawa et al. 2005; Kobayashi et al. 1972; McCollister et al. 1961; NTP 1989).

Table A-13 Summary of Intermediate-Duration Studies in Experimental Animals Orally Exposed to 2,4,6-Trichlorophenol

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Liver effects
Rat (Sprague-Dawley) | Dams: from weaning through mating at PND 90, gestation, and lactation; Offspring: from conception through weaning (PND 21) and for additional 12 weeks (W) | 0.46 | 4.6 | 15% increase in offspring absolute liver weight | Exon and Koller 1985
Rat (Sprague-Dawley) | 90 days (GO) | 80 | 240 | 14% increase in relative liver weight | Bercz et al. 1990
Reproductive effects
Rat (Sprague-Dawley) | Dams: from weaning through mating at PND 90, gestation, and lactation; Offspring: from conception through weaning (PND 21) and for additional 12 weeks (W) | 4.6 | 46 | Decreased mean litter size | Exon and Koller 1985
Developmental effects
Rat (Long-Evans hooded) | 2 week premating at 5 days/week; then GDs 1–21 at 7 days/week (GO) | 100 | 500 | 10–11% reduction in litter weight | Blackburn et al. 1986
Body weight effects
Rat (F344) | 7 weeks, 7 days/week (F) | 500 | 735 | 11–16% decreased body weight | NCI 1979

(F) = feed; (GO) = gavage in oil vehicle; GD = gestation day; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; PND = postnatal day; (W) = water

Selection of the Principal Study: The Exon and Koller (1985) study was selected as the principal study because this study identified the lowest LOAEL and NOAEL (4.6 and 0.46 mg/kg/day, respectively, for hepatic effects).

Summary of the Principal Study:

Exon JH, Koller LD. 1985. Toxicity of 2-chlorophenol, 2,4-dichlorophenol and 2,4,6-trichlorophenol. In: Jolley RL, ed. Water chlorination: Chemistry, environmental impact and health effects. Vol. 5. Chelsea, MI: Lewis Publishers, 307–330.

The effect of pre- and postnatal exposure to 2,4,6-TCP on body and organ weights was evaluated in rats. 2,4,6-TCP (purity=98%) was administered in the drinking water of female Sprague-Dawley rats (12–14 rats/group) at concentrations of either 0, 3, 30, or 300 ppm (0, 0.46, 4.6, or 46 mg/kg/day, respectively). Treatment with 2,4,6-TCP was initiated at 3 weeks of age and continued through breeding (at 90 days of age), parturition, and lactation. The reproductive/developmental parameters evaluated included conception (%), mean litter size, number of stillborn, birth weight of pups, and survival of pups to weaning (%). Ten randomly selected pups (sex not specified) from each group were weaned at 3 weeks and continued on 2,4,6-TCP treatment for 12 weeks. Mean body weight and mean weights of thymus, spleen, and liver were recorded. Histopathology examination was not performed. Mean body and organ weights were evaluated statistically by analysis of variance and least-square means.

The conception, pup birth weight, and survival of pups to weaning were similar in control and treated rats. The percentage of stillborn pups was increased in all treatment groups, but this increase was not statistically significant. Mean litter size was similar in rats treated with 0, 0.46, or 4.6 mg/kg/day; however, mean litter size was significantly reduced (p<0.1) in rats of the 46 mg/kg/day group. The mean litter sizes were 12.1, 11.3, 11.2, and 9.1 in control through high dose respectively. Mean terminal body weight and mean thymus weight of offspring exposed pre- and postnatally to 2,4,6-TCP were comparable to those of controls. Mean spleen weight was significantly increased (p< 0.05) in offspring treated with 46 mg/kg/day, and mean liver weight was significantly increased at 4.6 (15% higher than controls) and 46 mg/kg/day (29% higher than controls). The LOAEL and NOAEL for this study were 4.6 and 0.46 mg/kg/day (respectively) based on increased liver weight.

Selection of the Point of Departure for the MRL: The NOAEL of 0.46 mg/kg/day was used as the POD for the MRL.

The lowest LOAEL of 4.6 mg/kg/day for increased absolute liver weight (Exon and Koller 1985) was 10-fold lower than the nearest LOAEL (46 mg/kg/day); thus, only this endpoint and study was considered for the POD. The absolute liver weight reported by Exon and Koller (1985) are shown in Table A-14.

Table A-14 Absolute Liver Weight in Rats Exposed to 2,4,6-Trichlorophenol from Conception Through Weaning and for 12 Additional Weeks

Endpoint (reference) | Dose (mg/kg/day)
Endpoint (reference) | 0 | 0.46 | 4.6 | 46
Liver weight (mean±standard error) | 10.9±0.4 | 11.9±0.3 | 12.5±0.5^a^ | 14.1±0.6^a^
Calculated standard deviation | 1.26 | 0.95 | 1.58 | 1.90
Number/group | 10 | 10 | 10 | 10

a p≤0.05 compared with controls based on analysis of variance (ANOVA) and least squares means performed by study authors.

Source: Exon and Koller 1985

The liver weight data were fit to all available continuous models in EPA’s BMDS (version 3.1.2). Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL was selected as the POD when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest AIC was chosen. A BMR of 1 standard deviation from the control mean was selected for the liver weight data.

The model predictions for absolute liver weight are shown in Table A-15 and the fit of the selected (Hill) model is shown in Figure A-3.

Table A-15 Results from BMD Analysis (Constant Variance) of Absolute Liver Weights in Male and Female Sprague-Dawley Rats Exposed to 2,4,6-Trichlorophenol

Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Scaled residuals^d^ | | | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Exponential (model 2)^e^ | <0.001 | 0.17 | 0.09 | 1.30 | −0.11 | −1.64 | 150.79 | ND | ND
Exponential (model 3)^e^ | <0.001 | 0.17 | 0.09 | 1.30 | −0.11 | −1.64 | 150.79 | ND | ND
Exponential (model 4)^e^ | <0.001 | 0.17 | 0.18 | −0.18 | 0.02 | 1.00 | 149.71 | 5.24 | 1.97
Exponential (model 5)^e^ | <0.001 | 0.17 | 0.18 | −0.18 | 0.02 | 1.00 | 149.71 | 5.24 | 1.97
Hill ^e^ ^,^ ^f^ | <0.001 | 0.17 | 0.20 | −0.29 | 0.06 | 0.97 | 149.54 | 4.75 | 0.64
Polynomial (2-degree)^e^ | <0.001 | 0.17 | 0.09 | 1.27 | −0.13 | −1.62 | 150.67 | ND | ND
Polynomial (3-degree)^e^ | <0.001 | 0.17 | 0.09 | 1.27 | −0.13 | −1.62 | 150.67 | ND | ND
Power^e^ | <0.001 | 0.17 | 0.09 | 1.27 | −0.13 | −1.62 | 150.67 | ND | ND
Linear | <0.001 | 0.17 | 0.09 | 1.27 | −0.13 | −1.62 | 150.67 | ND | ND

a Values >0.05 fail to meet conventional goodness-of-fit criteria.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Values <0.1 fail to meet conventional goodness-of-fit criteria.

d Scaled residuals at doses immediately below and above the benchmark dose; also the largest residual at any dose.

e Restricted model.

f Recommended model. There was an adequate fit to the variance when assuming constant variance. Only the Exponential 4, Exponential 5, and Hill models provided adequate fit to the means. Of the adequately fit models, the BMDLs were not sufficiently close (differed by >3-fold), suggesting that the model with the lowest BMDL should be selected (Hill). However, EPA’s BMDS guidance notes that models with an asymptote term (which includes the Hill and Exponential 4 and 5 models) may not support reasonable BMD and BMDL values when the observed data appear to be supralinear. As the modeled data appear supralinear, the BMD results were not selected for use in deriving the MRL.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control); BMDS =Benchmark Dose Software; EPA = U.S. Environmental Protection Agency; MRL = Minimal Risk Level; ND = not determined, the test for the means failed to meet conventional goodness-of-fit criteria

Figure A-3 Fit of Hill Model to Absolute Liver Weight Data in Rats Administered 2,4,6-Trichlorophenol from Conception Through Weaning and for 12 Additional Weeks in Drinking Water

Figure A-3 description

Three models provided adequate fit to the liver weight data: the Hill and Exponential 4 and 5 models. However, EPA’s BMDS guidance notes that models with an asymptote term (which includes the Hill and Exponential 4 and 5 models) may not support reasonable BMD and BMDL values when the observed data appear to be supralinear. Because the liver weight data from Exon and Koller (1985) do appear supralinear, the BMD results were not selected for use in deriving the MRL. The NOAEL of 0.46 mg/kg/day was selected as the POD for the intermediate-duration oral MRL for 2,4,6-TCP.

Uncertainty Factor: The NOAEL was divided by a total uncertainty factor (UF) of 100:

- 10 UF for extrapolation from animals to humans
- 10 UF for human variability

- MRL = NOAEL ÷ (UF)
- 0.46 mg/kg/day ÷ (10 × 10) = 0.0046 mg/kg/day ≈ 0.005 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The liver is a well-established target of chlorophenol toxicity in laboratory animals. Hepatic effects including clinical chemistry changes, increased liver weight, hepatocellular hypertrophy, and necrosis have been observed in rats or mice after oral exposure to 2-CP, 4-CP, 2,4-DCP, 2,4,5-TCP, and 2,3,4,6-TeCP (Aydin et al. 2009; Bercz et al. 1990; BSRC 2011; Dodd et al. 2012; Exon and Koller 1985; Exon et al. 1984; Hasegawa et al. 2005; Kobayashi et al. 1972; McCollister et al. 1961; NCI 1979; NTP 1989).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,4,6-Trichlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,4,6-Trichlorophenol
CAS Numbers: | 88-06-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 2,4,6-TCP; available studies identified only serious LOAELs in the absence of NOAELs.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. Table A-16 summarizes results from available chronic-duration oral studies in experimental animals.

Table A-16 Summary of NOAELs and LOAELs from Candidate Chronic-Duration Studies in Experimental Animals Orally Exposed to 2,4,6-Trichlorophenol

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Rat (F344) | 2 years (F) | ND | 250 (serious LOAEL) | High incidence of bone marrow hyperplasia; remaining animals had leukemia | NCI 1979
Mouse (B6C3F1) | 2 years (F) | ND | 650 (serious LOAEL) | Hepatic hyperplasia; hepatocellular carcinomas or adenomas; 24% decrease in body weight | NCI 1979

(F) = feed; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

It is not appropriate to derive a chronic-duration oral MRL for 2,4,6-TCP because the lowest effect levels from chronic studies represent serious LOAELs in the absence of identified NOAELs, and because the lowest doses tested were higher than LOAELs identified for intermediate-duration exposures.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,5-Tetrachlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,5-Tetrachlorophenol
CAS Numbers: | 4901-51-3
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 2,3,4,5-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,5-Tetrachlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,5-Tetrachlorophenol
CAS Numbers: | 4901-51-3
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 2,3,4,5-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,5-Tetrachlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,5-Tetrachlorophenol
CAS Numbers: | 4901-51-3
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 2,3,4,5-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,5-Tetrachlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,5-Tetrachlorophenol
CAS Numbers: | 4901-51-3
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 2,3,4,5-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. The only information on the health effects of 2,3,4,5-TeCP following oral exposure in animals was acute lethality data following a single exposure (Ahlborg and Larsson 1978).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,5-Tetrachlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,5-Tetrachlorophenol
CAS Numbers: | 4901-51-3
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for 2,3,4,5-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,5-Tetrachlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,5-Tetrachlorophenol
CAS Numbers: | 4901-51-3
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 2,3,4,5-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. No chronic-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,6-Tetrachlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,6-Tetrachlorophenol
CAS Numbers: | 58-90-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 2,3,4,6-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,6-Tetrachlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,6-Tetrachlorophenol
CAS Numbers: | 58-90-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 2,3,4,6-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,6-Tetrachlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,6-Tetrachlorophenol
CAS Numbers: | 58-90-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 2,3,4,6-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,6-Tetrachlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,6-Tetrachlorophenol
CAS Numbers: | 58-90-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.08 mg/kg/day
Critical Effect: | Hepatic effects (liver weight increases and histopathology)
Reference: | Dodd et al. 2012
Point of Departure: | BMDL_1SD_ of 8.45 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 5
Species: | Rats

MRL Summary: An acute-duration oral MRL of 0.08 mg/kg/day has been derived for 2,3,4,6-TeCP, based on hepatic effects in rats administered 2,3,4,6-TeCP by daily gavage for 14 days (Dodd et al. 2012). A BMDL_1SD_ of 8.45 mg/kg/day was calculated for increased relative liver weight and used as the POD; this value was divided by an uncertainty factor of 100 (10 for interspecies extrapolation and 10 for human variability) to derive the MRL.

Selection of the Critical Effect: No adequate exposure-response data were available for humans. Two studies were considered candidate principal studies for deriving an acute-duration oral MRL for 2,3,4,6-TeCP. A third acute-duration study (Hattula et al. 1981) was not considered because the test material used in the study contained a large proportion of contaminants including pentachlorophenol and dioxins (IRIS 1988). Table A-17 summarizes results from candidate acute-duration oral studies in experimental animals. EPA (1987a, 1987b) was a developmental toxicity study, while Dodd et al. (2012) evaluated liver effects in adult animals; both studies were 14 days in duration.

Table A-17 Summary of Acute-Duration Studies in Experimental Animals Orally Exposed to 2,3,4,6-TeCP

Species | Duration (Route) | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Liver effects
Sprague-Dawley rat | 14 days (GO) | 10 | 25 | Increased absolute and relative liver weights; low incidence of vacuolation | Dodd et al. 2012
Body weight effects
CD rat | 14 days (GDs 6–15) (GO) | 25 | 100 | 13% decrease in maternal body weight gain | EPA 1987a, 1987b

GD = gestation day; (GO) = gavage in oil vehicle); LOAEL = lowest observed adverse effect level; NOAEL = no-observed-adverse-effect level

The lowest LOAEL for an acute-duration study was 25 mg/kg/day for liver effects in the study by Dodd et al. (2012).

Selection of the Principal Study: The Dodd et al. (2012) study was selected as the principal study as it was well-conducted, thoroughly reported, and identified the lowest LOAEL.

Summary of the Principal Study:

Dodd DE, Pluta LJ, Sochaski MA, . 2012. Subchronic hepatotoxicity evaluation of 2,3,4,6-tetra-chlorophenol in Sprague-Dawley rats. J Toxicol 2012:376246. 10.1155/2012/376246.22666246

In the study by Dodd et al. (2012), male Sprague-Dawley rats (10/group) were administered 2,3,4,6-TeCP in olive oil (0, 10, 25, 50, 100, or 200 mg/kg/day) by daily gavage for 2 weeks. Clinical signs were recorded and body weights were measured daily. At sacrifice at the end of exposure, blood was collected for serum chemistry (ALT, AST, alkaline phosphatase, LDH, and bilirubin) and the liver was excised for weight and microscopic examination. No clinical signs of toxicity were noted and there was no adverse effect of treatment on body weight at any dose. Serum ALT levels were statistically significantly increased (70% relative to controls) at 200 mg/kg/day; lower doses were not affected, and no other serum chemistry changes were observed. Significantly increased absolute (≥15% at ≥25 mg/kg/day) and relative (≥9% at ≥10 mg/kg/day) liver weights were noted. Single cell necrosis and hepatocellular hypertrophy were observed at ≥50 mg/kg/day, with statistically significant increased incidences in the 100 and 200 mg/kg/day groups. Centrilobular hepatocytic vacuolation was observed at doses ≥25 mg/kg/day, but the incidence was statistically significantly increased only in the 200 mg/kg/day group. A LOAEL of 25 mg/kg/day and NOAEL of 10 mg/kg/day were identified for hepatic effects. Table A-18 presents summary data for hepatic effects among rats exposed to 2,3,4,6-TeCP for 2 weeks (Dodd et al. 2012).

Table A-18 Liver Weight and Histopathology Data for Rats Exposed to 2,3,4,6-Tetrachlorophenol by Gavage for 2 weeks

Test | Dose (mg/kg/day)
Test | 0 | 10 | 25 | 50 | 100 | 200
Absolute liver weight (g) | 13.8±1.5^a^ | 15.2±1.3 | 15.9±1.7^b^ | 17.9±2.1^c^ | 19.5±1.8^c^ | 21.4±2.3^c^
Relative liver weight (%) | 3.89±0.24 | 4.25±0.27^b^ | 4.43±0.25^c^ | 4.96±0.34^c^ | 5.56±0.23^c^ | 6.36±0.32^c^
Vacuolation (centrilobular) | 0/11^d^ | 0/10 | 1/10 (1.0) | 1/10 (1.0) | 4/10 (1.5) | 7/10^e^ (1.6)
Hypertrophy (centrilobular) | 0/11 | 0/10 | 0/10 | 4/10 (1.0) | 10/10^c^ (2.0) | 10/10^c^ (3.4)
Necrosis (centrilobular) | 0/11 | 0/10 | 0/10 | 2/10 (1.0) | 6/10^b^ (1.0) | 9/10^c^ (2.3)

a Mean±standard deviation.

b p<0.05 compared to control based on analysis of variance (ANOVA) and Dunnet’s test performed by study authors.

c p<0.001 compared to control.

d Incidence (average severity score). Severity scores were 1:minimal, 2: slight/mild, 3:moderate, 4: moderately severe, and 5: severe/high.

e p<0.01 compared to control.

Source: Dodd et al. 2012

Selection of the Point of Departure for the MRL: The BMDL_1SD_ of 8.45 mg/kg/day for increased relative liver weight was selected as basis for deriving an acute-duration oral MRL for 2,3,4,6-TeCP.

The liver weight and histopathology data were fit to all available continuous or dichotomous models (respectively) in EPA’s BMDS (version 3.1.2). Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL (95% lower confidence limit on the benchmark concentration) was selected as the POD when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest AIC was chosen. For the liver weight data, a BMR of 1 standard deviation from the control mean was selected. For the histopathology incidence data, a BMR of 10% extra risk was used.

No model fit was achieved with the full dataset on centrilobular hypertrophy, or when the high dose was dropped. Dropping the two highest doses would result in only one dose with a nonzero incidence, so no additional modeling was done with this dataset. The model predictions for absolute and relative liver weights and hepatic vacuolation and necrosis are shown in Tables A-19, A-20, A-21, and A-22 (respectively), and the fit of the selected models are shown in Figures A-4, A-5, A-6, and A-7 (respectively).

Table A-19 Results from BMD Analysis (Constant Variance) of Absolute Liver Weights in Male Rats Exposed to 2,3,4,6-Tetrachlorophenol for 2 Weeks (Dodd et al. 2012)

Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Scaled residuals^d^ | | | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Exponential (model 2)^e^ | <0.0001 | 0.50 | 0.00 | 1.99 | 1.91 | −2.30 | 261.58 | 64.59 | 53.98
Exponential (model 3)^e^ | <0.0001 | 0.50 | 0.00 | 1.99 | 1.91 | −2.30 | 261.58 | 64.59 | 53.98
Exponential (model 4)^e^ | <0.0001 | 0.50 | 0.84 | 0.55 | −0.39 | 0.55 | 248.01 | 19.42 | 13.06
Exponential (model 5)^e^ | <0.0001 | 0.50 | 0.84 | 0.55 | −0.39 | 0.55 | 248.01 | 19.41 | 13.06
Hill ^e^ ^,^ ^f^ | <0.0001 | 0.50 | 0.88 | 0.47 | −0.55 | −0.55 | 247.86 | 17.40 | 10.68
Polynomial (2-degree)^e^ | <0.0001 | 0.50 | 0.01 | 1.90 | 1.56 | −2.00 | 258.12 | 53.03 | 43.40
Polynomial (3-degree)^e^ | <0.0001 | 0.50 | 0.01 | 1.90 | 1.56 | −2.00 | 258.12 | 53.03 | 43.40
Polynomial (4-degree)^e^ | <0.0001 | 0.50 | 0.01 | 1.90 | 1.56 | −2.00 | 258.12 | 53.03 | 43.40
Polynomial (5 degree)^e^ | <00001 | 0.50 | 0.01 | 1.90 | 1.56 | −2.00 | 258.12 | 53.03 | 43.41
Power^e^ | <0.0001 | 0.50 | 0.01 | 1.90 | 1.56 | −2.00 | 258.12 | 53.03 | 43.40
Linear | <0.0001 | 0.50 | 0.01 | 1.90 | 1.56 | −2.00 | 258.12 | 53.03 | 43.40

a Values >0.05 fail to meet conventional goodness-of-fit criteria.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Values <0.1 fail to meet conventional goodness-of-fit criteria.

d Scaled residuals at doses immediately below and above the benchmark dose; also the largest residual at any dose.

e Restricted model.

f Recommended model. There was an adequate fit to the variance when assuming constant variance. The Exponential 4, Exponential 5, and Hill models provided adequate fit to the means. Of the adequately fit models, the BMDLs were sufficiently close (differed by < 3-fold); therefore, the model with the lowest AIC was selected (Hill).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control)

Figure A-4 Fit of Hill Model to Absolute Liver Weight Data in Rats administered 2,3,4,6-Tetrachlorophenol by Gavage for 14 Days

Figure A-4 description

Table A-20 Results from BMD Analysis (Constant Variance) of Relative Liver Weights in Male Rats Exposed to 2,3,4,6-Tetrachlorophenol for 2 Weeks (Dodd et al. 2012)

Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Scaled residuals^d^ | | | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Exponential (model 2)^e^ | <0.0001 | 0.76 | <0.0001 | −0.15 | 2.39 | −3.04 | 50.17 | 36.12 | 31.08
Exponential (model 3)^e^ | <0.0001 | 0.76 | <0.0001 | −0.15 | 2.39 | −3.04 | 50.17 | 36.11 | 31.08
Exponential (model 4)^e^ | <0.0001 | 0.76 | 0.57 | 0.99 | −0.56 | 0.99 | 20.37 | 11.77 | 9.33
Exponential (model 5)^e^ | <0.0001 | 0.76 | 0.57 | 0.99 | −0.56 | 0.99 | 20.37 | 11.77 | 9.33
Hill ^e^ ^,^ ^f^ | <0.0001 | 0.76 | 0.62 | 0.96 | −0.71 | 0.96 | 20.15 | 11.01 | 8.45
Polynomial (2-degree)^e^ | <0.0001 | 0.76 | 0.00 | −0.06 | 2.23 | −2.56 | 39.76 | 26.68 | 22.75
Polynomial (3-degree)^e^ | <0.0001 | 0.76 | 0.00 | −0.06 | 2.23 | −2.56 | 39.76 | 26.68 | 22.75
Polynomial (4-degree)^e^ | <0.0001 | 0.76 | 0.00 | −0.06 | 2.23 | −2.56 | 39.76 | 26.68 | 22.75
Polynomial (5 degree)^e^ | <0.0001 | 0.76 | 0.00 | −0.06 | 2.23 | −2.56 | 39.76 | 26.68 | 22.82
Power^e^ | <0.0001 | 0.76 | 0.00 | −0.06 | 2.23 | −2.56 | 39.76 | 26.68 | 22.75
Linear | <0.0001 | 0.76 | 0.00 | −0.06 | 2.23 | −2.56 | 39.76 | 26.68 | 22.75

a Values >0.05 fail to meet conventional goodness-of-fit criteria.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Values <0.1 fail to meet conventional goodness-of-fit criteria.

d Scaled residuals at doses immediately below and above the benchmark dose; also the largest residual at any dose.

e Restricted model.

f Recommended model. There was an adequate fit to the variance when assuming constant variance. The Exponential 4, Exponential 5, and Hill models provided adequate fit to the means. Of the adequately fit models, the BMDLs were sufficiently close (differed by < 3-fold); therefore, the model with the lowest AIC was selected (Hill).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with one standard deviation from the control mean)

Figure A-5 Fit of Hill Model to Relative Liver Weight Data in Rats Administered 2,3,4,6-Tetrachlorophenol by Gavage for 14 Days

Figure A-5 description

Table A-21 Model Predictions for Vacuolation (Centrilobular) in Male Rats Exposed to 2,3,4,6-Tetrachlorophenol (Dodd et al. 2012)

Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg/day) | BMDL^10^ (mg/kg/day)
Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_10_ (mg/kg/day) | BMDL^10^ (mg/kg/day)
Dichotomous Hill | 2 | 0.86 | 0.65 | 0.71 | −0.49 | 0.71 | 47.56 | 37.62 | 16.33
Gamma^c^ | 4 | 0.78 | 0.94 | 0.63 | −0.47 | 0.63 | 43.53 | 37.10 | 16.48
Logistic | 4 | 2.29 | 0.68 | −0.09 | 0.95 | 0.95 | 45.78 | 61.29 | 42.54
LogLogistic^d^ | 4 | 0.86 | 0.93 | 0.71 | −0.49 | 0.71 | 43.56 | 37.62 | 16.33
LogProbit^d^ | 3 | 0.97 | 0.81 | 0.73 | −0.60 | 0.73 | 45.64 | 35.86 | 16.67
Multistage (1-degree) ^e^ ^,^ ^f^ | 5 | 1.59 | 0.90 | −0.69 | −0.10 | −0.84 | 42.87 | 22.60 | 14.62
Multistage (2-degree)^e^ | 3 | 0.79 | 0.87 | 0.49 | −0.40 | 0.49 | 45.67 | 36.95 | 16.23
Multistage (3-degree)^e^ | 4 | 0.79 | 0.94 | 0.49 | −0.40 | 0.49 | 43.68 | 36.95 | 16.23
Multistage (4-degree)^e^ | 4 | 0.79 | 0.94 | 0.49 | −0.40 | 0.49 | 43.67 | 36.95 | 16.23
Multistage (5-degree)^e^ | 4 | 0.79 | 0.94 | 0.49 | −0.40 | 0.49 | 43.67 | 36.95 | 16.23
Probit | 4 | 1.98 | 0.74 | −0.09 | 0.85 | 0.85 | 45.29 | 57.15 | 40.15
Weibull^c^ | 3 | 0.76 | 0.86 | 0.58 | −0.45 | 0.58 | 45.56 | 37.03 | 16.44

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

ef Betas restricted to ≥0.

f Selected model. All models provided adequate fits to the data. BMDLs for models providing adequate fit were sufficiently close (differed by <3-fold). Therefore, the model with the lowest AIC was selected (Multistage [1-degree]).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with 10% extra risk); DF = degrees of freedom; ND = not determined, goodness-of-fit criteria, p<0.10

Figure A-6 Fit of Multistage Degree 1 Model to Hepatic Vacuolation Data in Rats Administered 2,3,4,6-Tetrachlorophenol by Gavage for 14 Days

Figure A-6 description

Table A-22 Model Predictions for Necrosis (Centrilobular) in Male Rats Exposed to 2,3,4,6-Tetrachlorophenol (Dodd et al. 2012)

Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Dichotomous Hill | 3 | 0.37 | 0.95 | −0.43 | 0.37 | 0.37 | 36.53 | 42.70 | 24.58
Gamma^c^ | 4 | 0.71 | 0.95 | −0.56 | 0.30 | −0.56 | 34.99 | 40.03 | 21.79
Logistic | 4 | 3.95 | 0.41 | −0.79 | 0.63 | −1.29 | 38.48 | 47.49 | 32.48
LogLogistic^d^ | 3 | 0.42 | 0.94 | −0.76 | 0.63 | 1.02 | 36.65 | 41.38 | 24.20
LogProbit^d^ | 3 | 0.28 | 0.96 | −0.42 | 0.25 | −0.41 | 36.42 | 41.15 | 24.79
Multistage (1-degree)^e,f^ | 5 | 4.54 | 0.47 | −0.87 | −1.41 | −1.41 | 39.10 | 14.57 | 9.78
Multistage (2-degree) ^e^ | 5 | 1.28 | 0.94 | −0.67 | 0.33 | −0.67 | 33.70 | 38.65 | 18.62
Multistage (3-degree)^e^ | 5 | 1.28 | 0.94 | −0.67 | 0.33 | −0.67 | 33.70 | 38.65 | 18.56
Multistage (4-degree)^e^ | 5 | 1.28 | 0.94 | −0.67 | 0.33 | −0.67 | 33.70 | 38.65 | 18.56
Multistage (5-degree)^e^ | 5 | 1.28 | 0.94 | −0.67 | 0.33 | −0.67 | 33.70 | 38.65 | 18.56
Probit | 4 | 3.59 | 0.46 | −0.77 | 0.63 | −1.03 | 38.25 | 46.02 | 31.42
Weibull^c^ | 3 | 1.15 | 0.76 | −0.71 | 0.24 | −0.71 | 37.67 | 36.92 | 19.34

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMC; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

ef Betas restricted to ≥0.

f Selected model. All models provided adequate fits to the data. BMDLs for models providing adequate fit differed by >3-fold. However, the model with the lowest BMDL (1-degree polynomial multistage) was an outlier and predicted a BMD below the NOAEL of 25 mg/kg/day. Therefore, the model with the lowest AIC was selected (Multistage [2-degree]).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with 10% extra risk); DF = degrees of freedom; ND = not determined, goodness-of-fit criteria, p<0.10

Figure A-7 Fit of Multistage 2 Degree Model to Hepatic Necrosis Data in Rats Administered 2,3,4,6-Tetrachlorophenol by Gavage for 14 Days

Figure A-7 description

A comparison of the BMDs and BMDLs for the selected models is shown in Table A-23.

Table A-23 Benchmark Dose Modeling Results for Hepatic Endpoints in 2-Week Rat Study by Dodd et al. (2012)

Endpoint | Selected model | BMD (mg/kg/day) | BMDL (mg/kg/day)
Absolute liver weight (g) | Hill | 17.40 | 10.68
Relative liver weight (%) | Hill | 11.01 | 8.45
Vacuolation (centrilobular) | 1-degree multistage | 22.60 | 14.62
Necrosis (centrilobular) | 2-degree multistage | 38.65 | 18.62

The lowest BMDL was the BMDL_1SD_ of 8.45 mg/kg/day for increased relative liver weight; this value was selected as the POD.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The BMDL_1SD_ was divided by a total uncertainty factor (UF) of 100:

- 10 UF for extrapolation from animals to humans
- 10 UF for human variability

- MRL = BMDL_1SD_ ÷ (UF)
- 8.45 mg/kg/day ÷ (10 × 10) = 0.0845 mg/kg/day ≈ 0.08 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The liver is a well-established target of chlorophenol toxicity in laboratory animals. Hepatic effects including clinical chemistry changes, increased liver weight, hepatocellular hypertrophy, and necrosis have been observed in rats or mice after oral exposure to 2-CP, 4-CP, 2,4-DCP, 2,4,5-TCP, and 2,4,6-TCP (Bercz et al. 1990; Aydin et al. 2009; BSRC 2011; Exon and Koller 1985; Exon et al. 1984; Hasegawa et al. 2005; Kobayashi et al. 1972; McCollister et al. 1961; NCI 1979; NTP 1989).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,6-Tetrachlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,6-Tetrachlorophenol
CAS Numbers: | 58-90-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.01 mg/kg/day
Critical Effect: | Hepatic Effects (liver weight increases and histopathology)
Reference: | Dodd et al. 2012
Point of Departure: | BMDL_10_ of 1.02 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 8
Species: | Rats

MRL Summary: An intermediate-duration oral MRL of 0.01 mg/kg/day was derived for 2,3,4,6-TeCP based on hepatic effects in rats administered 2,3,4,6-TeCP by gavage for 13 weeks (Dodd et al. 2012). BMD analysis was used to identify a BMDL_10_ of 1.02 mg/kg/day for hepatocellular hypertrophy. A total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) was applied to the BMDL_10_ of 1.02 mg/kg/day.

Selection of the Critical Effect: No dose-response data are available for humans. Table A-24 summarizes results from candidate intermediate-duration oral studies in experimental animals. Two studies were considered potential candidate principal studies for deriving an intermediate-duration oral MRL for 2,3,4,6-TeCP. A third intermediate-duration study (Hattula et al. 1981) was not considered because the test material used in the study contained a large proportion of contaminants including pentachlorophenol and dioxins (IRIS 1988).

Table A-24 Summary of NOAELs and LOAELs from Candidate Intermediate-Duration Studies in Experimental Animals Orally Exposed to 2,3,4,6-Tetrachlorophenol

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Liver effects
Sprague-Dawley rat | 13 weeks, 7 days/week (GO) | ND | 10 | Increased liver weights; centrilobular vacuolation and hypertrophy | Dodd et al. 2012
Sprague-Dawley rat | 13 weeks, 7 days/week (GO) | 25 | 100 | Increased liver and kidney weights, centrilobular hypertrophy | EPA 1986

(GO) = gavage in oil vehicle; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study:

The study by Dodd et al. (2012) was selected because it tested lower doses and identified a lower LOAEL for the same endpoint (hepatic effects) as the EPA (1986) study.

Summary of the Principal Study:

Dodd DE, Pluta LJ, Sochaski MA, . 2012. Subchronic hepatotoxicity evaluation of 2,3,4,6-tetra-chlorophenol in Sprague-Dawley rats. J Toxicol 2012:376246. 10.1155/2012/376246.22666246

In the study by Dodd et al. (2012), male Sprague-Dawley rats (10/group) were administered 2,3,4,6-TeCP in olive oil (0, 10, 25, 50, 100, or 200 mg/kg/day) by daily gavage for 13 weeks. Clinical signs were recorded and body weights were measured daily. At sacrifice at the end of exposure, blood was collected for serum chemistry (ALT, AST, alkaline phosphatase, LDH, and bilirubin) and the liver was excised for weight and microscopic examination. No clinical signs of toxicity were noted. Mean body weights were decreased by 12 and 22% at 100 and 200 mg/kg/day, respectively. At lower doses, no statistically or biologically significant effect on body weight was observed. Serum ALT levels were increased at ≥50 mg/kg/day (61–216% compared to controls), and alkaline phosphatase and AST were increased at 200 mg/kg/day (92 and 95%, respectively). Increased absolute and relative liver weights were noted in the groups exposed to ≥25 mg/kg/day; the differences from controls were at least 27 and 18% for absolute and relative weights, respectively. Centrilobular vacuolation was seen in all groups including controls (4/12), but incidence and severity increased with dose such that all animals were affected at doses ≥25 mg/kg/day. Hypertrophy was not seen in controls, but the incidence increased with dose from 4/10 at 10 mg/kg/day to all animals (9/9 or 10/10) at doses of at least 50 mg/kg/day. Necrosis was observed at doses of ≥50 mg/kg/day, from 3/9 at 50 mg/kg/day to 10/10 at 200 mg/kg/day. Incidences of other histopathology lesions were not reported in tables. All high-dose (200 mg/kg/day) rats exhibited bile duct hyperplasia, as did 20% of rats in the 100 and 25 mg/kg/day groups. Finally, centrilobular and/or periportal fibrosis was observed at 10% incidence in groups exposed to 25 and 100 mg/kg/day and at 40–60% incidence in the 200 mg/kg/day group. The LOAEL for hepatic effects was 10 mg/kg/day; a NOAEL was not identified. Table A-25 presents summary data for hepatic effects among rats exposed to 2,3,4,6-TeCP for 13 weeks (Dodd et al. 2012).

Table A-25 Liver Weight and Histopathology Changes in Rats Exposed to 2,3,4,6-Tetrachlorophenol by Gavage for 13 Weeks

Test | Dose (mg/kg/day)
Test | 0 | 10 | 25 | 50 | 100 | 200
Absolute liver weight (g) | 16.8±2.9 | 21.4±2.7 | 24.2±3.3^b^ | 27.5±5.5^c^ | 33.6±7.3^c^ | 38.9±7.2^c^
Relative liver weight (%) | 3.10±0.20 | 3.65±0.13 | 4.36±0.42^c^ | 5.46±0.62^c^ | 7.11±0.86^c^ | 9.40±1.11^c^
Vacuolation, centrilobular | 4/12 (1.0)^d^ | 9/10 (1.6) | 9/9^e^ (2.4) | 9/9^e^ (3.4) | 10/10^b^ (4.3) | 10/10^b^ (4.7)
Hypertrophy, centrilobular | 0/12 | 4/10 (1.0) | 8/9^c^ (1.3) | 9/9^c^ (2.6) | 0/10 | 0/10
Hypertrophy, diffuse | 0/12 | 0/10 | 0/10 | 0/10 | 10/10^c^ (3.0) | 10/10^c^ (4.2)
Necrosis, centrilobular | 0/12 | 0/10 | 0/10 | 3/9 (1.0) | 2/10 (1.5) | 0/10
Necrosis, midzonal | 0/12 | 0/10 | 0/10 | 0/10 | 1/10 (1.0) | 10/10^c^ (2.3)

a Mean±standard deviation.

b p<0.01 compared to control.

c p<0.001 compared to control.

d Incidence (average severity score). Severity scores were 1:minimal, 2: slight/mild, 3:moderate, 4: moderately severe, and 5: severe/high.

e p<0.05 compared to control based on Fisher’s exact test with Bonferroni correction performed by study authors.

Source: Dodd et al. 2012

Selection of the Point of Departure for the MRL: The BMDL_10_ of 1.02 mg/kg/day for centrilobular or diffuse hepatocellular hypertrophy was selected as basis for deriving an intermediate-duration oral MRL for 2,3,4,6-TeCP.

The absolute liver weight and selected histopathology data (vacuolation and hypertrophy) were fit to all available continuous or dichotomous models (respectively) in EPA’s BMDS (version 3.1.1). Relative liver weights were not modeled, as these values were influenced by significantly decreased body weights (12 and 22% at doses of 100 and 200 mg/kg/day). Necrosis incidences were not modeled because this effect occurred at higher doses than vacuolation and hypertrophy. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL was selected as the POD when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest AIC was chosen. For the liver weight data, a BMR of 1 standard deviation from the control mean in the absence of information to suggest an alternative BMR. For the histopathology incidence data, a BMR of 10% extra risk was used.

No model fit was achieved with the data on centrilobular vacuolation, even when up to three dose groups were dropped from the analysis. The model predictions for absolute liver weight and hepatic hypertrophy are shown in Tables A-26 and A-27 (respectively), and the fit of the selected models is shown in Figures A-8 and A-9 (respectively).

Table A-26 Results from BMD Analysis of Absolute Liver Weights in Male Rats Exposed to 2,3,4,6-Tetrachlorophenol for 13 Weeks (Dodd et al. 2012)

Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Scaled residuals^d^ | | | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Model | Test for significant difference p-value^a^ | Test for variance p-value^b^ | Test for means p-value^c^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Constant variance
Linear | <0.0001 | 0.001 | 0.01 | 1.15 | 1.74 | −2.19 | 379.13 | 52.14 | 42.73
Nonconstant variance
Exponential (model 2)^e^ | <0.0001 | 0.56 | <0.0001 | 1.27 | 1.73 | −3.02 | 379.01 | 45.49 | 32.10
Exponential (model 3)^e^ | <0.0001 | 0.56 | <0.0001 | 1.28 | 1.74 | −3.02 | 379.01 | 45.21 | 32.10
Exponential (model 4)^e^ | <0.0001 | 0.56 | 0.67 | −0.67 | 1.17 | 1.17 | 355.31 | 8.62 | 5.44
Exponential (model 5)^e^ | <0.0001 | 0.56 | 0.67 | −0.68 | 1.17 | 1.17 | 355.31 | 8.59 | 5.44
Hill^e,f^ | <0.0001 | 0.56 | 0.80 | −0.48 | 0.97 | 0.97 | 354.80 | 7.43 | 4.47
Polynomial (2-degree)^e^ | <0.0001 | 0.56 | 0.002 | 1.43 | 1.27 | −2.37 | 369.05 | 25.78 | 17.47
Polynomial (3-degree)^e^ | <0.0001 | 0.56 | 0.002 | 1.43 | 1.27 | −2.37 | 369.05 | 25.78 | 17.47
Polynomial (4-degree)^e^ | <0.0001 | 0.56 | 0.002 | 1.43 | 1.27 | −2.37 | 369.05 | 25.78 | 17.47
Polynomial (5 degree)^e^ | <0.0001 | 0.56 | 0.002 | 1.43 | 1.27 | −2.37 | 369.05 | 25.78 | 17.47
Power^e^ | <0.0001 | 0.56 | 0.002 | 1.43 | 1.26 | −2.37 | 369.05 | 25.78 | 17.47
Linear | <0.0001 | 0.56 | 0.002 | 1.43 | 1.26 | −2.37 | 369.05 | 25.78 | 17.47

a Values >0.05 fail to meet conventional goodness-of-fit criteria.

b Values <0.1 fail to meet conventional goodness-of-fit criteria.

c Values <0.1 fail to meet conventional goodness-of-fit criteria.

d Scaled residuals at doses immediately below and above the benchmark dose; also the largest residual at any dose.

e Restricted model.

f Recommended model. There was not an adequate fit to the variance when assuming constant variance. With the nonconstant variance model applied, an adequate fit to the variance was achieved. The Exponential 4, Exponential 5, and Hill models provided adequate fit to the means. Of the adequately fit models, the BMDLs were sufficiently close (differed by < 3-fold); therefore, the model with the lowest AIC was selected (Hill).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control)

Figure A-8 Fit of Hill Model to Absolute Liver Weight Data in Male Rats Exposed to 2,3,4,6-Tetrachlorophenol for 13 Weeks

Figure A-8 description

Table A-27 Model Predictions for Hypertrophy (Centrilobular and Diffuse) in Male Rats Exposed to 2,3,4,6-Tetrachlorophenol for 13 Weeks (Dodd et al. 2012)

Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Model | DF | χ^2^ | χ^2^ Goodness-of-fit p-value^a^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day)
Gamma^c^ | 4 | 0.03 | 0.99989 | −0.0004 | 0.03 | 0.15 | 23.79 | 4.49 | 1.02
LogLogistic^d^ | 4 | 0.19 | 0.99579 | −0.0004 | 0.07 | 0.32 | 24.04 | 5.64 | 1.95
Multistage (5-degree)^e^ | 1 | 2.89×10^−7^ | 0.99957 | −0.0004 | −0.0001 | −0.0004 | 29.74 | 2.42 | 1.02
Multistage (4-degree)^e^ | 4 | 3.00×10^−7^ | 1.00000 | −0.0004 | 1.3×10^−6^ | −0.0004 | 23.74 | 2.17 | 1.02
Multistage (3-degree)^e^ | 3 | 0.0002 | 1.00000 | −0.0004 | 0.0007 | 0.01 | 25.74 | 2.37 | 1.02
Multistage (2-degree) ^e^ ^,^ ^f^ | 3 | 0.005 | 0.99990 | −0.0005 | 0.01 | 0.07 | 25.75 | 3.15 | 1.02
Multistage (1-degree)^e^ | 5 | 0.99 | 0.96345 | −0.0004 | −0.79 | −0.79 | 22.97 | 1.42 | 0.91
Weibull^c^ | 3 | 0.01 | 0.99967 | −0.006 | 0.02 | 0.09 | 25.76 | 3.82 | 1.02
Dichotomous Hill | 4 | 0.19 | 0.99579 | −0.0004 | 0.07 | 0.32 | 24.04 | 5.64 | 1.95
Logistic | 4 | 1.18 | 0.88197 | −0.75 | 0.62 | −0.75 | 25.41 | 5.52 | 3.18
LogProbit^d^ | 4 | 0.09 | 0.99911 | −0.0004 | 0.05 | 0.23 | 23.88 | 5.58 | 1.75
Probit | 5 | 1.70 | 0.88940 | −1.10 | 0.44 | −1.10 | 24.57 | 4.71 | 3.00

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Selected model. All models provided an adequate fit to the dataset based on the χ2 goodness-of-fit p value; the 1-degree multistage model was considered questionable because the BMDL was 10 times lower than the lowest non-zero dose. BMDLs for the viable models were not sufficiently close (differed by >3-fold). Therefore, the model with the lowest BMDL was selected. The polynomial multistage 2-,3-, 4-, and 5-degree models all provided the same BMDL; the 2-degree model was the most parsimonious and was selected.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with 10% extra risk); DF = degrees of freedom; ND = not determined, goodness-of-fit criteria, p<0.10

Figure A-9 Fit of Multistage (2-Degree) Model to Data on Hepatocellular Hypertrophy (Centrilobular and Diffuse) in Male Rats Exposed to 2,3,4,6-Tetrachlorophenol for 13 Weeks

Figure A-9 description

A comparison of the BMDs and BMDLs for the selected models is shown in Table A-28. The lowest BMDL for the remaining two datasets was the BMDL_10_ of 1.02 mg/kg/day for centrilobular or diffuse hypertrophy; this value was selected as the POD.

Table A-28 Benchmark Dose Modeling Results for Hepatic Endpoints in 13-Week Rat Study by Dodd et al. (2012)

Endpoint^a^ | Selected model | BMD (mg/kg/day) | BMDL (mg/kg/day)
Absolute liver weight (g) | Hill | 7.43 | 4.47
Hypertrophy (centrilobular or diffuse): | Multistage (3 degree) | 3.15 | 1.02

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The BMDL_10_ of 1.02 mg/kg/day was divided by a total uncertainty factor (UF) of 100:

- 10 UF for extrapolation from animals to humans
- 10 UF for human variability

- MRL = BMDL_10_ ÷ (UF)
- 1.02 mg/kg/day ÷ (10 × 10) = 0.0102 mg/kg/day ≈ 0.01 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The liver is a well-established target of chlorophenol toxicity in laboratory animals. Hepatic effects including clinical chemistry changes, increased liver weight, hepatocellular hypertrophy, and necrosis have been observed in rats or mice after oral exposure to 2-CP, 4-CP, 2,4-DCP, 2,4,5-TCP, and 2,4,6-TCP (Aydin et al. 2009; Bercz et al. 1990; BSRC 2011; Exon and Koller 1985; Exon et al. 1984; Hasegawa et al. 2005; Kobayashi et al. 1972; McCollister et al. 1961; NCI 1979; NTP 1989).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,4,6-Tetrachlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,6-Tetrachlorophenol
CAS Numbers: | 58-90-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 2,3,4,6-TeCP due to the lack of chronic studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. No chronic-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,5,6-Tetrachlorophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,5,6-Tetrachlorophenol
CAS Numbers: | 935-95-5
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 2,3,5,6-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,5,6-Tetrachlorophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,5,6-Tetrachlorophenol
CAS Numbers: | 935-95-5
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 2,3,5,6-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,5,6-Tetrachlorophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,5,6-Tetrachlorophenol
CAS Numbers: | 935-95-5
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for 2,3,5,6-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,5,6-Tetrachlorophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,5,6-Tetrachlorophenol
CAS Numbers: | 935-95-5
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 2,3,5,6-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. The only information on the health effects of 2,3,5,6-TeCP following oral exposure in animals was acute lethality data following a single exposure (Ahlborg and Larsson 1978).

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,5,6-Tetrachlorophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,5,6-Tetrachlorophenol
CAS Numbers: | 935-95-5
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for 2,3,5,6-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams

## 2,3,5,6-Tetrachlorophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,5,6-Tetrachlorophenol
CAS Numbers: | 935-95-5
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 2,3,5,6-TeCP because there are no relevant studies.

Rationale for Not Deriving an MRL: No adequate exposure-response data were available for humans. No chronic-duration oral data were located for experimental animals.

Agency Contacts (Chemical Managers): Malcolm Williams