# CHAPTER 8 REFERENCES

ACGIH. 2012. TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Andrews AW, Zawistowski ES, Valentine CR. 1976. A comparison of the mutagenic properties of vinyl chloride and methyl chloride. Mutat Res 40(3):273–276. 10.1016/01651218(76)90054-9.785251
Asakura M, Sasaki T, Sugiyama T, . 2008. An improved system for exposure of cultured mammalian cells to gaseous compounds in the chromosomal aberration assay. Mutat Res 652(2):122–130. 10.1016/j.mrgentox.2008.01.004.18342567
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634. https://www.govinfo.gov/content/pkg/FR-1989-09-11/pdf/FR-1989-09-11.pdf. September 14, 2022.
ATSDR. 2022. Chloromethane. SPL data. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources. June 15, 2023.
Baird TT. 1954. Methyl chloride poisoning. Br Med J 2(4900):1353. 10.1136/bmj.2.4900.1353.13209119
Baker HM. 1927. Intoxication with commercial methyl chloride: Report of a series of cases. JAMA 88(15):1137–1138. 10.1001/jama.1927.02680410013005.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barry KH, Zhang Y, Lan Q, . 2011. Genetic variation in metabolic genes, occupational solvent exposure, and risk of non-Hodgkin lymphoma. Am J Epidemiol 173(4):404–413. 10.1093/2Faje/2Fkwq360.21228414
Battigelli MC, Perini A. 1955. [Two cases of acute poisoning with methyl chloride]. Med Lav 46(11):646–652. (Italian)13308646
Beckett EM, Miller E, Unice K, . 2022. Evaluation of volatile organic compound (VOC) emissions from memory foam mattresses and potential implications for consumer health risk. Chemosphere 303(Pt 1):134945. 10.1016/j.chemosphere.2022.134945.35588879
Borovska D, Jindrichova J, Klima M. 1976. [Methyl chloride poisoning in the country of East Bohemia]. Z Gesamte Hyg 22:241–245. (German)969737
Bradley PM, Journey CA, Romanok KM, . 2017a. Expanded target-chemical analysis reveals extensive mixed-organic-contaminant exposure in U.S. streams. Environ Sci Technol 51(9):4792–4802. 10.1021/acs.est.7b00012.28401767
Bradley PM, Journey CA, Romanok KM, . 2017b. Supplemental material: Expanded targetchemical analysis reveals extensive mixed-organic-contaminant exposure in U.S. streams. Environ Sci Technol 51(9) 10.1021/acs.est.7b00012.
Bradley PM, Kolpin DW, Romanok KM, . 2018. Reconnaissance of mixed organic and inorganic chemicals in private and public supply tapwaters at selected residential and workplace sites in the United States. Environ Sci Technol 52(23):13972–13985. 10.1021/acs.est.8b04622.30460851
Bringel F, Besaury L, Amato P, . 2019. Methylotrophs and methylotroph populations for chloromethane degradation. Curr Issues Mol Biol 33:149–172. 10.21775/cimb.033.149.31166190
Brown KW, Donnelly KC. 1988. An estimation of the risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Haz Waste Haz Mater 5(1):1–30. 10.1089/hwm.1988.5.1.
Burek JD, Potts WJ, Gushow TS, . 1981. Initial submission: Methyl chloride: 48 and 72 hour continuous inhalation exposure in rats followed by up to 12 days of recovery (final report) with letter dated 102591 (sanitized). Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0534632. 889200001828. 8EHQ109115369. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0534632.xhtml. September 14, 2022.
Chaignaud P, Morawe M, Besaury L, . 2018. Methanol consumption drives the bacterial chloromethane sink in a forest soil. ISME J 12(11):2681–2693. 10.1038/s41396-018-0228-4.29991765
Chapin RE, White RD, Morgan KT, . 1984. Studies of lesions induced in the testis and epididymis of F-344 rats by inhaled methyl chloride. Toxicol Appl Pharmacol 76(2):328–343. 10.1016/0041-008x(84)90014-0.6388032
Chellman GJ, Morgan KT, Bus JS, . 1986a. Inhibition of methyl chloride toxicity in male F-344 rats by the anti-inflammatory agent BW755C. Toxicol Appl Pharmacol 85(3):367–379. 10.1016/0041-008x(86)90344-3.3094195
Chellman GJ, White RD, Norton RM, . 1986b. Inhibition of the acute toxicity of methyl chloride in male B6C3F1 mice by glutathione depletion. Toxicol Appl Pharmacol 86(1):93–104. 10.1016/0041-008x(86)90402-3.3764938
Chellman GJ, Bus JS, Working PK. 1986c. Role of epididymal inflammation in the induction of dominant lethal mutations in Fischer 344 rat sperm by methyl chloride. Proc Natl Acad Sci U S A 83(21):8087–8091. 10.1073/pnas.83.21.8087.3095827
Chellman GJ, Hurtt ME, Bus JS, . 1987. Role of testicular versus epididymal toxicity in the induction of cytotoxic damage in Fischer-344 rat sperm by methyl chloride. Reprod Toxicol 1(1):25–35. 10.1016/0890-6238(87)90068-2.2980361
Chen G, Kleindienst S, Griffiths DR, . 2017. Mutualistic interaction between dichloromethane- and chloromethane-degrading bacteria in an anaerobic mixed culture. Environ Microbiol 19(11):4784–4796. 10.1111/1462-2920.13945.28967177
CIIT. 1981. Final report on a chronic inhalation toxicology study in rats and mice exposed to methyl chloride. Battelle-Columbus Laboratories. Submitted to the U.S. Environmental Protection Agency under section 4. 40-8120717. OTS0511310.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/2F074823378500100408.3843496
Cox ML, Fraser PJ, Sturrock GA, . 2004. Terrestrial sources and sinks of halomethanes near Cape Grim, Tasmania. Atmos Environ 38(23):3839–3852. 10.1016/j.atmosenv.2004.03.050.
Crutzen PJ, Gidel LT. 1983. A two-dimensional photochemical model of the atmosphere. 2: The tropospheric budgets of the anthropogenic chlorocarbons, carbon monoxide, methane, chloromethane and the effect of various nitrogen oxides sources on the tropospheric ozone. J Geophys Res 88(C11):6641–6661. 10.1029/JC088iC11p06641.
Dekant W, Frischmann C, Speerschneider P. 1995. Sex, organ and species specific bioactivation of chloromethane by cytochrome P4502E1. Xenobiotica 25(11):1259–1265. 10.3109/00498259509046681.8592874
DeKok AC, Anthenius WS. 1981. S-Methylcysteine no human metabolite of methylchloride. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8. OTS0215176. 878221209.
Delfino RJ, Gong H, Linn WS, . 2003. Asthma symptoms in Hispanic children and daily ambient exposures to toxic and criteria air pollutants. Environ Health Perspect 111(4):647–656. 10.1289/ehp.5992.12676630
Derendorp L, Wishkerman A, Keppler F, . 2012. Methyl chloride emissions from halophyte leaf litter: dependence on temperature and chloride content Chemosphere 87(5):483–489. 10.1016/j.chemosphere.2011.12.035.22225707
DHHS. 1995. Report to Congress on workers’ home contamination study conducted under the Workers’ Family Protection Act (29 U.S.C. 671a). Cincinnati, OH: U.S. Department of Health and Human Services. DHHS(NIOSH) Publication No. 95–123. https://www.cdc.gov/niosh/docs/95123/default.html. September 14, 2022.
Dilling WL. 1982. Atmospheric environment. In: Conway RA, ed. Environmental risk analysis for chemicals. New York, NY: Van Nostrand Reinhold Co., 154–197.
Dodd DE, Bus JS, Barrow CS. 1982. Nonprotein sulfhydryl alterations in F-344 rats following acute methyl chloride inhalation. Toxicol Appl Pharmacol 62(2):228–236. 10.1016/0041-008x(82)90121-1.7058527
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 6, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
Doronina NV, Sokolov AP, Trotsenko YA. 1996. Isolation and initial characterization of aerobic chloromethane-utilizing bacteria. FEMS Microbiol Lett 142(2–3):179–183. 10.1111/j.1574-6968.1996.tb08427.x.
Dosemeci M, Cocco P, Chow WH. 1999. Gender differences in risk of renal cell carcinoma and occupational exposures to chlorinated aliphatic hydrocarbons. Am J Ind Med 36(1):54–59. 10.1002/(sici)1097-0274(199907)36:1%3C54::aid-ajim8%3E3.0.co;2-0.10361587
Draper WM, Li N, Solomon GM, . 2022. Organic chemical contaminants in water system infrastructure following wildfire. ACS ES T Water 2(2):357–366. 10.1021/acsestwater.1c00401.35647583
Dunn RC, Smith WW. 1947. Acute and chronic toxicity of methyl chloride. IV. Histopathologic observations. Arch Pathol 43(3):296–300.
DuPont. 1977. Mutagenic activity of methane, chloro- in the Salmonella/microsome assay with cover letter. E.I. Du Pont de Nemours and Co., Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8DS. OTS0215036. 878220403. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0215036.xhtml. September 14, 2022.
ECHA. 2022. Registration dossier: Chloromethane; methyl chloride. European Chemicals Agency. https://echa.europa.eu/de/registration-dossier/-/registered-dossier/15768. September 16, 2022.
Edwards PR, Campbell I, Milne GS. 1982a. The impact of chloromethanes on the environment. Part 1. The atmospheric chlorine cycle. Chem Ind 16:574–578.
Elliot S, Rowland FS. 1995. Methyl halide hydrolysis rates in natural waters. J Atmos Chem 20(3):229–236. 10.1007/BF00694495.
EPA. 1975. Identification of organic compounds in effluents from industrial sources. Washington, DC: Environmental Protection Agency. EPA560375002. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000YZQK.txt. September 14, 2022.
EPA. 1980. Organic chemical manufacturing. Vol. 6: Selected processes. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA450380028a. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101OOB1.txt. September 14, 2022.
EPA. 1986. Method 8021B: Aromatic and halogenated volatiles by gas chromatography using photoionization and/or electrolytic conductivity detectors. U.S. Environmental Protection Agency.
EPA. 1995. Reportable quantity adjustments. U.S. Environmental Protection Agency. Fed Regist 60(112):30926–30962. https://www.govinfo.gov/content/pkg/FR-1995-06-12/html/X95-10612.htm. September 14, 2022.
EPA. 2001. Toxicological review of methyl chloride. Washington, DC: U.S. Environmental Protection Agency. EPA635R01003. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1003tr.pdf. August 2, 2019.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100EI4V.txt. September 14, 2022.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F09004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. August 2, 2019.
EPA. 2011. Background indoor air concentrations of volatile organic compounds in North American residences (1990–2005): A compilation of statistics for assessing vapor intrusion. Washington, DC: U.S. Environmental Protection Agency. EPA530R10001. https://www.epa.gov/sites/production/files/2015-09/documents/oswer-vapor-intrusion-background-report-062411.pdf. August 2, 2019.
EPA. 2012a. EPI Suite™ - Estimation Programs Interface v4.11. U.S. Environmental Protection Agency. https://www.epa.gov/tsca-screening-tools/download-epi-suitetm-estimation-programinterface-v411. September 15, 2022.
EPA. 2012b. Provisional peer-reviewed toxicity values for chloromethane (CASRN 74-87-3). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R12008F. https://cfpub.epa.gov/ncea/pprtv/documents/Chloromethane.pdf. August 2, 2019.
EPA. 2016. The third unregulated contaminant monitoring rule (UCMR 3): Fact sheet for assessment monitoring (List 1 contaminants). U.S. Environmental Protection Agency. EPA815F16003. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100OFUT.txt. September 14, 2022.
EPA. 2017a. Section 7412. Hazardous air pollutants. U.S. Environmental Protection Agency. United States Code. 42 U.S.C. § 7412. https://www.govinfo.gov/content/pkg/USCODE-2016title42/pdf/USCODE-2016-title42-chap85-subchapI-partA-sec7412.pdf. September 14, 2022.
EPA. 2017b. The third unregulated contaminant monitoring rule (UCMR 3): Data summary, January 2017. Environmental Protection Agency. EPA815S17001. https://www.epa.gov/sites/production/files/2017-02/documents/ucmr3-data-summary-january-2017.pdf. August 2, 2019.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/202201/dwtable2018.pdf. September 14, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018c. About acute exposure guideline levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2019. The ozone-depleting substances phaseout: 2020-2030. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2019-12/documents/fact_sheet_0.pdf. August 2, 2019.
EPA. 2022a. Chemical data reporting. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data. September 15, 2022.
EPA. 2022b. 2017 National Emissions Inventory (NEI) data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. September 14, 2022.
EPA. 2022c. AQS data. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/airdata/download_files.html. September 14, 2022.
Fabian P. 1986. Halogenated hydrocarbons in the atmosphere. In: Hutzinger O, ed. The handbook of environmental chemistry. Vol. 4. Berlin, Germany: Springer-Verlag, 23–51.
Farhan Ul Haque M, Besaury L, Nadalig T, . 2017. Correlated production and consumption of chloromethane in the Arabidopsis thaliana phyllosphere. Scientific Reports 7(1):17589. 10.1038/s41598-017-17421-y.29242530
FDA. 2019. Substances added to food (formerly EAFUS). Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances&sort=Sortterm&order=ASC&startrow=1&type=basic&search=74-87-3. May 8, 2019.
FDA. 2022. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. January 24, 2022.
Filipiak W, Ruzsanyi V, Mochalski P, . 2012. Dependence of exhaled breath composition on exogenous factors, smoking habits and exposure to air pollutants. J Breath Res 6(3):036008. 10.1088/1752-7155/6/3/036008.22932429
Fostel J, Allen PF, Bermudez E, . 1985. Assessment of the genotoxic effects of methyl chloride in human lymphoblasts. Mutat Res 155(1–2):75–81. 10.1016/0165-1218(85)90028-x.3881666
Fridovich I. 1978. The biology of oxygen radicals. Science 201(4359):875–880. 10.1126/science.210504.210504
Gaskin S, Thredgold L, Heath L, . 2018. Empirical data in support of a skin notation for methyl chloride. J Occup Environ Hyg 15(8):569–572. 10.1080/15459624.2018.1470636.29708856
Gidel LT, Crutzoen PJ, Fishman J. 1983. A two-dimensional photochemical model of the atmosphere. 1: Chlorocarbon emissions and their effect on stratospheric ozone. J Geophys Res 88(C11):6622–6640. 10.1029/JC088iC11p06622.
Goldstein BD, Witz G, Amoruso M, . 1979. Protease inhibitors antagonize the activation of polymorphonuclear leukocyte oxygen consumption. Biochem Biophys Res Commun 88(3):854–860. 10.1016/0006-291X(79)91487-6.465084
Goldstein BD, Witz G, Amoruso M, . 1981. Stimulation of human polymorphonuclear leukocyte superoxide anion radical production by tumor promoters. Cancer Lett 11(3):257–262. 10.1016/0304-3835(81)90117-8.6265062
Granstrom ML, Ahlert RC, Wiesenfeld J. 1984. The relationships between the pollutants in the sediments and in the water of the Delaware and Raritan Canal. Water Sci Technol 16(5–7):375–380. 10.2166/wst.1984.0144.
Great Lakes Water Quality Board. 1983. Status report on the development of an inventory of chemical substances identified in the Great Lakes ecosystem. Appendix E: Draft. November 9, 1983. Great Lakes Water Quality Board Implementation Committee. https://scholar.uwindsor.ca/cgi/viewcontent.cgi?article=1316&context=ijcarchive. September 14, 2022.
Greenberg M, Anderson R, Keene J, . 1982. Empirical test of the association between gross contamination of wells with toxic substances and surrounding land use. Environ Sci Technol 16(1):14–19. 10.1021/es00095a007.
Gudmundsson G. 1977. Methyl chloride poisoning 13 years later. Arch Environ Health 32(5):236–237. 10.1080/00039896.1977.10667287.911203
Guengerich FP, Shimada T. 1991. Oxidation of toxic and carcinogenic chemicals by human cytochrome P-450 enzymes. Chem Res Toxicol 4(4):391–407. 10.1021/tx00022a001.1912325
Hallier E, Deutschmann S, Reichel C, . 1990. A comparative investigation of the metabolism of methyl bromide and methyl iodide in human erythrocytes. Int Arch Occup Environ Health 62(3):221–225. 10.1007/bf00379437.2347645
Hamm TE, Raynor TH, Phelps MC, . 1985. Reproduction in Fischer-344 rats exposed to methyl chloride by inhalation for two generations. Fundam Appl Toxicol 5(3):568–577. 10.1016/0272-0590(85)90104-6.4007311
Hansen H, Weaver NK, Venable FS. 1953. Methyl chloride intoxication; report of fifteen cases. AMA Arch Ind Hyg Occup Med 8(4):328–334.13091432
Harper DB. 1985. Halomethane from halide ion - a highly efficient fungal conversion of environmental significance. Nature 315(6014):55–57. 10.1038/315055a0.
Harper DB, Hamilton JTG. 1988. Biosynthesis of chloromethane in Phellinus pomaceus. J Gen Microbiol 134(10):2831–2839. 10.1099/00221287-134-10-2831.
Harper DB, Kennedy JT, Hamilton JTG. 1988. Chloromethane biosynthesis in poroid fungi. Phytochemistry 27(10):3147–3153. 10.1016/0031-9422(88)80017-7.
Harper DB, Buswell JA, Kennedy JT, . 1990. Chloromethane, methyl donor in veratryl alcohol biosynthesis in Phanerochaete chrysosporium and other lignin-degrading fungi. Appl Environ Microbiol 56(11):3450–3457. 10.1128/aem.56.11.3450-3457.1990.16348350
Hartman TL, Wacker W, Roll RM. 1955. Methyl chloride intoxication - report of two cases, one complicating pregnancy. N Engl J Med 253(13):552–554. 10.1056/nejm195509292531304.13253876
Hartmans S, Schmuckle A, Cook AM, . 1986. Methyl chloride: Naturally occurring toxicant and C-1 growth substrate. J Gen Microbiol 132(4):1139–1142. 10.1099/00221287-132-4-1139.
Häsänen E, Soininen V, Pyysalo H, . 1979. On the occurrence of aliphatic chlorine and bromine compounds in automobile exhaust. Atmos Environ 13(8):1217–1219. 10.1016/0004-6981(79)90049-0.
Hatch GG, Mamay PD, Ayer ML, . 1982. Methods for detecting gaseous and volatile carcinogens using cell transformation assays. In: Tice RR, Costa DL, Schaich KM, eds. Genotoxic effects of airborne agents. Vol. 25. Boston MA: Springer, 75–90.
Hatch GG, Mamay PD, Ayer ML, . 1983. Chemical enhancement of viral transformation in Syrian hamster embryo cells by gaseous and volatile chlorinated methanes and ethanes. Cancer Res 43(5):1945–1950.6299533
Heck HD, White EL, Casanova-Schmitz M. 1982. Determination of formaldehyde in biological tissues by gas chromatography/mass spectrometry. Biomed Mass Spectrom 9(8):347–353. 10.1002/bms.1200090808.7126766
Heppolette RL, Robertson RE, Steacie EWR. 1959. The neutral hydrolysis of the methyl halides. Proc R Soc Lond A Math Phys Sci 252(1269):273–285. 10.1098/rspa.1959.0152.
Holmes TM, Buffler PA, Holguin AH, . 1986. A mortality study of employees at a synthetic rubber manufacturing plant. Am J Ind Med 9(4):355–362. 10.1002/ajim.4700090407.3706309
Horst A, Bonifacie M, Bardoux G, . 2019. Isotopic characterization (2H, 13C, 37Cl, 81Br) of abiotic degradation of methyl bromide and methyl chloride in water and implications for future studies. Environ Sci Technol 53(15):8813–8822. 10.1021/acs.est.9b02165.31286766
Hsu CY, Chiang HC, Shie RH, . 2018. Ambient VOCs in residential areas near a large-scale petrochemical complex: Spatiotemporal variation, source apportionment and health risk. Environ Pollut 240:95–104. 10.1016/j.envpol.2018.04.076.29730422
IARC. 1999. Methyl chloride. IARC monographs on the evaluation of carcinogenic risks to humans. Volume 71. Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.who.int/wp-content/uploads/2018/06/mono71.pdf. September 10, 2022.
IARC. 2019. Agents classified by the IARC monographs, volumes 1-123. International Agency for Research on Cancer.
IPCC. 1995. Climate change 1995: The science of climate change. Cambridge: Intergovernmental Panel on Climate Change. https://www.ipcc.ch/site/assets/uploads/2018/02/ipcc_sar_wg_I_full_report.pdf. September 14, 2022.
Jaeger N, Besaury L, Röhling AN, . 2018. Chloromethane formation and degradation in the fern phyllosphere. Sci Total Environ 634:1278–1287. 10.1016/j.scitotenv.2018.03.316.29660879
Jager R, Peter H, Sterzel W, . 1988. Biochemical effects of methyl chloride in relation to its tumorigenicity. J Cancer Res Clin Oncol 114(1):64–70. 10.1007/bf00390487.3350844
Jiang XZ, White R, Morgan KT. 1985. An ultrastructural study of lesions induced in the cerebellum of mice by inhalation exposure to methyl chloride. Neurotoxicology 6(1):93–103.3873041
Johanson G, Jonsson F, Bois F. 1999. Development of new technique for risk assessment using physiologically based toxicokinetic models. Am J Ind Med Suppl 1:101–103. 10.1002/(sici)1097-0274(199909)36:1+%3C101::aid-ajim36%3E3.0.co;2-i.
John-Greene JA, Welsch F, Bus JS. 1985. Comments on heart malformations in B6C3F1 mouse fetuses induced by methyl chloride-continuing efforts to understand the etiology and interpretation of an unusual lesion. Teratology 32(3):483–487. 10.1002/tera.1420320317.4082076
Jones MA. 1942. Methyl chloride poisoning. Quart J Med 41:29–43.
Jonsson F, Bois FY, Johanson G. 2001. Assessing the reliability of PBPK models using data from methyl chloride-exposed, non-conjugating human subjects. Arch Toxicol 75(4):189–199. 10.1007/s002040100221.11482516
Jury WA, Winer AM, Spencer WF, . 1987. Transport and transformation of organic chemicals in the soil-air-water ecosystem. Rev Environ Contam Toxicol 99:119–164. 10.1007/978-1-4613-8719-0_5.
Kavouras IG, DuBois DW, Nikolich G, . 2015. Monitoring, source identification and health risks of air toxics in Albuquerque, New Mexico, U.S.A. Aerosol Air Qual Res 15(2):556–571. 10.4209/aaqr.2014.04.0075.
Kegel AH, McNally WD, Pope AS. 1929. Methyl chloride poisoning from domestic refrigerators. J Am Med Assoc 93(5):353–358. 10.1001/jama.1929.02710050007003.
Kempkes M, Wiebel FA, Golka K, . 1996. Comparative genotyping and phenotyping of glutathione S-transferase GSTT1. Arch Toxicol 70(5):306–309. 10.1007/s002040050278.8852702
Keppler F, Harper DB, Rockmann T, . 2005. New insight into the atmospheric chloromethane budget gained using stable carbon isotope ratios. Atmos Chem Phys 5(9):2403–2411. 10.5194/acp-5-2403-2005.
Keppler F, Fischer J, Sattler T, . 2017. Chloromethane emissions in human breath. Sci Total Environ 605–606:405–410. 10.1016/j.scitotenv.2017.06.202.28672229
Keppler F, Röhling AN, Jaeger N, . 2020. Sources and sinks of chloromethane in a salt marsh ecosystem: constraints from concentration and stable isotope measurements of laboratory incubation experiments. Environ Sci Process Impacts 22(3):627–641. 10.1039/c9em00540d.32080692
Kernan GJ, Ji B, Dosemeci M, . 1999. Occupational risk factors for pancreatic cancer: A case-control study based on death certificates from 24 U.S. states. Am J Ind Med 36(2):260–270. 10.1002/(sici)1097-0274(199908)36:2%3C260::aid-ajim5%3E3.0.co;2-p.10398934
Khalil MAK, Rasmussen RA. 1999. Atmospheric methyl chloride. Atmos Environ 33(8):1305–1321. 10.1016/S1352-2310(98)00234-9.
Khindaria A, Grover TA, Aust SD. 1995. Reductive dehalogenation of aliphatic halocarbons by lignin peroxidase of Phanerochaete chrysosporium. Environ Sci Technol 29(3):719–725. 10.1021/es00003a020.22200281
Kopfler FC, Melton RG, Mullaney JL, . 1977. Human exposure to water pollutants. Adv Environ Sci Technol 8:419–433.
Kornbrust DJ, Bus JS. 1983. The role of glutathione and cytochrome P-450 in the metabolism of methyl chloride. Toxicol Appl Pharmacol 67(2):1983. 10.1016/0041-008x(83)90231-4.
Kornbrust DJ, Bus JS. 1984. Glutathione depletion by methyl chloride and association with lipid peroxidation in mice and rats. Toxicol Appl Pharmacol 72(3):388–399. 10.1016/0041008x(84)90115-7.6710490
Kornbrust DJ, Bus JS, Doerjer G, . 1982. Association of inhaled [14C]methyl chloride with macromolecules from various rat tissues. Toxicol Appl Pharmacol 65(1):122–134. 10.1016/0041-008x(82)90370-2.6183790
Kosson DS, Dienemann EA, Ahlert RC. 1985. Characterization and treatability studies of an industrial landfill leachate (KIN-BUC I). Proc Ind Waste Conf 39:329–341.
Krishnan K, Clewell HJ, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling of chemical mixtures. In: Yang RSA, ed. Toxicology of chemical mixtures. New York, NY: Academic Press, 399–437.
Kröber E, Wende S, Kanukollu S, . 2021. 13C-chloromethane incubations provide evidence for novel bacterial chloromethane degraders in a living tree fern. Environ Microbiol 23(8):4450–4465. 10.1111/1462-2920.15638.34121306
Kröber E, Kanukollu S, Wende S, . 2022. A putatively new family of alphaproteobacterial chloromethane degraders from a deciduous forest soil revealed by stable isotope probing and metagenomics. Environ Microbiome 17(1):24. 10.1186/s40793-022-00416-2.35527282
Krotoszynski BK, O’Neill HJ. 1982. Involuntary bioaccumulation of environmental pollutants in nonsmoking heterogeneous human population. J Environ Sci Health A Tox Hazard Subst Environ Eng 17(6):855–883. 10.1080/10934528209375082.
Landry TD, Ramsey JC, McKenna MJ. 1983b. Pulmonary physiology and inhalation dosimetry in rats: development of a method and two examples. Toxicol Appl Pharmacol 71(1):72–83. 10.1016/0041-008x(83)90046-7.6636181
Landry TD, Gushow TS, Langvardt PW, . 1983a. Pharmacokinetics and metabolism of inhaled methyl chloride in the rat and dog. Toxicol Appl Pharmacol 68(3):473–486. 10.1016/0041-008X(83)90292-2.6857680
Landry TD, Quast JF, Gushow TS, . 1985. Neurotoxicity of methyl chloride in continuously versus intermittently exposed female C57BL/6 mice. Fundam Appl Toxicol 5(1):87–98. 10.1016/0272-0590(85)90052-1.3987995
Lanham JM. 1982. Methyl chloride: an unusual incident of intoxication. Can Med Assoc J 126(6):593.
Laughton PM, Robertson RE. 1956. Solvolysis in deuterium and hydrogen oxide. Can J Chem 34(12):1714–1718. 10.1139/v56-223.
Lestari F, Hayes AJ, Green AR, . 2011. An alternative method for in vitro fire smoke toxicity assessment of polymers and composites using human lung cells. Fire Mater 35(6):411–429. 10.1002/fam.1062.
Linge KL, Blair P, Busetti F, . 2012. Chemicals in reverse osmosis-treated wastewater: occurrence, health risk, and contribution to residual dissolved organic carbon. J Water Supply Res T 61(8):494–505. 10.2166/aqua.2012.047.
Liu R, Chen J, Li G, . 2017. Using an integrated decontamination technique to remove VOCs and attenuate health risks from an e-waste dismantling workshop. Chem Eng J 318:57–63. 10.1016/j.cej.2016.05.004.
Lof A, Johanson G, Rannug A, . 2000. Glutathione transferase T1 phenotype affects the toxicokinetics of inhaled methyl chloride in human volunteers. Pharmacogenetics 10(7):645–653. 10.1097/00008571-200010000-00007.11037805
Logue JM, Price PN, Sherman MH, . 2012. A method to estimate the chronic health impact of air pollutants in U.S. residences. Environ Health Perspect 120(2):216–222. 10.1289/ehp.1104035.22094717
Lurker PA, Clark CS, Elia VJ, . 1983. Worker exposure to chlorinated organic compounds from the activated-sludge wastewater treatment process. Am Ind Hyg Assoc J 44(2):109–112. 10.1080/15298668391404464.6837435
Ma JJ, Zhu Hl, Zhao SP, . 2008. Impact of artificial waterfall using reclaimed water to VOCs and its health risk assessment. J Harbin Inst Technol 15(3):331–340.
Mabey W, Mill T. 1978. Critical review of hydrolysis of organic compounds in water under environmental conditions. J Phys Chem Ref Data 7(2):383–415. 10.1063/1.555572.
MacDonald JD. 1964. Methyl chloride intoxication. Report of 8 cases. J Occup Med 6:81–84.14116289
Mackie IJ. 1961. Methyl chloride intoxication. Med J Aust 48(1):203–205. 10.5694/j.1326-5377.1961.tb82386.x.
Manca D, Birmingham B, Raha D. 1997. Toxicological screening of chemical emissions from municipal solid waste landfills. Application of a predictive framework to a state-of-the-art facility. Hum Ecol Risk Assess 3(2):257–286. 10.1080/10807039709383684.
McAnulla C, McDonald IR, Murrell JC. 2001. Methyl chloride utilising bacteria are ubiquitous in the natural environment. FEMS Microbiol Lett 201(2):151–155. 10.1111/j.1574-6968.2001.tb10749.x.11470354
McCulloch A, Aucott ML, Benkovitz CM, . 1999. Global emissions of hydrogen chloride and chloromethane from coal combustion, incineration and industrial activities: Reactive Chlorine Emissions Inventory. J Geophys Res 104(D7):8391–8403. 10.1029/1999JD900025.
McKenna MJ, Gushow TS, Bell TJ, . 1981a. Initial submission: Methyl chloride: A 72-hour continuous (abt 23-1/2 hr/day) inhalation toxicity study in dogs and cats (final report) w/attchmt & ltr dated 10/25/91 (sanitized). Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0534633. 88900001839. 8EHQ109115379. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0534633.xhtml. September 14, 2022.
McKenna MJ, Burek JD, Henck JW, . 1981b. Methyl chloride: A 90-day inhalation toxicity study in rats, mice and beagle dogs. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0511317. 408120723. 47002B3B17. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0511317.xhtml. September 14, 2022.
McNally WD. 1946. Eight cases of methyl chloride poisoning with three deaths. J Ind Hyg Toxicol 28:94–97.20982154
Minami M. 1998. Does industrial and environmental toxicology have relevance to forensic toxicology? J Toxicol Toxin Rev 17(1):39–55. 10.3109/15569549809006489.
Minami M, Katsumata M, Miyake K, . 1992. Dangerous mixture of household detergents in an old-style toilet: a case report with simulation experiments of the working environment and warning of potential hazard relevant to the general environment. Hum Exp Toxicol 11(1):27–34. 10.1177/096032719201100104.1354456
Minami M, Inagaki H, Katsumata M, . 1993. Inhibitory action of chloramine on formate-metabolizing system. Studies suggested by an unusual case record. Biochem Pharmacol 45(5):1059–1064. 10.1016/0006-2952(93)90250-z.8461035
Mitchell RI, Pavkov K, Everett RM, . 1979. A 90-day inhalation toxicology study in F-344 rats and B6C3F1 mice exposed to atmospheric methyl chloride gas. Columbus, OH: Battelle Columbus Laboratory.
Mohamed MF, Kang D, Aneja VP. 2002. Volatile organic compounds in some urban locations in United States. Chemosphere 47(8):863–882. 10.1016/s0045-6535(02)00107-8.12079081
Moore RM. 2008. A photochemical source of methyl chloride in saline waters. Environ Sci Technol 42(6):1933–1937. 10.1021/es071920l.18409616
Moore RM, Gut A, Andreae MO. 2005. A pilot study of methyl chloride emissions from tropical woodrot fungi. Chemosphere 58(2):221–225. 10.1016/j.chemosphere.2004.03.011.15571754
Morgan A, Black A, Belcher DR. 1970. The excretion in breath of some aliphatic halogenated hydrocarbons following administration by inhalation. Ann Occup Hyg 13(4):219–233. 10.1093/annhyg/13.4.219.5509094
Morgan KT, Swenberg JA, Hamm TE, . 1982. Histopathology of acute toxic response in rats and mice exposed to methyl chloride by inhalation. Fundam Appl Toxicol 2(6):293–299. 10.1016/S0272-0590(82)80008-0.7185629
NAS/NRC. 1989. Biological markers in reproductive toxicology. National Academies of Science. National Research Council.
NIOSH. 1976. Behavioral and neurological effects of methyl chloride. Behavioral and neurological evaluation of workers exposed to industrial solvents: Methyl chloride. Cincinnati, OH: National Institute for Occupational Safety and Health. PB274770. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB274770.xhtml. August 8, 2022.
NIOSH. 1991. National occupational exposure survey 1981-1983. National Institute of Occupational Safety and Health.
NIOSH. 1994. Methyl chloride: Method 1001, Issue 2. NIOSH Manual of Analytical Methods (NMAM). National Institute of Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/1001.pdf. August 2, 2019.
NIOSH. 2018. NIOSH Pocket guide to chemical hazards - Methyl chloride. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0403.html. August 2, 2019.
NIOSH. 2019. Methyl chloride. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0403.html. February 26, 2023.
Nolan RJ, Rick DL, Landry TD, . 1985. Pharmacokinetics of inhaled methyl chloride (CH3Cl) in male volunteers. Fundam Appl Toxicol 5(2):361–369. 10.1016/0272-0590(85)90084-3.3988005
Novak BJ, Meinardi S, Blake DR. 2008. Methyl chloride and the U.S. cigarette. Nicotine Tob Res 10(11):1621–1625. 10.1080/14622200802410014.18988074
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments- February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. August 2, 2019.
NTP. 2015. Handbook for conducting a literature-based health assessment using OHAT approach for systematic review and evidence integration. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/handbookjan2015_508.pdf. August 2, 2019.
NTP. 2016. Substances listed in the fourteenth report on carcinogens. National Toxicology Program. http://ntp.niehs.nih.gov/go/roc. August 2, 2019.
NTP. 2019. Chemical effects in biological systems (CEBS): CASRN: 74-87-3: Ames conclusions. National Toxicology Program. https://cebs.niehs.nih.gov/cebs/. September 14, 2022.
NTP. 2021. CASRN index. In: Report on carcinogens. 15th ed. National Toxicology Program, https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. January 10, 2022.
OSHA. 2018. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Standards. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/app/details/CFR-2018-title29-vol7/CFR-2018-title29-vol7-sec1915-1000. August 2, 2019.
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1000.pdf. August 28, 2022.
Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15(12):1475–1481. 10.1021/es00094a008.
Palmer TY. 1976. Combustion sources of atmospheric chlorine. Nature 263(5572):44–46. 10.1038/263044a0.
Pellizzari ED, Hartwell TD, Harris BS, . 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28(3):322–328. 10.1007/bf01608515.7082873
Perkins AN, Inayat-Hussain SH, Deziel NC, . 2019. Evaluation of potential carcinogenicity of organic chemicals in synthetic turf crumb rubber. Environ Res 169:163–172. 10.1016/j.envres.2018.10.018.30458352
Peter H, Deutschmann S, Reichel C, . 1989a. Metabolism of methyl chloride by human erythrocytes. Arch Toxicol 63(5):351–355. 10.1007/bf00303122.2818198
Peter H, Deutschmann S, Muelle A, . 1989b. Different affinity of erythrocyte glutathione-S-transferase to methyl chloride in humans. Arch Toxicol Suppl 13:128–132. 10.1007/978-3-642-74117-3_17.2774921
Philbrick CA, Aggarwal SK, Puri IK. 1993. The extinction of methan/methyl chloride nonpremixed flames. Haz Waste Haz Mater 10(1):71–79. 10.1089/hwm.1993.10.71.
Pincince AB. 1988. Estimating volatile organic emissions from publicly owned treatment works. J Water Pollut Cont Fed 59:119–121.
Plumb RH. 1991. The occurrence of appendix IX organic constituents in disposal site ground water. Ground Water Monit Remediat 11(2):157–164. 10.1111/j.1745-6592.1991.tb00378.x.
PubChem. 2021. Compound summary. Vinyl chloride. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/6338. August 2, 2019.
PubChem. 2022. Compound summary: Chloromethane. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/6327. September 14, 2022.
Putz-Anderson V, Setzer JV, Croxton JS. 1981b. Effects of alcohol, caffeine and methyl chloride on man. Psychol Rep 48(3):715–725. 10.2466/pr0.1981.48.3.715.7267903
Putz-Anderson V, Setzer JV, Croxton JS, . 1981a. Methyl chloride and diazepam effects on performance. Scand J Work Environ Health 7(1):8–13. 10.5271/sjweh.2563.7313613
Rafnsson V, Gudmundsson G. 1997. Long-term follow-up after methyl chloride intoxication. Arch Environ Health 52(5):355–359. 10.1080/00039899709602211.9546758
Rafnsson V, Kristbjornsdottir A. 2014. Increased cardiovascular mortality and suicide after methyl chloride exposure. Am J Ind Med 57(1):108–113. 10.1002/ajim.22243.24037987
Redford-Ellis M, Gowenlock AH. 1971a. Studies on the reaction of chloromethane with human blood. Acta Pharmacol Toxicol (Copenh) 30(1):36–48. 10.1111/j.1600-0773.1971.tb00632.x.5171352
Redford-Ellis M, Gowenlock AH. 1971b. Studies on the reaction of chloromethane with preparations of liver, brain and kidney. Acta Pharmacol Toxicol (Copenh) 30(1):49–58. 10.1111/j.1600-0773.1971.tb00633.x.5171353
RePORTER. 2022. Chloromethane. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/advanced-search. August 2, 2019.
Reynolds ES, Yee AG. 1967. Liver parenchymal cell injury: V. Relationships between patterns of chloromethane-C14 incorporation into constituents of liver in vivo and cellular injury. Lab Invest 16(4):591–603.4290484
Rhew RC, Miller BR, Weiss RF. 2000. Natural methyl bromide and methyl chloride emissions from coastal salt marshes. Nature 403(6767):292–295. 10.1038/35002043.10659844
Ristau C, Bolt HM, Vangala RR. 1989. Detection of DNA-protein crosslinks in the kidney of male B6C3F1 mice after exposure to methyl chloride. Arch Toxicol 13:243–245. 10.1007/978-3-642-74117-3_41.
Ristau C, Bolt HM, Vangala RR. 1990. Formation and repair of DNA lesions in kidneys of male mice after acute exposure to methyl chloride. Arch Toxicol 64(3):254–256. 10.1007/bf02010734.2372238
Rodriguez C, Cook A, Van Buynder P, . 2007. Screening health risk assessment of micropullutants for indirect potable reuse schemes: a three-tiered approach. Water Sci Technol 56(11):35–42. 10.2166/wst.2007.831.
Rodriguez C, Linge K, Blair P, . 2012. Recycled water: potential health risks from volatile organic compounds and use of 1,4-dichlorobenzene as treatment performance indicator. Water Res 46(1):93–106. 10.1016/j.watres.2011.10.032.22078226
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rudolph J, Khedim A, Koppmann R, . 1995. Field study of the emissions of methyl chloride and other halocarbons from biomass burning in Western Africa. J Atmos Chem 22(1–2):67–80. 10.1007/BF00708182.
Rushbrook CJ. 1984. Evaluation of toxicological test methods used in estimating potential human health hazards. Dominant lethal study of chloromethane in rats. U.S. Environmental Protection Agency. OTS0511319. 408220726. 47002B3B19. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0511319.xhtml. September 14, 2022.
Sabel GV, Clark TP. 1984. Volatile organic compounds as indicators of municipal solid waste leachate contamination. Waste Manag Res 2(2):119–130. 10.1016/0734-242X(84)90135-6.
Saxena D, Aouad S, Attieh J, . 1998. Biochemical characterization of chloromethane emission from the wood-rotting fungus Phellinus pomaceus. Appl Environ Microbiol 64(8):2831–2835. 10.1128/aem.64.8.2831-2835.1998.9687437
Scharnweber HC, Spears GN, Cowles SR. 1974. Chronic methyl chloride intoxication in six industrial workers. J Occup Med 16(2):112–113.4855514
Shah JJ, Singh HB. 1988. Distribution of volatile organic chemicals in outdoor and indoor air: a national VOCs data base. Environ Sci Technol 22(12):1381–1388. 10.1021/es00177a001.22200458
Shuckrow AJ, Pajah AP, Touhill CJ. 1982. Chloromethane. In: Hazardous waste leachate management manual, Appendix A. Park Ridge, NJ: Noyes Data Corporation, 126–149.
Sieber WK, Sundin DS, Frazier TM, . 1991. Development, use, and availability of a job exposure matrix based on national occupational hazard survey data. Am J Ind Med 20(2):163–174. 10.1002/ajim.4700200204.1951366
Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. Dev Toxicol Environ Sci 2:249–258.
Singh HB, Salas LJ, Stiles RE. 1982. Distribution of selected gaseous organic mutagens and suspect carcinogens in ambient air. Environ Sci Technol 16(12):872–880. 10.1021/es00106a010.22236265
Singh HB, Salas LJ, Stiles RE. 1983. Methyl halides in and over the eastern Pacific (40° N–32° S). J Geophys Res 88(C6):3684–3690. 10.1029/JC088iC06p03684.
Singh HB, Salas L, Shigeishi H, . 1977. Urban-nonurban relationships of halocarbons, SF6, N2O, and other atmospheric trace constituents. Atmos Environ (1967) 11(9):819–828. 10.1016/0004-6981(77)90044-0.
Singh HB, Salas LJ, Shigeishi H, . 1979. Atmospheric halocarbons, hydrocarbons, and sulfur hexafluoride: global distributions, sources, and sinks. Science 203(4383):899–903. 10.1126/science.203.4383.899.17771727
Singh HB, Salas LJ, Smith AJ, . 1981. Measurements of some potentially hazardous organic chemicals in urban environments. Atmos Environ 15(4):601–612. 10.1016/00046981(81)90191-8.
Sleiman M, Logue JM, Luo W, . 2014. Inhalable constituents of thirdhand tobacco smoke: Chemical characterization and health impact considerations. Environ Sci Technol 48(22):13093–13101. 10.1021/es5036333.25317906
Smith WW. 1947. The acute and chronic toxicity of methyl chloride. III. Hematology and biochemical studies. J Ind Hyg Toxicol 29(3):185–189.20296244
Smith WW, von Oettingen WF. 1947a. The acute and chronic toxicity of methyl chloride: I. Mortality resulting from exposures to methyl chloride in concentrations of 4,000 to 300 parts per million. J Ind Hyg Toxicol 29(1):47–52.20278381
Smith WW, von Oettingen WF. 1947b. The acute and chronic toxicity of methyl chloride: II. Symptomatology of animals poisoned by methyl chloride. J Ind Hyg Toxicol 29(2):123–128.20286772
Smith JH, Mabey WR, Bohonos N, . 1977. Environmental pathways of selected chemicals in freshwater systems part 1: Background and experimental procedures. Athens, GA: U.S. Environmental Protection Agency. EPA600777113. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101ZFCE.txt. August 2, 2019.
Snider EH, Manning FS. 1982. A survey of pollutant emission levels in wastewaters and residuals from the petroleum refining industry. Environ Int 7(4):237–258. 10.1016/01604120(82)90114-3.
Spevak L, Nadj V, Felle D. 1976. Methyl chloride poisoning in four members of a family. Br J Ind Med 33(4):272–274. 10.1136/oem.33.4.272.999802
Steinemann A. 2015. Volatile emissions from common consumer products. Air Qual Atmos Health 8(3):273–281. 10.1007/s11869-015-0327-6.
Stewart RD, Hake CL, Wu A, . 1980. Methyl chloride: Development of a biologic standard for the industrial worker by breath analysis. Milwaukee, WI: National Institute for Occupational Safety & Health. PB8116786. Report No.: NIOSH-MCOW-ENVM-MCM-77-1. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB81167686.xhtml. September 14, 2022.
Stirling DI, Dalton H. 1979. The fortuitous oxidation and cometabolism of various carbon compounds by whole-cell suspensions of Methylococcus capsulatus (Bath). FEMS Microbiol Lett 5(4):315–318. 10.1111/j.1574-6968.1979.tb03329.x.
Taylor PH, Dellinger B. 1988. Thermal degradation characteristics of chloromethane mixtures. Environ Sci Technol 22(4):438–447. 10.1021/es00169a012.
Theuns-van Vliet JG. 2016. A prenatal development study in New Zealand white rabbits with methyl chloride by inhalation. Utrecht, Netherlands: Triskelion.
Thier R, Wiebel FA, Hinkel A, . 1998. Species differences in the glutathione transferase GSTT1-1 activity towards the model substrates methyl chloride and dichloromethane in liver and kidney. Arch Toxicol 72(10):622–629. 10.1007/s002040050552.9851677
TRI20. 2022. Toxics Release Inventory (TRI) program. U.S. Environmental Protection Agency. https://www.epa.gov/enviro/tri-search. May 26, 2022.
TRI21. 2022. Toxics Release Inventory (TRI) program. U.S. Environmental Protection Agency. https://www.epa.gov/enviro/tri-search. May 26, 2022.
Tsai WT. 2017. Fate of chloromethanes in the atmospheric environment: Implications for human health, ozone formation and depletion, and global warming impacts. Toxics 5(4):23. 10.3390/toxics5040023.
U.S. Census Bureau. 2018. Trade definitions. U.S. Census Bureau. https://www.census.gov/foreign-trade/reference/definitions/index.html#general_imports. May 2, 2019.
UNEP. 1999. Synthesis of the reports of the scientific, environmental effects, and technology and economic assessment panels of the Montreal Protocol, a decade of assessments for decision makers regarding the protection of the ozone layer: 1988 - 1999. United Nations Environment Programme. https://ozone.unep.org/sites/default/files/2019-05/Synthesis-Complete.pdf. May 2, 2019.
University of Wisconsin. 1986. Drosophila sex linked recessive lethal test on chloromethane. University of Wisconsin. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0511305. 408320709. 47002B3B2. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0511305.xhtml. September 14, 2022.
USGS. 2014. Water quality in principal aquifers of the United States, 1991–2010. Reston, VA: U.S. Geological Survey. Circular 1360. https://pubs.er.usgs.gov/publication/cir1360. December 1, 2022.
USGS. 2015. The Reston groundwater dating laboratory: Low-level VOCs lab. U.S. Geological Survey. https://water.usgs.gov/lab/voc/lab/. August 5, 2019.
USITC. 2019. Chloromethane import and export data. United States International Trade Commission. https://dataweb.usitc.gov/. August 2, 2019.
Vallero DA. 2014. Dynamics within an organism. In: Fundamentals of air pollution. 5th ed. New York, NY: Elsevier Science, 469.
van Doorn R, Borm PJ, Leijdekkers CM, . 1980. Detection and identification of S-methylcysteine in urine of workers exposed to methyl chloride. Int Arch Occup Environ Health 46(2):99–109. 10.1007/BF00378189.7399728
Van Winkle MR, Scheff PA. 2001. Volatile organic compounds, polycyclic aromatic hydrocarbons and elements in the air of ten urban homes. Indoor Air 11(1):49–64. 10.1034/j.1600-0668.2001.011001049.x.11235231
Vannelli T, Studer A, Kertesz M, . 1998. Chloromethane metabolism by methylobacterium sp. strain CM4. Appl Environ Microbiol 64(5):1933–1936. 10.1128/AEM.64.5.1933-1936.1998.9572975
Venkataramani ES, Ahlert RC, Corbo P. 1984. Biological treatment of landfill leachates. CRC Crit Rev Environ Control 14:333–376. 10.1080/10643388409381723.
Verriere MP, Vachez M. 1949. [Gravely acute nephrotoxicity after poisoning by methyl chloride]. Lyon Med 1:296–297. (French)
von Oettingen WF, Powell CC, Sharpless NE, . 1949. Relation between the toxic action of chlorinated methanes and their chemical and physicochemical properties. Washington, DC: National Institutes of Health. NIH Bulletin No. 191.
von Oettingen WF, Powell CC, Sharpless NE, . 1950. Comparative studies of the toxicity and pharmacodynamic action of chlorinated methanes with special reference to their physical and chemical characteristics. Arch Int Pharmacodyn Ther 81(1):17–34.15399270
von Raalte HGS, van Velzen HGECT. 1945. Methyl chloride intoxication. Ind Med 14:707–709.
Wang Z, Minami M. 1996. Effects of chloramine on neuronal cholinergic factors: Further studies of toxicity mechanism suggested by an unusual case record. Biog Amines 12(3):213–223.
Warholm M, Alexandrie AK, Hogberg J, . 1994. Polymorphic distribution of glutathione transferase activity with methyl chloride in human blood. Pharmacogenetics 4(6):307–311.7704036
Warholm M, Rane A, Alexandrie A-K, . 1995. Genotypic and phenotypic determination of polymorphic glutathione transferase Tl in a Swedish population. Pharmacogenetics 5:252–254.8528273
Weinstein A. 1937. Methyl chloride (refrigerator) gas poisoning: an industrial hazard. J Am Assoc 108(19):1603–1605. 10.1001/jama.1937.02780190019008.
Weisel CP, Alimokhtari S, Sanders PF. 2008. Indoor air VOC concentrations in suburban and rural New Jersey. Environ Sci Technol 42(22):8231–8238. 10.1021/es8005223.19068799
Weitzman SA, Stossel TP. 1981. Mutation caused by human phagocytes. Science 212(4494):546–547. 10.1126/science.6259738.6259738
WHO. 1999. Vinyl chloride. Geneva, Switzerland: World Health Organization. Environmental Health Criteria 215. https://inchem.org/documents/ehc/ehc/ehc215.htm. September 14, 2022.
WHO. 2000. Concise international chemical assessment document 28: Methyl chloride. Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/bitstream/handle/10665/42324/9241530286.pdf?sequence=1&isAllowed=y. August 2, 2019.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Wolkowski-Tyl R. 1985. Response to comments on heart malformations in B6C3F1 mouse fetuses induced by methyl chloride - continuing efforts to understand the etiology and interpretation of an unusual lesion. Teratology 32(3):489–492. 10.1002/tera.1420320318.
Wolkowski-Tyl R, Phelps MC, Barrow CS. 1981a. Structural teratogenicity evaluation of methyl chloride in rats and mice after inhalation exposure. Chemical Industry Institute of Toxicology. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8. OTS0205952. 878212062. Docket No. 12512.
Wolkowski-Tyl R, Phelps M, Davis JK. 1983a. Structural teratogenicity evaluation of methyl chloride in rats and mice after inhalation exposure. Teratology 27(2):181–195. 10.1002/tera.1420270206.6867940
Wolkowski-Tyl R, Lawton AD, Marr MC, . 1981b. Methyl chloride structural teratogenicity evaluation in B6C3F1 mice. Chemical Industry Institute of Toxicology. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8DS. OTS84003A. 878212063.
Wolkowski-Tyl R, Lawton AD, Phelps M, . 1983b. Evaluation of heart malformations in B6C3F1 mouse fetuses induced by in utero exposure to methyl chloride. Teratology 27(2):197–206. 10.1002/tera.1420270207.6867941
Wood MW. 1951. Cirrhosis of the liver in a refrigeration engineer attributed to methyl chloride. Lancet 1(6653):508–509. 10.1016/s0140-6736(51)91979-4.
Woodruff TJ, Axelrad DA, Caldwell J, . 1998. Public health implications of 1990 air toxics concentrations across the United States. Environ Health Perspect 106(5):245–251. 10.1289/2Fehp.98106245.9518474
Working PK, Bus JS. 1986. Failure of fertilization as a cause of preimplantation loss induced by methyl chloride in Fischer 344 rats. Toxicol Appl Pharmacol 86(1):124–130. 10.1016/0041-008x(86)90405-9.3764932
Working PK, Chellman GJ. 1989. The use of multiple endpoints to define the mechanism of action of reproductive toxicants and germ cell mutagens. Prog Clin Biol Res 302:211–224.2666990
Working PK, Bus JS, Hamm TE. 1985a. Reproductive effects of inhaled methyl chloride in the male Fischer 344 rat. I. Mating performance and dominant lethal assay. Toxicol Appl Pharmacol 77(1):133–143. 10.1016/0041-008x(85)90274-1.3966236
Working PK, Bus JS, Hamm TE. 1985b. Reproductive effects of inhaled methyl chloride in the male Fischer 344 rat. II. Spermatogonial toxicity and sperm quality. Toxicol Appl Pharmacol 77(1):144–157. 10.1016/0041-008X(85)90275-3.3966237
Working PK, Doolittle DJ, Smith-Oliver T, . 1986. Unscheduled DNA synthesis in rat tracheal epithelial cells, hepatocytes and spermatocytes following exposure to methyl chloride in vitro and in vivo. Mutat Res 162(2):219–224. 10.1016/0027-5107(86)90088-6.3748050
WQP. 2022. Water quality portal: Chloromethane. National Water Quality Monitoring Council. https://www.waterqualitydata.us/. September 16, 2022.
Xing L, Wang L, Zhang R. 2018. Characteristics and health risk assessment of volatile organic compounds emitted from interior materials in vehicles: a case study from Nanjing, China. Environ Sci Pollut Res Int 25(15):14789–14798. 10.1007/s11356-018-1661-7.29541982
Xu DG, Peter H, Hallier E, . 1990. Hemoglobin adducts of monohalomethanes. Ind Health 28(3):121–123. 10.2486/indhealth.28.121.2283319
Yokouchi Y, Noijiri Y, Barrie LA, . 2000. A strong source of methyl chloride to the atmosphere from tropical coastal land. Nature 403(6767):295–298. 10.1038/35002049.10659845
Yokouchi Y, Ikeda M, Inuzuka Y, . 2002. Strong emission of methyl chloride from tropical plants. Nature 416(6877):163–165. 10.1038/416163a.11894090
Yokouchi Y, Saito T, Ishigaki C, . 2007. Identification of methyl chloride-emitting plants and atmospheric measurements on a subtropical island. Chemosphere 69(4):549–553. 10.1016/j.chemosphere.2007.03.028.17462706
Zafiriou OC. 1975. Reaction of methyl halides with seawater and marine aerosols. J Mar Res 33:75–81.
Zhang W, Jiao Y, Zhu R, . 2020. Methyl chloride and methyl bromide production and consumption in coastal Antarctic tundra soils subject to sea animal activities. Environ Sci Technol 54(20):13354–13363. 10.1021/acs.est.0c04257.32935983
Zitomer DH, Speece RE. 1995. Methanethiol in nonacclimated sewage sludge after addition of chloroform and other toxicants. Environ Sci Technol 29(3):762–768. 10.1021/es00003a025.22200286