# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Sam Keith, M.S., C.H.P. (Lead)
  Breanna Alman, M.P.H.
  ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA

- Lauren Brown, M.S., D.A.B.T.
  Kaley Beins, M.P.H.
  Hannah Derrick, B.S.
  Kerry Diskin, Ph.D.
  Andrea Chiger, M.P.H.
  Mary Juergens, M.P.H.
  Meghan Lynch, M.P.H., DSc
  Abt Associates, Cambridge, MA

- Kimberly Zaccaria, Ph.D., D.A.B.T.
  Deborah Herber, Ph.D.
  Mario Citra, Ph.D.
  Christina Coley, B.S.
  SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Sciences and Practice; EPA.

## PEER REVIEWERS

Peer Reviewers for the full profile:

1. Kyle Steenland, Ph.D., Professor, Department of Environmental Health Professor, Department of Epidemiology, Rollins School of Public Health, Emory University, Atlanta, Georgia
2. James S. Bus Ph.D., DABT, Fellow ATS, Senior Managing Scientist, Center for Toxicology and Mechanistic Biology, Midland, Michigan
3. Dale Hattis, Ph.D., George Perkins Marsh Institute, Clark University, Worcester, Massachusetts

Peer Reviewers for the intermediate-duration inhalation MRL:

1. Lili Tang, Ph.D., Associate Professor, Biological Sciences Department, University of Georgia, Athens, Georgia
2. James S. Bus Ph.D., DABT, Senior Managing Scientist, Center for Toxicology and Mechanistic Biology, Midland, Michigan
3. Vilhjálmur Rafnsson MD, Ph.D., Professor in Preventive Medicine, University of Iceland, Reykjavik, Iceland

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.