# VERSION HISTORY

Date | Description
September 2023 | Final toxicological profile released
January 2022 | Draft for public comment toxicological profile released
June 2009 | Addendum to the toxicological profile released
December 1998 | Final toxicological profile released