# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding chloromethane in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for chloromethane.

Table 7-1 Regulations and Guidelines Applicable to Chloromethane

Agency | Description | Information | Reference
Air
EPA | RfC | 0.09 mg/m^3^ (0.04 ppm) | EPA 2001
EPA | Provisional peer reviewed toxicity values | | EPA 2012b
EPA | Subchronic provisional RfC | 3 mg/m^3^ (1 ppm)
WHO | Air quality guidelines | 0.018 mg/m^3^ (0.009 ppm) | WHO 2000
Water & Food
EPA | Drinking water standards | | EPA 2018a
EPA | 1-day health advisory for a 10-kg child | 9 mg/L
EPA | 10-day health advisory for a 10-kg child | 0.4 mg/L
EPA | Lifetime health advisory | No data
EPA | National primary drinking water regulations | No data | EPA 2009
EPA | RfD | No data | EPA 2001
WHO | Drinking water quality guidelines | No data | WHO 2022
FDA | Substances Added to Food^a^ | No data | FDA 2022
Cancer
HHS | Carcinogenicity classification | No data | NTP 2021
EPA | Carcinogenicity classification | Group D^b^ | EPA 2001
IARC | Carcinogenicity classification | Group 3^c^ | IARC 1999
NIOSH | Carcinogenicity classification | Potential occupational carcinogen^d^ | NIOSH 2019
Occupational
OSHA | PEL (8-hour TWA) for general industry and shipyards | 100 ppm | OSHA 2021a, 2021b
OSHA | Ceiling PEL for general industry | 200 ppm; 300 ppm maximum peak (5 minutes in any 3 hours) | OSHA 2021a
NIOSH | REL (up to 10-hour TWA) | Lowest feasible concentration^d^ | NIOSH 2018, 2019
Emergency Criteria
EPA | AEGLs-air | | EPA 2018b
EPA | AEGL 1^e^
EPA | 10-minute | NR^f^
EPA | 30-minute | NR
EPA | 60-minute | NR
EPA | 4-hour | NR
EPA | 8-hour | NR
EPA | AEGL 2^e^
EPA | 10-minute | 1,100 ppm
EPA | 30-minute | 1,100 ppm
EPA | 60-minute | 910 ppm
EPA | 4-hour | 570 ppm
EPA | 8-hour | 380 ppm
EPA | AEGL 3^e^
EPA | 10-minute | 3,800 ppm
EPA | 30-minute | 3,800 ppm
EPA | 60-minute | 3,000 ppm
EPA | 4-hour | 1,900 ppm
EPA | 8-hour | 1,300 ppm
DOE | PACs | | DOE 2018a
DOE | PAC-1^g^ | 150 ppm
DOE | PAC-2^g^ | 910 ppm
DOE | PAC-3^g^ | 3,000 ppm

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b Group D: Not classifiable as to its human carcinogenicity.

c Group 3: Not classifiable as to its carcinogenicity to humans.

d NIOSH recommends wearing the most protective respirators for chloromethane at any detectable concentration.

e Definitions of AEGL terminology are available from U.S. EPA (2018c).

f NR: not recommended due to insufficient data.

g Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; HHS = Department of Health and Human Services; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = Generally Recognized As Safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization