# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR CHLOROMETHANE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to chloromethane.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for chloromethane. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of chloromethane have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of chloromethane are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for chloromethane released for public comment in 2022; thus, the literature search was restricted to studies published between January 2018 and June 2022. The following main databases were searched in June 2022:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for chloromethane. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to chloromethane were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
06/2022 | (74-87-3[rn] AND (2018:3000[mhda] OR 2018:3000[crdat] OR 2018:3000[edat] OR 2018:3000[dp])) OR (((“Chlormethan”[tw] OR “Chloromethane”[tw] OR “Methane, chloro"-[tw] OR “Methyl chloride”[tw] OR “Methylchloride”[tw] OR “Monochloromethane”[tw]) AND (2018:3000[crdat] OR 2018:3000[edat] OR 2018:3000[dp])) NOT medline[sb])
NTRL
06/2022 | “Chlormethan” OR “Chloromethane” OR “Methane, chloro-” OR “Methyl chloride” OR “Methylchloride” OR “Monochloromethane”
Toxcenter
06/2022 | FILE ‘TOXCENTER’ ENTERED AT 13:37:02 ON 15 JUN 2022 CHARGED TO COST=EH038.13.03.LB.04; L1 4179 SEA FILE=TOXCENTER 74-87-3; L2 4020 SEA FILE=TOXCENTER L1 NOT TSCATS/FS; L3 3345 SEA FILE=TOXCENTER L2 NOT PATENT/DT; L4 348 SEA FILE=TOXCENTER L3 AND PY>=2018 ACTIVATE TOXQUERY/Q; -------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST, CT, IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?) L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (NONHUMAN MAMMALS)/ORGN; L35 QUE L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; -------; L38 126 SEA FILE=TOXCENTER L4 AND L37; L39 5 SEA FILE=TOXCENTER L38 AND MEDLINE/FS; L40 8 SEA FILE=TOXCENTER L38 AND BIOSIS/FS; L41 113 SEA FILE=TOXCENTER L38 AND CAPLUS/FS; L42 0 SEA FILE=TOXCENTER L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L43 121 DUP REM L39 L40 L41 (5 DUPLICATES REMOVED); L*** DEL 5 S L38 AND MEDLINE/FS; L*** DEL 5 S L38 AND MEDLINE/FS; L44 5 SEA FILE=TOXCENTER L43; L*** DEL 8 S L38 AND BIOSIS/FS; L*** DEL 8 S L38 AND BIOSIS/FS; L45 6 SEA FILE=TOXCENTER L43; L*** DEL 113 S L38 AND CAPLUS/FS; L*** DEL 113 S L38 AND CAPLUS/FS; L46 110 SEA FILE=TOXCENTER L43; L47 116 SEA FILE=TOXCENTER (L44 OR L45 OR L46) NOT MEDLINE/FS D SCAN L47

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via Chem | View
06/2022 | 74-87-3
NTP
06/2022 | “74-87-3” “Methyl chloride” “Chloromethane”; “Chlormethan” “Methane, chloro-” “Methylchloride” “Monochloromethane”
Regulations.gov
06/2022 | Limited to dockets, or documents with DocType: Notice, Posted 01/01/2018 to 06/16/2022, Agency: EPA; “Methyl chloride”; “74-87-3”; “Chlormethan”; “Methane, chloro-”; “Methylchloride”;; “Monochloromethane”; “Chloromethane”
NIH RePORTER
09/2022 | Fiscal Year: Active Projects; Text Search: “Chlormethan” OR “Chloromethane” OR “Methane, chloro-” OR “Methyl chloride” OR “Methylchloride” OR “Monochloromethane” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2022 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 183
- Number of records identified from other strategies: 26
- Total number of records to undergo literature screening: 209

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on chloromethane:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 209
- Number of studies considered relevant and moved to the next step: 50

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 50
- Number of studies cited in the pre-public draft of the toxicological profile: 247 • Total number of studies cited in the profile: 274

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 June 2022 Literature Search Results and Screen for Chloromethane