# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## Chloromethane Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloromethane
CAS Numbers: | 74-87-3
Date: | September 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 0.5 ppm (1 mg/m^3^)
Critical Effect: | Degenerative changes in the cerebellum granule cells
Reference: | Landry et al. (1985)
Point of Departure: | NOAEL of 50 ppm; (NOAEL_HEC_ of 46 ppm)
Uncertainty Factor: | 30
Modifying Factor: | 3
LSE Graph Key: | 26
Species: | Mouse

MRL Summary: An acute-duration inhalation MRL of 0.5 ppm was derived for chloromethane based on neurological effects including moderate degenerative changes in the cerebellum granule cells with nuclear pyknosis and karyorrhexis in female C57BL/6 mice following exposure to chloromethane for 22 hours/day for 11 days (Landry et al. 1985). The MRL is based on a NOAEL of 50 ppm, which was adjusted to a human equivalent concentration (NOAEL_HEC_) of 46 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustments and 10 for human variability) and a modifying factor of 3 to account for the steepness of the dose-response curve.

Selection of the Critical Effect: Based on systematic review (see Appendix C), it was determined that hepatic, neurological, and male reproductive effects were presumed health effects associated with inhalation exposure. These presumed health effects were subsequently the focus of the acute-duration MRL evaluation.

For presumed health effects, the lowest reported LOAELs and serious LOAELs from acute-duration inhalation studies were reviewed to determine the most sensitive effects (Table A-1). Since studies used a variety of exposure paradigms, ranging from intermittent exposure (5.5 or 6 hours/day) to continuous or near-continuous exposure (22–24 hours/day), LOAELs and serious LOAELs were adjusted for continuous exposure. The lowest reported duration-adjusted LOAELs and serious LOAELs were 92 and 486 ppm, respectively, for neurological effects; 92 and 375 ppm, respectively, for hepatic effects; and 501 and 500 ppm, respectively, for male reproductive effects. Based on duration-adjusted values, the lowest LOAELs are comparable for neurological and hepatic effects, and the severity of effects show a comparable dose-response curve. Therefore, both the nervous and hepatic systems are considered sensitive targets of chloromethane toxicity. However, the human evidence (predominantly from case reports) shows that neurological effects are the main observed adverse outcome after accidental acute-duration exposure to chloromethane (Baird 1954; Baker 1927; Battigelli and Perini 1955; Borovska et al. 1976; Hansen et al. 1953; Hartman et al. 1955; Jones 1942; Kegel et al. 1929; MacDonald 1964; McNally 1946; Minami 1998; Spevak et al. 1976; von Raalte and van Velzen 1945; Wood 1951). Therefore, neurological effects are selected as the critical effect for the acute-duration inhalation MRL.

Table A-1 Selected NOAEL and LOAEL Values Following Acute-Duration Inhalation Exposure to Chloromethane

Species | Duration | NOAEL (NOAEL_ADJ_) (ppm) | LOAEL (LOAEL_ADJ_) (ppm) | Effect | Reference
Neurological effects
C57BL/6 mouse | 11 days 22 hours/day | 50 (46) | 100 (92) | Slight cerebellar granule cell degeneration | Landry et al. 1985
C57BL/6 mouse | 11 days 5.5 hours/day | 150 (34) | 400 (92) | Slight cerebellar granule cell degeneration | Landry et al. 1985
Beagle dog | 3 days 23.5 hours/day | 197 (193) | 496 (486) (SLOAEL) | Severe clinical signs of neurotoxicity; lesions in brain and spinal cord; axonal loss | McKenna et al. 1981a
Swiss, Strain A, C3H mouse | 2 weeks 6 hours/day 6 days/week | 300 (64) | 500 (107) (SLOAEL) | Neuromuscular abnormalities, impaired gait, hindlimb drag | Smith and von Oettingen 1947b
Dog (NS) | 2 weeks 6 hours/day 6 days/week | 300 (64) | 500 (107) (SLOAEL) | Tremors, spasticity, impaired gait | Smith and von Oettingen 1947b
C57BL/6 mouse | 12 days 6 hours/day GDs 6–17 | 251 (63) | 502 (126) (SLOAEL) | Ataxia in dams | Wolkowski-Tyl et al. 1981b, 1983b
Hepatic effects
C57BL/6 mouse | 11 days 22 hours/day | 50 (46) | 100 (92) | Decreased hepatocyte size; glycogen depletion | Landry et al. 1985
C57BL/6 mouse | 11 days 5.5 hours/day | 150 (34) | 400 (92) | Decreased hepatocyte size; glycogen depletion | Landry et al. 1985
C57BL/6 or C3H mouse | 12 days 6 hours/day | ND | 500 (125) | Minimal hepatocellular degeneration | Morgan et al. 1982
Sprague-Dawley rat | 48 hours continuous | ND | 196 (196) | Decreased liver weight | Burek et al. 1981
Sprague-Dawley rat | 72 hours continuous | ND | 198 (198) | Decreased absolute and relative liver weight and altered tinctorial^a^ appearance in males, lipid accumulation in females | Burek et al. 1981
Guinea pig | 6 days 6 hours/day | 500 | 1,000 (250) | Fatty metamorphosis | Dunn and Smith 1947
B6C3F1 mouse | 6 hours | ND | 1,500 (375) (SLOAEL) | Hepatocellular necrosis and cytoplasmic vacuolization; increased serum ALT | Chellman et al. 1986b
Male reproductive effects
Sprague-Dawley rat | 48 hours continuous | 196 (196) | 501 (501) | Testicular lesions, decreased sperm in the lumen | Burek et al. 1981
Sprague-Dawley rat | 72 hours continuous | 198 (198) | 504 (504) | Testicular lesions, decreased sperm in the lumen | Burek et al. 1981
Fischer-344 rat | 9 days 6 hours/day | ND | 2,000 (500) (SLOAEL) | Reduced sperm, immature sperm in lumen, testicular lesions | Morgan et al. 1982

a Altered staining properties of hepatocyte.

ADJ = adjusted for continuous exposure; ALT = alanine aminotransferase; GD = gestation day; LOAEL = lowestobserved-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; SLOAEL = serious LOAEL

Selection of the Principal Study: The 11-day mouse study (Landry et al. 1985) was selected as the principal study because it provides the highest NOAEL below the lowest LOAEL for the critical effect (neurotoxicity).

Summary of the Principal Study:

Landry TD, Quast JF, Gushow TS, . 1985. Neurotoxicity of methyl chloride in continuously versus intermittently exposed female c57bl/6 mice. Fundam Appl Toxicol 5(1):87–98.3987995

Landry et al. (1985) evaluated the neurological effects of chloromethane following nearly continuous exposure versus intermittent exposure in female C57BL/6 mice. This species, strain, and sex were chosen due to their high sensitivity to chloromethane-associated neurological effects. Groups of 12 mice each were exposed to chloromethane in whole-body inhalation chambers for 11 days for either 22 hours/day (referred to as “continuous” by the study authors) or 5.5 hours/day (referred to as intermittent by the study authors). Each duration protocol had two distinct experiments, each with their own concurrent control. For the continuous exposure, the first experiment exposed mice to 0, 15, 50, or 150 ppm and the second experiment exposed mice to 0, 100, 200, or 400 ppm. For the intermittent exposure, the first experiment exposed mice to 0, 150, or 2,400 ppm and the second experiment exposed mice to 0, 400, 800, or 1,600 ppm. Mice were evaluated twice daily for clinical signs of toxicity. Motor coordination was evaluated using a rotarod (ability to stay on a rotating 4-cm diameter rod) on exposure days 4, 8, and 11. Mice were weighed prior to exposure, on exposure days 4 and 8, and at necropsy. Animals were sacrificed after exposure, and the following tissues were collected, weighed, and prepared for histological evaluation in six mice/group: brain (cerebellum, cerebrum, and brain stem), sciatic nerve, vertebral bone with spinal cord, liver, kidneys, and thymus.

All mice exposed continuously to ≥150 ppm and intermittently to 2,400 ppm died or were sacrificed moribund prior to scheduled sacrifice. Prior to death/moribund sacrifice, mice displayed inanition (exhaustion caused by lack of nourishment) associated with decreased food consumption. Hematuria was observed in mice exposed to 2,400 ppm. Consistent with this, body weights were decreased by >10% at both continuous and intermittent exposure levels associated with decreased survival. Mice continuously exposed to ≥200 ppm showed ataxia and prostration by day 3; therefore, they were not assessed on the rotarod. In other continuously exposed groups, performance on a rotating rod was significantly decreased following exposure to 150 ppm starting on day 4, with severity of impairment increasing in a duration-related manner; no changes in motor coordination were observed at ≤100 ppm. In mice exposed intermittently, sedation and hind-limb rigidity were observed in some mice at ≥1,600 ppm. Transient decreases in motor coordination on the rotarod were observed in mice exposed to 800 or 1,600 ppm on day 4; however, decreases were not observed on days 8 or 11. In mice intermittently exposed to 2,400 ppm, motor activity decreased in a duration-related manner starting on day 4.

At sacrifice, gross necropsy showed thymus atrophy at ≥1,600 ppm and an enlarged spleen at 2,400 ppm in mice exposed intermittently. The enlarged spleen was accompanied by hemoglobinuria, which is suggestive of extramedullary hematopoiesis. Absolute and relative thymus weights were reduced in all exposure groups from the first continuous exposure group (15, 50, and 150 ppm); however, no changes in thymus weights were observed in the second experiment at 100 ppm (thymic weights were not weighed at higher exposure levels due to early death). Therefore, the biological significance of decreased thymus weight at low concentrations is unclear due to lack of clear dose-response. In intermittently exposed mice, absolute and relative thymus weights were reduced at ≥1,600 ppm, and absolute and relative liver weights were increased at 1,600 ppm (but not at 2,400 ppm; this may be due to early sacrifice at this concentration). Other observed organ weight changes, including decreased absolute liver weight and increased relative kidney weight after continuous exposure to 150 ppm, were considered secondary to body weight effects.

Histopathological changes were observed in the brain, liver, and kidney. In the brain, degenerative changes in the cerebellum granule cells were observed in 100% of mice continuously exposed to ≥100 ppm, 33% of mice intermittently exposed to 400 ppm, 65–67% of mice intermittently exposed to 800–1,600 ppm, and 100% of mice intermittently exposed to 2,400 ppm. The changes consisted of nuclear pyknosis, karyorrhexis, and hemorrhaged areas, and the severity of the lesions increased in a concentration- and duration-dependent manner. In the liver, decreased hepatocyte size (attributed to glycogen depletion by the study authors) were also observed in mice continuously exposed to ≥100 ppm or intermittently exposed to ≥400 ppm. The study authors noted focal hepatic necrosis at unspecified “higher concentrations.” In the kidney, slight multifocal degeneration of the renal tubules was observed after intermittent exposure to 2,400 ppm. Incidence data were not provided for hepatic or renal lesions.

Selection of the Point of Departure for the MRL: In order to select the POD based on neurological effects observed by Landry et al. (1985), data from experiments with the same daily duration were combined for dose-response analysis, and duration adjustments were made to compare across continuous and intermittent exposure scenarios (Table A-2). While the adjusted LOAEL concentrations are comparable across exposure scenarios, the continuous exposure scenario provides the highest NOAEL below the lowest LOAEL; therefore, the continuous exposure scenario was selected for derivation of the acute-duration inhalation MRL. Additionally, due to the steep dose-response curve (cerebellar lesion incidence of 0% at NOAEL and 100% at LOAEL), benchmark dose (BMD) modeling was not conducted to develop the MRL. Subsequently, the NOAEL of 50 ppm (NOAEL_ADJ_ of 46 ppm) was used in derivation of the MRL.

Table A-2 Summary of Neurological Effects Observed in Mice Exposed to Chloromethane for 11 Days via Inhalation

Continuous exposure (22 hours/day) | | Intermittent exposure (5.5 hours/day)
Concentration (adjusted^a^) (ppm) | Effect | Concentration (adjusted^a^) (ppm) | Effect
15 (14) | No neurological effects
50 (46) | No neurological effects | 150 (34) | No neurological effects
100 (92) | Slight degenerative changes in the cerebellum granule cells (100% incidence) | 400 (92) | Slight degenerative changes in the cerebellum granule cells (33% incidence)
150 (138) | Moderate cerebellar lesions (100% incidence); impaired motor coordination
200 (183) | Incapacitated after 4 days, severe cerebellar lesions (100% incidence) | 800 (183) | Slight degenerative changes in the cerebellum granule cells (67% incidence); transient impairment in motor coordination
400 (367) | Incapacitated after 2 days, severe cerebellar lesions (100% incidence) | 1,600 (367) | Slight degenerative changes in the cerebellum granule cells (65% incidence); sedation, hindlimb rigidity, transient impairment in motor coordination
| | 2,400 (505) | Slight degenerative changes in the cerebellum granule cells (100% incidence); sedation, hindlimb rigidity, impaired motor coordination

a Exposure concentration adjusted for continuous exposure.

Source: Landry et al. 1985

Adjustment of Intermittent Exposure: The NOAEL of 50 ppm concentration was adjusted from a 22-hour exposure to a continuous 24-hour exposure scenario:

N O A E L_A D J_ = N O A E L × (22 h o u r s)/(24 h o u r s) = 50 p p m × (22 h o u r s)/(24 h o u r s) = 46 p p m

The human equivalent concentration (HEC) was calculated by multiplying the duration-adjusted NOAEL by the default ratio of 1 for air:blood partition coefficient for humans and rats (partition coefficient values are not available for chloromethane):

N O A E L_H E C_ = N O A E L_A D J_ × ((H B / g)_A_)/((H B / g)_H_) = 46 p p m × 1 = 46 p p m

Where:

((H B / g)_A_)/((H B / g)_H_) = the blood : air partition coefficient ratio for animal (a) to human (h)

Uncertainty Factors and Modifying Factor: The following uncertainty factors were applied to the NOAEL_HEC_ to derive the MRL:

- uncertainty factor of 3 for extrapolation from animals to humans with dosimetric adjustments
- uncertainty factor of 10 for human variability
- modifying factor of 3 to account for the steep dose-response seen between the NOAEL and the LOAEL (e.g., 100% response rate in the animals evaluated at the LOAEL)

Subsequently, the MRL for acute-duration exposure to chloromethane via inhalation is:

M R L = (N O A E L_H E C_)/((U F × M F)) = (46 p p m)/(90) = 0.5 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that neurological effects are a presumed health effect following inhalation exposure to chloromethane based on a low level of evidence from human studies and a high level of evidence from animal studies (see Appendix C).

In humans, there are multiple case reports that noted adverse neurological effects as the main observed outcome after exposure to chloromethane (Baird 1954; Baker 1927; Battigelli and Perini 1955; Borovska et al. 1976; Hansen et al. 1953; Hartman et al. 1955; Jones 1942; Kegel et al. 1929; MacDonald 1964; McNally 1946; Minami 1998; Spevak et al. 1976; von Raalte and van Velzen 1945; Wood 1951). Additionally, one occupational cohort study reported neurological effects, some lasting years after exposure, following accidental exposure to high levels of chloromethane from a refrigeration leak (Gudmundsson 1977). At lower concentration levels, neurological effects were not noted in an occupational cohort study (NIOSH 1976) or three human controlled trials (Putz-Anderson et al. 1981a, 1981b; Stewart et al. 1980). In animals, a range of neurological effects have been observed in rats, mice, and dogs, including clinical signs of neurotoxicity, motor impairments, and lesions in the cerebellum and spinal cord. Neurological effects were observed following inhalation exposure for acute durations (Burek et al. 1981; Chellman et al. 1986a, 1986b; Jiang et al. 1985; Landry et al. 1985; McKenna et al. 1981a; Morgan et al. 1982; Smith and von Oettingen 1947b; Wolkowski-Tyl et al. 1983a, 1983b), intermediate durations (McKenna et al. 1981b; Smith and von Oettingen 1947b), or chronic durations (CIIT 1981).

Agency Contact (Chemical Manager): Sam Keith, MS, CPH

## Chloromethane Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloromethane
CAS Numbers: | 74-87-3
Date: | September 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.3 ppm (0.6 mg/m^3^)
Critical Effect: | Impaired sensorimotor function
Reference: | McKenna et al. 1981b
Point of Departure: | NOAEL of 51 ppm; (NOAEL_HEC_ of 9 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 44
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.3 ppm was derived for chloromethane based on neurological effects including impaired sensorimotor performance (wire maneuver) in female Sprague-Dawley rats following exposure to chloromethane for 93 days (5 days/week, 6 hours/day) (McKenna et al. 1981b). The MRL is based on a NOAEL of 51 ppm, which was adjusted to continuous duration exposure and converted to a human equivalent concentration (NOAEL_HEC_) of 9 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustments and 10 for human variability).

Selection of the Critical Effect: Based on systematic review (see Appendix C), it was determined that hepatic, neurological, and male reproductive effects were presumed health effects associated with inhalation exposure. These presumed health effects were subsequently the focus of the intermediate-duration MRL evaluation.

For presumed health effects, the lowest reported LOAELs from intermediate-duration inhalation studies were 149 ppm for neurological effects, 399 ppm for hepatic effects, and 472 ppm for male reproductive effects (Table A-3). Based on available data, the nervous system appears to be the most sensitive target of chloromethane toxicity and is selected as the critical effect for the intermediate-duration inhalation MRL.

Table A-3 Selected NOAEL and LOAEL Values Following Intermediate-Duration Inhalation Exposure to Chloromethane

Species | Duration | NOAEL (NOAEL_ADJ_) (ppm) | LOAEL (LOAEL_ADJ_) (ppm) | Effect | Reference
Neurological effects
Sprague-Dawley rat | 93 days 5 days/week 6 hours/day | 51 (9) | 149 (27) | Impaired sensorimotor function (wire maneuver) | McKenna et al. 1981b
CD-1 mouse | 93 days 5 days/week 6 hours/day | 399 (71) | ND | No adverse effects | McKenna et al. 1981b
Monkey (NS) | 120 days 6 days/week 6 hours/day | 300 (64) | 500 (107)^a^ (SLOAEL) | Progressive debility, prostration, loss of consciousness | Smith and von Oettingen 1947b
Mouse (NS) | 266 days 6 days/week 6 hours/day | 300 (64) | 500 (107)^a^ (SLOAEL) | Persistent neuromuscular abnormalities, impaired gait, hindlimb paralysis | Smith and von Oettingen 1947b
Guinea pig (NS) | 266 days 6 days/week 6 hours/day | 300 (64) | 500 (107)^a^ (SLOAEL) | Persistent neuromuscular abnormalities, impaired gait, hindlimb drag | Smith and von Oettingen 1947b
Dog (NS) | 211 days 6 days/week 6 hours/day | 300 (64) | 500 (107) (SLOAEL) | Severe clinical signs of neurotoxicity (e.g., tremors, spasticity, impaired gait) | Smith and von Oettingen 1947b
Hepatic effects
Sprague-Dawley rat | 93 days 5 days/week 6 hours/day | 149 (27) | 399 (71) | Increased relative liver weight | McKenna et al. 1981b
CD-1 mouse | 93 days 5 days/week 6 hours/day | 149 (27) | 399 (71) | Increased relative liver weight | McKenna et al. 1981b
B6C3F1 mouse | 90 days 5 days/week 6 hours/day | 368 (66) | 741 (132) | Increased relative liver weight | Mitchell et al. 1979
B6C3F1 mouse | 6 months 5 days/week 6 hours/day | 224 (40) | 997 (178) | Hepatocellular degeneration | CIIT 1981
Male reproductive effects
Fischer 344 rat | 12–19 weeks per generation 5–7 days/week 6 hours/day | 151 (32) | 472 (101) | Decreased number of fertile F0 males, decreased number of litters per copulation plug in F0 rats | Hamm et al. 1985
Fischer 344 rat | 6 months 5 days/week 6 hours/day | 224 (40) | 997 (178) | Degeneration and atrophy of seminiferous tubules; sperm granulomas | CIIT 1981
Sprague-Dawley rat | 93 days 5 days/week 6 hours/day | 399 (71) | ND | No adverse effects (fertility not assessed) | McKenna et al. 1981b
Fischer 344 rat | 90 days 5 days/week 6 hours/day | 1,473 (263) | ND | No adverse effects (fertility not assessed) | Mitchell et al. 1979

a Decreased survival observed at this concentration

ADJ = adjusted for intermittent exposure; LOAEL = lowest observed adverse effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: The 93-day rat study (McKenna et al. 1981b) was selected as the principal study because it provides the highest NOAEL below the lowest LOAEL for the critical effect (neurotoxicity).

Summary of the Principal Study:

McKenna MJ, Burek JD, Henck JW, . 1981b. Methyl chloride: A 90-day inhalation toxicity study in rats, mice and beagle dogs. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0511317. 408120723. 47002B3B17.

McKenna et al. (1981b) exposed Sprague-Dawley rats (10/sex/group) to chloromethane at nominal concentrations of 0, 50, 150, or 400 ppm for 93 days (5 days/week, 6 hours/day). Analytical concentrations were 0, 51, 149, and 399 ppm, respectively. Animals were observed daily for clinical signs of toxicity. Body weights were measured twice weekly for the first 4 weeks and weekly thereafter. Sensorimotor responses were tested in 5/sex/group weekly for the first 4 weeks of exposure, and every other week thereafter. Sensorimotor tests included evaluation of body position, respiration, piloerection, exophthalmos, tremor, corneal reflex, pinna reflex, tail pinch, toe pinch, righting reflex, grasp irritability, visual placing, wire maneuver, and hindlimb clasping. Blood and urine were collected for hematology and urinalysis prior to the initiation of exposure and at study termination. Serum clinical chemistry endpoints were evaluated at time of necropsy. All animals underwent gross necropsy, and the following organ weights were measured: brain, heart, liver, kidneys, and testes. Histopathological examination of a comprehensive set of tissues was conducted on all rats in the control and 399-ppm group.

Two rats died prior to study termination, 1 female at 51 ppm and 1 female at 399 ppm. These deaths were not attributed to exposure. No clinical signs of toxicity were noted. A dose-related trend toward reduced body weight gain was noted in female rats; however, no statistically or biologically significant findings were observed. No exposure-related changes in clinical chemistry, hematology, or urinalysis were observed. The only exposure-related change in organ weights was a 10% increase in relative liver weights in male rats at 399 ppm. No exposure-related gross or microscopic lesions were observed.

Sensorimotor testing showed a significant decrease in the ability of female rats to perform the wire maneuver (inability of the animals to raise their hindquarters to the top of the wire while grasping with forelimbs) at 399 ppm beginning at day 16 and 149 ppm beginning at day 40, and persistent throughout the remainder of the study. Hindlimb clasping was significantly impaired in female rats at 399 ppm beginning on day 66 through the end of the study. In males, hindlimb clasping was transiently impaired at ≥149 ppm, observed only on days 16–39.

Selection of the Point of Departure for the MRL: The NOAEL of 51 ppm for neurological effects in the study by McKenna et al. (1981b) was selected as the point of departure (POD). While the study authors reported statistical results for sensorimotor testing, quantitative data were not provided; therefore, BMD modeling was not used to derive this MRL.

Adjustment of Intermittent Exposure: The NOAEL of 51 ppm concentration was adjusted for a continuous exposure scenario:

N O A E L_A D J_ = N O A E L × (6 h o u r s)/(24 h o u r s) × (5 days)/(7 days) = 51 p p m × (6 h o u r s)/(24 h o u r s) × (5 days)/(7 days) = 9 p p m

The human equivalent concentration (HEC) was calculated by multiplying the duration-adjusted NOAEL by the default ratio of 1 for air:blood partition coefficient for humans and rats (partition coefficient values are not available for chloromethane):

N O A E L_H E C_ = N O A E L_A D J_ × ((H B / g)_A_)/((H B / g)_H_) = 9 p p m × 1 = 9 p p m

Where:

((H B / g)_A_)/((H B / g)_H_) = the blood : air partition coefficient ratio for animal (a) to human (h)

Uncertainty Factors used in MRL derivation: The following uncertainty factors were applied to the NOAEL_HEC_ to derive the MRL:

- uncertainty factor of 3 for extrapolation from animals to humans with application of dosimetric adjustment
- uncertainty factor of 10 for human variability.

Subsequently, the inhalation MRL for intermediate-duration exposure to chloromethane is:

M R L = (N O A E L_H E C_)/((U F)) = (9 p p m)/(30) = 0.3 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that neurological effects are a presumed health effect following inhalation exposure to chloromethane based on a low level of evidence from human studies and a high level of evidence from animal studies (see Appendix C).

In humans, there are multiple case reports that noted adverse neurological effects as the main observed outcome after exposure to chloromethane (Baird 1954; Baker 1927; Battigelli and Perini 1955; Borovska et al. 1976; Hansen et al. 1953; Hartman et al. 1955; Jones 1942; Kegel et al. 1929; MacDonald 1964; McNally 1946; Minami 1998; Spevak et al. 1976; von Raalte and van Velzen 1945; Wood 1951). Additionally, one occupational cohort study reported neurological effects, some lasting years after exposure, following accidental exposure to high levels of chloromethane from a refrigeration leak (Gudmundsson 1977). At lower concentration levels, neurological effects were not noted in an occupational cohort study (NIOSH 1976) or three human controlled trials (Putz-Anderson et al. 1981a, 1981b; Stewart et al. 1980). In animals, a range of neurological effects have been observed in rats, mice, and dogs, including clinical signs of neurotoxicity, motor impairments, and lesions in the cerebellum and spinal cord. Neurological effects were observed following inhalation exposure for acute durations (Burek et al. 1981; Chellman et al. 1986a, 1986b; Jiang et al. 1985; Landry et al. 1985; McKenna et al. 1981a; Morgan et al. 1982; Smith and von Oettingen 1947b; Wolkowski-Tyl et al. 1983a, 1983b), intermediate durations (McKenna et al. 1981b; Smith and von Oettingen 1947b), or chronic durations (CIIT 1981).

The study author conclusions in the principal study were critically evaluated in deriving the intermediate-duration inhalation MRL. McKenna et al. (1981b) concluded that the wire maneuver findings in female rats may represent a mild muscle weakness but did not attribute findings to chemical exposure because: (1) all groups showed decreased ability as time progressed (attributed to increased body weight), and (2) findings were not associated with any discernable neuromuscular incoordination or apparent neurological deficit in the current study, and (3) no “observable effects of a CNS or neuromuscular character” in rats exposed to concentrations up to 1,500 ppm by Mitchell et al. (1979). However, there are issues with each point of the argument made by McKenna et al. (1981b). First, no statistically significant or biologically relevant body weight effects were noted in exposed female rats, compared to controls. Second, the lack of overt incoordination/deficit argument is considered invalid, as detailed sensorimotor testing is designed to identify subtle deficits not obvious in cage-side observations. Additionally, the study authors neglected to acknowledge or discuss the statistical changes in another sensorimotor test (hindlimb clasping), which found deficits in female rats at the highest exposure concentration. Lastly, Mitchell et al. (1979) only performed cage-side evaluations and did not conduct detailed sensorimotor testing; therefore, findings (or lack thereof) from that study are not directly comparable to the study by McKenna et al. (1981b). Taken together, impairments on the wire maneuver and hindlimb clasping tests provide evidence of sensorimotor dysfunction at ≥149 ppm that is considered toxicologically relevant, especially when considering consistent evidence of progressive dose- and duration-dependent motor impairments (particularly in the hind limbs) observed in other studies and species following inhalation exposure (e.g., Chellman et al. 1986b; Landry et al. 1985; Morgan et al. 1982; Smith and von Oettingen 1947b).

Agency Contact (Chemical Manager): Sam Keith, MS, CPH

## Chloromethane Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloromethane
CAS Numbers: | 74-87-3
Date: | September 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic
MRL: | 0.03 ppm (0.06 mg/m^3^)
Critical Effect: | Swelling and slight degeneration of axons in the spinal cord
Reference: | CIIT (1981)
Point of Departure: | LOAEL of 51 ppm; (LOAEL_HEC_: 9 ppm)
Uncertainty Factor: | 300
LSE Graph Key: | 60, 61
Species: | Rat

MRL Summary: A chronic-duration inhalation MRL of 0.03 ppm was derived for chloromethane based on neurotoxicity (swelling and degeneration of axons in the spinal cord) in mice exposed to concentrations ≥51 ppm for 18 or 24 months (6 hours/day, 5 days/week); no NOAEL was identified (CIIT 1981). The MRL is based on a LOAEL of 51 ppm, which was adjusted to continuous duration exposure and converted to a human equivalent concentration (LOAEL_HEC_) of 9 ppm and divided by a total uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans with dosimetric adjustments, and 10 for human variability).

Selection of the Critical Effect: Only one chronic-duration inhalation study evaluated potential adverse effects of chloromethane in rats and mice (CIIT 1981). Exposure-related nonneoplastic effects reported in this study included neurological effects in mice at ≥51 ppm; cardiovascular effects in mice at ≥224 ppm and rats at 997 ppm; body weight, hepatic, renal, and male reproductive effects in rats and mice at 997 ppm; and decreased survival and spleen effects in mice at 997 ppm. Of these effects, the most sensitive (neurotoxicity) was selected as the critical effect.

Selection of the Principal Study: The chronic mouse study (CIIT 1981) was selected as the principal study because it provides the lowest POD for the critical effect (neurotoxicity).

Summary of the Principal Study:

CIIT. 1981. Final report on a chronic inhalation toxicology study in rats and mice exposed to methyl chloride. Battelle-Columbus Laboratories. Submitted to the U.S. Environmental Protection Agency under section 4. 40-8120717. OTS0511310.

CIIT (1981) exposed groups of B6C3F1 mice (117–123/sex/group) to chloromethane in whole-body inhalation exposure chambers at target concentrations of 0 (control), 50, 225, or 1,000 ppm, 6 hours/day, 5 days/week for up to 24 months. Analytically measured concentrations were 0, 51, 224, and 997 ppm, respectively. Animals were checked twice daily for mortality, morbidity, and clinical signs of toxicity. Body weights were measured prior to exposure, weekly for the first 6 months, and biweekly thereafter. Neurofunctional assessments were conducted after 18 and 24 months of exposure, including posture and gait analysis, facial tone, and reflexes. Ophthalmological examinations were performed prior to exposure and within a week of scheduled sacrifice. Groups of animals were sacrificed at 6 months (9–11/sex/group), 12 (10/sex/group), 18 (5–10/sex/group), or 24 months (all surviving animals) after the initial exposure and underwent gross necropsy. At sacrifice, blood was collected for hematology and clinical chemistry analysis and urine was collected for urinalysis. Weights were recorded for the lungs, heart, brain, liver, kidneys, and gonads. A complete set of tissues was examined for histopathological changes from all animals at scheduled sacrifice or were sacrificed/died prematurely.

The number of unscheduled deaths was increased in both males (78%) and females (61%) at 997 ppm, compared to control (63 and 28%, respectively). Body weights were decreased at 997 ppm by 15–18% by 12 months; however, body weight effects were not noted in surviving animals at 18 or 24 months. Clinical signs of neurotoxicity (tremor, paralysis) were seen in both sexes, along with abnormal functional test neurological results (restricted use of rear legs, abnormal gait, poor extensor thrust, leg rigidity) at 997 ppm. No exposure-related changes in ophthalmology or hematology were observed. Clinical chemistry findings were restricted to increased serum ALT in at 12 and 18 months at 997 ppm (not assessed at 24 months due to 100% mortality). Exposure-related changes in organ weight included increased absolute and/or relative heart weight in female mice at 997 ppm after 18 months and at 224 ppm at 24 months, and increased absolute and relative liver weight in females at 997 ppm after 18 months. Histopathological findings identified the CNS as a sensitive target of toxicity. Axonal swelling and degenerative changes of minimal severity were observed in the spinal cord nerves, cauda equina, and dorsal root in the spinal cord at ≥51 ppm after exposure for ≥18 months. In the brain, minimal-to-moderate degeneration of the cerebellar granule cell neurons was observed at 997 ppm after exposure for ≥18 months. Table A-4 provides a summary of neurological effects observed in the chronic exposure study by CIIT (1981). Other exposure-related nonneoplastic findings at 997 ppm following exposure for ≥18 months included hepatic lesions (centrilobular degeneration, karyomegaly, and cytomegaly), renal tubule hyperplasia, testicular seminiferous tubule degeneration and atrophy, splenic atrophy, and lymphoid depletion of the spleen and thymus. Carcinogenic findings included renal cortex adenocarcinomas and metastatic fibrosarcoma in the lungs of male mice at 997 ppm.

Table A-4 Summary of Neurological Effects Observed in Mice Following Chronic-Duration Inhalation Exposure to Chloromethane

Concentration (ppm) | Effect
51 | Swelling and degeneration of axons in the spinal cord; 18 months: 4/5 males, 10/10 females
224 | Swelling and degeneration of axons in the spinal cord; 18 months: 5/5 male, 10/10 females
997 | Tremor and paralysis; Swelling and degeneration of axons in the spinal cord; 18 months: 3/7 males; no data on females; 24 months: 13/18 females; Minimal-to-mild degeneration of cerebellar granule cell neurons; 18–24 months: 45/47 males, 35/37 females (minimal-to-moderate)

Source: CIIT 1981

Selection of the Point of Departure for the MRL: The LOAEL of 51 ppm for neurological effects in the study by CIIT (1981) was selected as the POD. Given that the data do not show a monotonic graded-dose response (Table A-4), BMD modeling was not used to derive this MRL.

Adjustment for Intermittent Exposure: The LOAEL was adjusted from intermittent exposure to account for a continuous exposure scenario:

L O A E L_A D J_ = L O A E L × (6 h o u r s)/(24 h o u r s) × (5 days)/(7 days) = 51 p p m × (6 h o u r s)/(24 h o u r s) × (5 days)/(7 days) = 9 p p m

The HEC was calculated by multiplying the duration-adjusted LOAEL by the default ratio of 1 for air:blood partition coefficient for humans and rats (partition coefficient values are not available for chloromethane):

L O A E L_H E C_ = L O A E L_A D J_ × ((H B / g)_A_)/((H B / g)_H_) = 9 p p m × 1 = 9 p p m

Where:

((H B / g)_A_)/((H B / g)_H_) = the blood : air partition coefficient ratio for animal (a) to human (h)

Uncertainty factors used in MRL derivation: The following uncertainty factors were then applied to the LOAEL_HEC_ to derive the MRL.

- 10 for use of a LOAEL
- 3 for extrapolation from animals to humans with dosimetric adjustments
- 10 for human variability

Subsequently, the MRL becomes:

M R L = (L O A E L_H E C_)/(U F s) = (9 p p m)/(300) = 0.03 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that neurological effects are a presumed health effect following inhalation exposure to chloromethane based on a low level of evidence from human studies and a high level of evidence from animal studies (see Appendix C).

There are shortcomings of the CIIT (1981) study that were considered in deriving the chronic-duration inhalation MRL. Specifically, some of the females were initially mis-sexed and placed in male cages. These animals were kept in their originally assigned cages for the study duration. Still, all animals received their assigned dose, regardless of sex. Therefore, this is unlikely to be of consequence to the study results. In addition, 4 months after the beginning of the study, mice from the 50-ppm group were accidentally exposed to 1,000 ppm, and 1,000 ppm group mice were accidentally exposed to 50 ppm for 3 days at 5.5 hours/day. CIIT (1981) acknowledged that this was a serious mistake but concluded that the mistake did not affect the validity of the results of the study, given the length of the dosing regimen. Additionally, no neurological effects were recorded at either 50 or 1,000 ppm at 6 months, so there appears to be little effect of this error on the results of the study. Therefore, ATSDR has concluded that CIIT (1981) is adequate to inform a chronic-duration inhalation MRL that provides appropriate public health protection. In contrast, EPA (2001) opted to base the chronic reference concentration (RfC) on Landry et al. (1985) due to concerns over procedural errors in CIIT (1981) and cerebellar lesions and mortality at lower administered concentrations in Landry et al. (1985) compared to CIIT (1981), suggesting increased sensitivity C57BL/6 mice, compared to B6C3F1 mice. However, it is not consistent with ATSDR guidance to use an acute-duration study (e.g., Landry et al. 1985) to inform a chronic-duration MRL. Of note, the chronic MRL of 0.03 ppm (0.06 mg/m^3^) based on spinal cord lesions reported in the chronic study by CIIT (1981) is comparable to the chronic RfC of 0.09 mg/m^3^ based on the acute study by Landry et al. (1985).

Agency Contact (Chemical Manager): Sam Keith, MS, CPH

## Chloromethane Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloromethane
CAS Numbers: | 74-87-3
Date: | September 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: The database for deriving an acute-duration oral MRL is inadequate. The only identified study evaluating oral exposure to chloromethane was an acute-duration gavage study in which the hepatotoxic effects of chloroform, carbon tetrachloride, dichloroethane, and chloromethane were compared in rats (Reynolds and Yee 1967). In this study, no exposure-related histopathological changes were observed in rats exposed to a single dose of 420 mg/kg; no additional endpoints were evaluated. Due to the limited scope of this study and the lack of exposure-related effects, this study is not considered appropriate for derivation of an acute-duration oral MRL.

Agency Contact (Chemical Manager): Sam Keith, MS, CPH

## Chloromethane Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloromethane
CAS Numbers: | 74-87-3
Date: | September 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: No intermediate-duration oral studies were located for chloromethane. Subsequently, no MRL is proposed.

Agency Contact (Chemical Manager): Sam Keith, MS, CPH

## Chloromethane Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloromethane
CAS Numbers: | 74-87-3
Date: | September 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: No chronic-duration oral studies were located for chloromethane. Subsequently, no MRL is proposed.

Agency Contact (Chemical Manager): Sam Keith, MS, CPH