# CHAPTER 8 REFERENCES

Abbassi R, Chamkhia N, Sakly M. 2010. Chloroform-induced oxidative stress in rat liver: Implication of metallothionein. Toxicol Indust Health 26(8):487–496. 10.1177/0748233710373088.
Abraham MH, Ibrahim A. 2006. Air to fat and blood to fat distribution of volatile organic compounds and drugs: linear free energy analyses. Eur J Med Chem 41(12):1430–1438. 10.1016/j.ejmech.2006.07.012.16996652
Abraham MH, Ibrahim A, Acree WE. 2005. Air to blood distribution of volatile organic compounds: a linear free energy analysis. Chem Res Toxicol 18(5):904–911. 10.1021/tx050066d.15892585
Abraham MH, Ibrahim A, Acree WE. 2006. Air to brain, blood to brain and plasma to brain distribution of volatile organic compounds: linear free energy analyses. Eur J Med Chem 41(4):494–502. 10.1016/j.ejmech.2006.01.004.16516353
Ade P, Guastadisegni C, Testai E, 1994. Multiple activation of chloroform in kidney microsome from male and female DBA/2J mice. J Biochem Toxicol 9(6):289–295.7891364
Aelion CM, Conte BC. 2004. Susceptibility of residential wells to VOC and nitrate contamination. Environ Sci Technol 38(6):1648–1653. 10.1021/es030401p.15074670
Aggazzotti G, Fantuzzi G, Righi E, 1993. Chloroform in alveolar air of individuals attending indoor swimming pools. Arch Environ Health 48(4):250–254.8357275
Aggazzotti G, Fantuzzi G, Righi E, 1995. Environmental and biological monitoring of chloroform in indoor swimming pools. J Chromatogr 710(1):181–190. 10.1016/0021-9673(95)00432-m.
Aggazzotti G, Fantuzzi G, Righi E, 1998. Blood and breath analyses as biological indicators of exposure to trihalomethanes in indoor swimming pools. Sci Total Environ 217(1–2):155–163. 10.1016/s0048-9697(98)00174-0.9695179
Ago M, Hayashi T, Ago K, 2011. Two fatalities associated with chloroform inhalation. Variation of toxicological and pathological findings. Leg Med 13(3):156–160. 10.1016/j.legalmed.2011.01.002.
Ahmadpour E, Halle S, Valois I, 2022. Temporal and spatial variations in the levels of prominent airborne disinfection by-products at four indoor swimming pools. J Occup Environ Hyg 19(4):185–196. 10.1080/15459624.2022.2035741.35119975
Ahmed AE, Kubic VL, Anders MW. 1977. Metabolism of haloforms to carbon monoxide. I. In vitro studies. Drug Metab Dispos 5:198–204.15814
Ahn J, Rao G, Mamun M, 2020. Soil–air partitioning of volatile organic compounds into soils with high water content. Environ Chem 17(8):545–557. 10.1071/en20032.
Aiking H, van Acker MB, Scholten RJPM, 1994. Swimming pool chlorination: A health hazard? Toxicol Lett 72(1–3):375–380. 10.1016/0378-4274(94)90051-5.7911264
Allan AR, Blackmore RC, Toseland PA. 1988. A chloroform inhalation fatality-an unusual asphyxiation. Med Sci Law 28(2):120–122. 10.1177/002580248802800207.3386458
Allen BC, Covington TR, Clewell HJ. 1996. Investigation of the impact of pharmacokinetic variability and uncertainty on risks predicted with a pharmacokinetic model for chloroform. Toxicology 111(1–3):289–303. 10.1016/0300-483x(96)03383-5.8711743
Ammann P, Laethem CL, Kedderis GL. 1998. Chloroform-induced cytolethality in freshly isolated male B6C3F1 mouse and F-344 rat hepatocytes. Toxicol Appl Pharmacol 149(2):217–225. 10.1006/taap.1997.8351.9571991
Anand SS, Mehendale HM. 2004. Liver regeneration: a critical toxicodynamic response in predictive toxicology. Environ Toxicol Chem 18(2):149–160. 10.1016/j.etap.2004.02.011.
Anand SS, Murthy SN, Vaidya VS, 2003. Tissue repair plays pivotal role in final outcome of liver injury following chloroform and allyl alcohol binary mixture. Food Chem Toxicol 41(8):1123–1132. 10.1016/s0278-6915(03)00066-8.12842180
Anand SS, Murthy SN, Mumtaz MM, 2004. Dose-dependent liver tissue repair in chloroform plus thioacetamide acute hepatotoxicity. Environ Toxicol Chem 18(2):143–148. 10.1016/j.etap.2004.02.010.
Anand SS, Mumtaz MM, Mehendale HM. 2005a. Dose-dependent liver tissue repair after chloroform plus trichloroethylene binary mixture. Basic Clin Pharmacol Toxicol 96(6):436–444. 10.1111/j.1742-7843.2005.pto_06.x.15910407
Anand SS, Mumtaz MM, Mehendale HM. 2005b. Dose-dependent liver regeneration in chloroform, trichloroethylene and allyl alcohol ternary mixture hepatotoxicity in rats. Arch Toxicol 79(11):671–682. 10.1007/s00204-005-0675-3.15940471
Anand SS, Philip BK, Palkar PS, 2006. Adaptive tolerance in mice upon subchronic exposure to chloroform: Increased exhalation and target tissue regeneration. Toxicol Appl Pharmacol 213(3):267–281. 10.1016/j.taap.2006.02.007.16630638
Andelman JB. 1985a. Human exposures to volatile halogenated organic chemicals in indoor and outdoor air. Environ Health Perspect 62:313–318.4085436
Andelman JB. 1985b. Inhalation exposure in the home to volatile organic contaminants of drinking water. Sci Total Environ 47:443–460.4089611
Anders MW, Stevens JL, Sprague RW, 1978. Metabolism of haloforms to carbon monoxide. II. In vivo studies. Drug Metab Dispos 6:556–560.30605
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson TA, Beauchamp JJ, Walton BT. 1991. Fate of volatile and semivolatile organic chemicals in soils: Abiotic versus biotic losses. J Environ Qual 20(2):420–424.
Antoine SR, DeLeon IR, O’Dell-Smith RM. 1986. Environmentally significant volatile organic pollutants in human blood. Bull Environ Contam Toxicol 36:364–371.3955247
Araki A, Kamigaito N, Sasaki T, 2004. Mutagenicity of carbon tetrachloride and chloroform in Salmonella typhimurium TA98, TA100, TA1535, and TA1537, and Escherichia coli WP2uvrA/pKM101 and WP2/pKM101, using a gas exposure method. Environ Mol Mutagen 43(2):128–133. 10.1002/em.20005.14991753
Aranyi C, O’Shea WJ, Graham JA, 1986. The effects of inhalation of organic chemical air contaminants on murine lung host defenses. Fundam Appl Toxicol 6(4):713–720. 10.1016/0272-0590(86)90184-3.3519345
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry. Fed Reg 54(173):37618–37634. https://archives.federalregister.gov/issue_slice/1989/9/11/37613-37634.pdf#page=6. February 21, 2023.
ATSDR. 2016. Evaluating vapor intrusion pathways: Guidance for ATSDR’s Division of Community Health Investigations. Agency for Toxic Substances and Disease Registry. https://stacks.cdc.gov/view/cdc/79266. April 17, 2024.
ATSDR. 2022a. Toxicological profile for 1,1-dichloroethene. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/ToxProfiles/tp39.pdf. May 4, 2023.
ATSDR. 2022b. Sanders2015 HLCs used in SHOWER Model v3 and PHAST. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/pha-guidance/toolbox/ATSDR_SHOWER_Model_v3_0_0.zip. May 15, 2023.
ATSDR. 2022c. Chloroform. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/SPL/resources/index.html. June 21, 2023.
Auttachoat W, Germolec DR, Collins BJ, 2009. Immunotoxicological profile of chloroform in female B6C3F1 mice when administered in drinking water. Drug Chem Toxicol 32(1):77–87. 10.1080/01480540802433880.19514942
AWWA Disinfection Committee. 2021. Emerging trends in disinfection: Lessons from AWWA's Disinfection Survey. J Am Water Works Assoc 113(1):20–28. 10.1002/awwa.1648.35936109
Aylward LL, Kirman CR, Blount BC, 2010. Chemical-specific screening criteria for interpretation of biomonitoring data for volatile organic compounds (VOCs)-application of steady-state PBPK model solutions. Regul Toxicol Pharmacol 58(1):33–44. 10.1016/j.yrtph.2010.05.011.20685286
Baeder C, Hofmann T. 1988. Initial submission: Inhalation embryotoxicity study of chloroform in Wistar rats with cover letter dated 072492. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8E. OTS0544564. 88–920005781. 8EHQ-0792–7135. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0544564.xhtml. February 21, 2023.
Baines CJ, McKeown-Eyssen GE, Riley N, 2004. Case-control study of multiple chemical sensitivity, comparing haematology, biochemistry, vitamins and serum volatile organic compound measures. Occup Med 54(6):408–418. 10.1093/occmed/kqh083.
Balster RL, Borzelleca JF. 1982. Behavioral toxicity of trihalomethane contaminants of drinking water in mice. Environ Health Perspect 46:127–136. 10.1289/ehp.8246127.7151753
Ban M, Langonné I, Huguet N, 2006. Inhaled chemicals may enhance allergic airway inflammation in ovalbumin-sensitised mice. Toxicology 226(2–3):161–171. 10.1016/j.tox.2006.06.012.16879906
Barkley J, Bunch J, Bursey JT, 1980. Gas chromatography mass spectrometry computer analysis of volatile halogenated hydrocarbons in man and his environment. A multimedia environmental study. Biomed Mass Spectrom 7:130–147.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessment. Regul Toxicol Pharmacol 8:471–486.3222488
Barnes D, Fitzgerald PA, Swan HB. 1989. Catalysed formation of chlorinated organic materials in waters. Water Sci Technol 21(2):59–63.
Barrows ME, Petrocelli SR, Macek KJ, 1980. Bioconcentration and elimination of selected water pollutants by bluegill sunfish (Lepomis macrochirus). In: Haque R, ed. Dynamics, exposure and hazard assessment of toxic chemicals. Ann Arbor, MI: Ann Arbor Science, 379–392.
Basak S, Mills D, El-Masri HA, 2004. Predicting blood:air partition coefficients using theoretical molecular descriptors. Environ Toxicol Pharmacol 16(1–2):45–55. 10.1016/j.etap.2003.09.002.21782693
Batterman S, Zhang L, Wang S, 2002. Partition coefficients for the trihalomethanes among blood, urine, water, milk and air. Sci Total Environ 284(1–3):237–247. 10.1016/s0048-9697(01)00890-7.11846168
Bayer CW, Black MS, Galloway LM. 1988. Sampling and analysis techniques for trace volatile organic emissions from consumer products. J Chromatogr Sci 26(4):168–173.3379122
Bean RM, Thomas BL, Neitzel DA. 1985. Analysis of sediment matter for halogenated products from chlorination of power plant cooling water. In: Proceedings of the 5^th^ water chlorination conference. Chelsea, MI: Lewis Publishers, Inc., 1357–1370.
Béliveau M, Krishnan K. 2000a. Estimation of rat blood:air partition coefficients of volatile organic chemicals using reconstituted mixtures of blood components. Toxicol Lett 116(3):183–188. 10.1016/s0378-4274(00)00219-8.10996479
Béliveau M, Krishnan K. 2000b. Concentration dependency of rat blood: air partition coefficients of some volatile organic chemicals. J Toxicol Environ Health 60(6):377–389. 10.1080/00984100050033467.
Béliveau M, Charest-Tardif G, Krishnan K. 2001. Blood:air partition coefficients of individual and mixtures of trihalomethanes. Chemosphere 44(3):377–381. 10.1016/s0045-6535(00)00203-4.11459142
Benoit FM, Jackson R. 1987. Trihalomethane formation in whirlpool spas. Water Res 21(3):353–357.
Berger D, Vischer TL, Micheli A. 1983. Induction of proteolytic activity in serum by treatment with amniotic detergents and organic solvents. Experientia 39:1109–1111.6194011
Berry MR, Johnson LS, Brenner KP, 1997. Dietary characterizations in a study of human exposures in the Lower Rio Grande Valley: Part II. Household waters. Environ Int 23(5):693–703. 10.1016/S0160-4120(97)00070-6.
Bexfield LM, Belitz K, Fram MS, 2022a. Volatile organic compounds in groundwater used for public supply across the United States: Occurrence, explanatory factors, and human-health context. Sci Total Environ 827:154313. 10.1016/j.scitotenv.2022.154313.35257755
Bexfield LM, Belitz K, Fram MS, 2022b. Supplemental material: Volatile organic compounds in groundwater used for public supply across the United States: Occurrence, explanatory factors, and human-health context. Sci Total Environ 827 10.1016/j.scitotenv.2022.154313.
Bogen KT, Keating GA. 2000. Dermal absorption from short-term exposure to contaminated water. IAHS Publication 260:101–110.
Bomski H, Sobolewaka A, Strakowski A. 1967. [Toxic damage of the liver by chloroform in chemical industry workers]. Int Arch Arbeitsmed 24(2):127–134. 10.1007/BF00369015. (German)5603624
Bonou SG, Levallois P, Giguere Y, 2017. Prenatal exposure to drinking-water chlorination by-products, cytochrome P450 gene polymorphisms and small-for-gestational-age neonates. Reprod Toxicol 73:75–86. 10.1016/j.reprotox.2017.07.019.28774688
Boobis AR. 2009. Mode of action considerations in the quantitative assessment of tumour responses in the liver. Basic Clin Pharmacol Toxicol 106(3):173–179. 10.1111/j.1742-7843.2009.00505.x.20030633
Borgert CJ, Wise K, Becker RA. 2015. Modernizing problem formulation for risk assessment necessitates articulation of mode of action. Regul Toxicol Pharmacol 72(3):538–551. 10.1016/j.yrtph.2015.04.018.25929618
Botton J, Kogevinas M, Gracia-Lavedan E, 2015. Postnatal weight growth and trihalomethane exposure during pregnancy. Environ Res 136:280–288. 10.1016/j.envres.2014.09.035.25460647
Boublik T, Fried V, Hala E. 1984. Trichloromethane. In: The vapor pressures of pure substances: Selected values of the temperature dependence of the vapor pressures of some pure substances in the normal and low-pressure region. Vol. 17. Amsterdam, Netherlands: Elsevier Scientific Publications, 34–35.
Bouwer EJ, McCarty PL. 1983. Transformations of 1- and 2-carbon halogenated aliphatic organic compounds under methanogenic conditions. Appl Environ Microbial 45(4):1286–1294. 10.1128/aem.45.4.1286-1294.1983.
Bouwer EJ, Rittman B, McCarty PL. 1981a. Anaerobic degradation of halogenated 1- and 2-carbon organic compounds. Environ Sci Technol 15(5):596–599. 10.1021/es00087a012.22283955
Bouwer EJ, McCarty PL, Lance JC. 1981b. Trace organic behavior in soil columns during rapid infiltration of secondary wastewater. Water Res 15:151–159.
Bowman FJ, Borzelleca JF, Munson AE. 1978. The toxicity of some halomethanes in mice. Toxicol Appl Pharmacol 44(1):213–215. 10.1016/0041-008X(78)90300-9.675691
Branchflower RV, Nunn DS, Highet RJ, 1984. Nephrotoxicity of chloroform: Metabolism to phosgene by the mouse kidney. Toxicol Appl Pharmacol 72:159–168.6143425
Breider F, Albers CN, Hunkeler D. 2013. Assessing the role of trichloroacetyl-containing compounds in the natural formation of chloroform using stable carbon isotopes analysis. Chemosphere 90(2):441–448. 10.1016/j.chemosphere.2012.07.058.22925426
Brennan RJ, Schiestl RH. 1998. Chloroform and carbon tetrachloride induce intrachromosomal recombination and oxidative free radicals in Saccharomyces cerevisiae. Mutat Res 397(2):271–278. 10.1016/s0027-5107(97)00225-x.9541652
Brill MJ, Diepstraten J, van Rongen A, 2012. Impact of obesity on drug metabolism and elimination in adults and children. Clin Pharmacokinet 51(5):277–304. 10.2165/11599410-000000000-00000.22448619
Brown BR, Sipes IG, Sagalyn AM. 1974a. Mechanisms of acute hepatic toxicity: chloroform, halothane, and glutathione. Anesthesiology 41(6):554–561. 10.1097/00000542-197412000-00005.4433055
Brown DM, Langley PF, Smith D, 1974b. Metabolism of chloroform. I. The metabolism of 14C-chloroform by different species. Xenobiotica 4:151–163.
Bruchard W, Bajracharya A, Johnston NAC. 2023. Volatile organic compound emissions from disinfectant usage in the home and office. Environ Health Perspect 131(4):47701. 10.1289/EHP11916.37126655
Bull RJ, Brown JM, Meierhenry EA, 1986. Enhancement of the hepatotoxicity of chloroform in B6C3F1 mice by corn oil: Implications for chloroform carcinogenesis. Environ Health Perspect 69:49–58. 10.1289/ehp.866949.3816736
Bunge AL, Cleek RL, Vecchia BE. 1995. A new method for estimating dermal absorption from chemical exposure. 3. Compared with steady-state methods for prediction and data analysis. Pharm Res 12(7):972–982. 10.1023/a:1016298012408.7494817
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: a review of past Agency for Toxic Substances and Disease Registry public health evaluations. J Environ Health 75(9):36–41.
Burke AS, Redeker K, Kurten RC, 2007. Mechanisms of chloroform-induced hepatotoxicity: oxidative stress and mitochondrial permeability transition in freshly isolated mouse hepatocytes. J Toxicol Environ Health 70(22):1936–1945. 10.1080/15287390701551399.
Burkhalter JE, Balster RL. 1979. Behavioral teratology evaluation of trichloromethane in mice. Neurobehav Toxicol 1(3):199–205.551313
Butler TC. 1961. Reduction of carbon tetrachloride in vivo and reduction of carbon tetrachloride and chloroform in vitro by tissues and tissue constituents. J Pharmacol Exp Ther 134:311–319.13875205
Butterworth BE, Templin MV, Constan AA, 1998. Long-term mutagenicity studies with chloroform and dimethylnitrosamine in female lacI transgenic B6C3F1 mice. Environ Mol Mutagen 31(3):248–256. 10.1002/(sici)1098-2280(1998)31:3<248::aid-em6>3.0.co;2-g.9585263
Byard RW, Kostakis C, Pigou PE, 2000. Volatile substance use in sexual asphyxia. J Clin Forensic Med 7(1):26–28. 10.1054/jcfm.2000.0356.16083645
Cai Z, Mehendale HM. 1991. Hepatotoxicity and lethality of halomethanes in Mongolian gerbils pretreated with chlordecone, phenobarbital or mirex. Arch Toxicol 65(3):204–212. 10.1007/BF02307310.1711308
Caldwell KK, Harris RA. 1985. Effects of anesthetic and anticonvulsant drugs on calcium-dependent efflux of potassium from human erythrocytes. Eur J Pharmacol 107:119–125.3979423
Callahan CL, Stewart PA, Friesen MC, 2018. Case-control investigation of occupational exposure to chlorinated solvents and non-Hodgkin's lymphoma. Occup Environ Med 75(6):415–420. 10.1136/oemed-2017-104890.29588333
Callen DF, Wolf CR, Philpot RM. 1980. Cytochrome p-450 mediated genetic activity and cytotoxicity of seven halogenated aliphatic hydrocarbons in Saccharomyces cerevisiae. Mutat Res 77:55–63.6767185
Cammann K, Hübner K. 1995. Trihalomethane concentrations in swimmers’ and bath attendants’ blood and urine after swimming or working in indoor swimming pools. Arch Environ Health 50(1):61–65.7717770
Cantor KP, Hoover R, Mason TJ, 1978. Associations of cancer mortality with halomethanes in drinking water. J Natl Cancer Inst 61(4):979–985. 10.1093/jnci/61.4.979.702538
Cao XL, Sparling M, Dabeka R. 2024. Chloroform in food samples from 2014 Canadian total diet study: occurrence and dietary exposure. Food Addit Contam Part A Chem Anal Control Expo Risk Assess 41(2):143–150. 10.1080/19440049.2024.2302098.38193981
Cao WC, Zeng Q, Luo Y, 2016. Blood biomarkers of late pregnancy exposure to trihalomethanes in drinking water and fetal growth measures and gestational age in a Chinese cohort. Environ Health Perspect 124(4):536–541. 10.1289/ehp.1409234.26340795
Carla V, Moroni F. 1992. General anaesthetics inhibit the responses induced by glutamate receptor agonists in the mouse cortex. Neurosci Lett 146(1):21–24.1282227
Caro J, Gallego M. 2008. Alveolar air and urine analyses as biomarkers of exposure to trihalomethanes in an indoor swimming pool. Environ Sci Technol 42(13):5002–5007. 10.1021/es800415p.18678040
Carrasco-Turigas G, Villanueva CM, Goni F, 2013. The effect of different boiling and filtering devices on the concentration of disinfection by-products in tap water. J Environ Public Health 2013:959480. 10.1155/2013/959480.23476675
CDC. 2022a. Blood trichloromethane (chloroform) (2011–2018). National report on human exposure to environmental chemicals. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/data_tables.html January 26, 2023.
CDC. 2022b. Blood trichloromethane (chloroform) in smokers (2013–2016); Blood trichloromethane (chloroform) in non-smokers (2013–2016). National report on human exposure to environmental chemicals. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/data_tables.html. January 26, 2023.
Chaidou CI, Georgakilas VI, Stalikas C, 1999. Formation of chloroform by aqueous chlorination of organic compounds. Chemosphere 39(4):587–594. 10.1016/s0045-6535(99)00124-1.10422249
Challen PJR, Hickish DE, Bedford J. 1958. Chronic chloroform intoxication. Br J Ind Med 15(4):243–249. 10.1136/oem.15.4.243.13596546
Chen YJ, Duan P, Meng TQ, 2020. Associations of blood trihalomethanes with semen quality among 1199 healthy Chinese men screened as potential sperm donors. Environ Int 134:105335. 10.1016/j.envint.2019.105335.31783240
Chen Y, Qian Y, An D, 2024. Potential disinfection byproducts-related risks to drinking water? Molecular insights into the dissolved organic matter from photodegradation of polyethylene microplastics. ACS EST Water 4(1):217–226. 10.1021/acsestwater.3c00549.
Chenoweth MB, Robertson DN, Erley DS, 1962. Blood and tissue levels of ether, chloroform, halothane and methoxyflurane in dogs. Anesthesiology 23:101–106.13878671
Chinery RL, Gleason AK. 1993. A compartmental model for the prediction of breath concentration and absorbed dose of chloroform after exposure while showering. Risk Anal 13(1):51–62.8451460
Chiou WL. 1975. Quantitation of hepatic and pulmonary first-pass effect and its implications in pharmacokinetic study. I. Pharmacokinetics of chloroform in man. J Pharmacokinet Biopharm 3:193–201.1159623
Choi SH, Lee SW, Hong YS, 2006. Diagnostic radiopacity and hepatotoxicity following chloroform ingestion: a case report. Emerg Med J 23(5):394–395. 10.1136/emj.2005.027466.16627845
Christensen KY, Vizcaya D, Richardson H, 2013. Risk of selected cancers due to occupational exposure to chlorinated solvents in a case-control study in Montreal. J Occup Environ Med 55(2):198–208. 10.1097/JOM.0b013e3182728eab.23147555
Chu I, Villeneuve DC, Secours VE, 1982a. Trihalomethanes: II. Reversibility of toxicological changes produced by chloroform, bromodichloromethane, chlorodibromomethane and bromoform in rats. J Environ Sci Health B 17(3):225–240. 10.1080/03601238209372315.7096899
Chu I, Villeneuve DC, Secours VE, 1982b. Toxicity of trihalomethanes: I. The acute and subacute toxicity of chloroform, bromodichloromethane, chlorodibromomethane and bromoform in rats. J Environ Sci Health B 17(3):205–224. 10.1080/03601238209372314.7096898
Cianflone DJ, Hewitt WR, Villeneuve DC, 1980. Role of biotransformation in the alterations of chloroform hepatotoxicity produced by Kepone and mirex. Toxicol Appl Pharmacol 53:140–149.6155715
Clark CS, Meyer CR, Gartside PS, 1982. An environmental health survey of drinking water contamination by leachate from a pesticide waste dump in Hardemena County, Tennessee. Arch Environ Health 37:9–18.7059235
Class T, Ballschmidter K. 1986. Chemistry of organic traces in air. VI. Distribution of chlorinated Cl-C4-hydrocarbons in air over the northern and southern Atlantic Ocean. Chemosphere 15(4):413–427.
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Clewell HJ, Tan YM, Campbell JL, 2008. Quantitative interpretation of human biomonitoring data. Toxicol Appl Pharmacol 231(1):122–133. 10.1016/j.taap.2008.04.021.18589468
Coffin JC, Ge R, Yang S, 2000. Effect of trihalomethanes on cell proliferation and DNA methylation in female B6C3F1 mouse liver. Toxicol Sci 58(2):243–252. 10.1093/toxsci/58.2.243.11099637
Cohen EN, Hood N. 1969. Application of low-temperature autoradiography to studies of the uptake and metabolism of volatile anesthetics in the mouse. Anesthesiology 30:306–314.5778099
Colman J, Rice GE, Wright JM, 2011. Identification of developmentally toxic drinking water disinfection byproducts and evaluation of data relevant to mode of action. Toxicol Appl Pharmacol 254(2):100–126. 10.1016/j.taap.2011.02.002.21296098
Comba ME, Palabrica VS, Kaiser KLE. 1994. Volatile halocarbons as tracers of pulp mill effluent plumes. Environ Toxicol Chem 13(7):1065–1074.
Conolly RB, Butterworth BE. 1995. Biologically based dose response model for hepatic toxicity: a mechanistically based replacement for traditional estimates of noncancer risk. Toxicol Lett 82–83:901–906. 10.1016/0378-4274(95)03528-1.
Constan AA, Sprankle CS, Peters JM, 1999. Metabolism of chloroform by cytochrome P450 2E1 is required for induction of toxicity in the liver, kidney, and nose of male mice. Toxicol Appl Pharmacol 160(2):120–126. 10.1006/taap.1999.8756.10527910
Corley RA, Mendrala AL, Smith FA, 1990. Development of a physiologically based pharmacokinetic model for chloroform. Toxicol Appl Pharmacol 103:512–527.2339423
Corley RA, Gordon SM, Wallace LA. 2000. Physiologically based pharmacokinetic modeling of the temperature-dependent dermal absorption of chloroform by humans following bath water exposures. Toxicol Sci 53(1):13–23. 10.1093/toxsci/53.1.13.10653516
Corsi RL, Chang DPY, Schroeder ED, 1987. Modeling the emissions of volatile and potentially toxic organic compounds from municipal wastewater treatment plants. In: Proceedings of the 80th annual meeting of the Air Pollution Control Association, June 21–26, 1987 New York, New York. New York: Air Pollution Control Association, 87–95a.85.
Costet N, Garlantezec R, Monfort C, 2011. Environmental and urinary markers of prenatal exposure to drinking water disinfection by-products, fetal growth, and duration of gestation in the PELAGIE birth cohort (Brittany, France, 2002–2006). Am J Epidemiol 175(4):263–275. 10.1093/aje/kwr419.22156019
Crebelli R, Benigni R, Franekic J, 1988. Induction of chromosome malsegregation by halogenated organic solvents in Aspergillus nidulans: Unspecified or specified mechanism? Mutat Res 201:401–411.3050490
Crebelli R, Andreoli C, Carere A, 1995. Toxicology of halogenated aliphatic hydrocarbons: structural and molecular determinants for the disturbance of chromosome segregation and the induction of lipid peroxidation. Chem Biol Interact 98(2):113–129. 10.1016/0009-2797(95)03639-3.8548852
Crume RV, Ryan WM, Peters TA, 1990. Risk analysis on air from groundwater aeration. J Water Poll Control Fed 62:119–123.
Cui SQ, Tao YM, Jian TZ, 2022. An incident of chloroform poisoning on a university campus. World J Emerg Med 13(2):155–157. 10.5847/wjem.j.1920-8642.2022.028.35237374
Culliford D, Hewitt HB. 1957. The influence of sex hormone status on the susceptibility of mice to chloroform-induced necrosis of the renal tubules. J Endocrinol 14:381–393.13398532
da Silva ML, Charest-Tardif G, Krishnan K, 1999. Influence of oral administration of a quaternary mixture of trihalomethanes on their blood kinetics in the rat. Toxicol Lett 106(1):49–57. 10.1016/s0378-4274(99)00022-3.10378450
da Silva ML, Charest-Tardif G, Krishnan K, 2000. Evaluation of the pharmacokinetic interactions between orally administered trihalomethanes in the rat. J Toxicol Environ Health 60(5):343–353. 10.1080/00984100050030127.
Daft JA. 1988. Rapid determination of fumigant and industrial chemical residues in food. J Assoc Off Anal Chem 71:748–760.3417594
Daft JA. 1989. Determination of fumigants and related chemicals in fatty and non-fatty foods. J Agric Food Chem 37:560–564.
Danielsson BRG, Ghantous H, Dencker L. 1986. Distribution of chloroform and methyl chloroform and their metabolites in pregnant mice. Biol Res Pregnancy 7:77–83.
Davis ME. 1992. Dichloroacetic acid and trichloroacetic acid increase chloroform toxicity. J Toxicol Environ Health 37(1):139–148.1522607
Davis ME, Bemdt WO. 1992. Sex differences in monochloroacetate pretreatment effects on chloroform toxicity in rats. Fundam Appl Toxicol 18(1):66–71.1601211
Davison MH. 1959. The evolution of anaesthesia. Br J Anaesth 30(10):495–504. 10.1093/bja/30.10.495.
de Best JH, Salminen E, Doddema HJ, 1998. Transformation of carbon tetrachloride under sulfate reducing conditions. Biodegradation 8(6):429–436. 10.1023/a:1008262225760.
de Castro Medeiros L, de Alencar FLS, Navoni JA, 2019. Toxicological aspects of trihalomethanes: a systematic review. Environ Sci Pollut Res Int 26(6):5316–5332. 10.1007/s11356-018-3949-z.30607849
de Groot H, Noll T. 1989. Halomethane hepatotoxicity: induction of lipid peroxidation and inactivation of cytochrome P-450 in rat liver microsomes under low oxygen partial pressures. Toxicol Appl Pharmacol 97(3):530–537. 10.1016/0041-008x(89)90258-5.2609348
de Oliveira TH, Campos KK, Soares NP, 2015. Influence of sexual dimorphism on pulmonary inflammatory response in adult mice exposed to chloroform. Int J Toxicol 34(3):250–257. 10.1177/1091581815580172.25870144
De Serres FJ, Hoffmann GR, von Borstel J, 1981. Summary report on the performance of yeast assays. Prog Mutat Res 1:67–76.
DeAngelo AB, Geter DR, Rosenberg DW, 2002. The induction of aberrant crypt foci (ACF) in the colons of rats by trihalomethanes administered in the drinking water. Cancer Lett 187(1–2):25–31. 10.1016/s0304-3835(02)00356-7.12359347
DeJongh J, Verhaar HJ, Hermens JL. 1997. A quantitative property-property relationship (QPPR) approach to estimate in vitro tissue-blood partition coefficients of organic chemicals in rats and humans. Arch Toxicol 72(1):17–25. 10.1007/s002040050463.9458186
Delic JI, Lilly PD, MacDonald AJ, 2000. The utility of PBPK in the safety assessment of chloroform and carbon tetrachloride. Regul Toxicol Pharmacol 32(2):144–155. 10.1006/rtph.2000.1419.11067771
Dell'Aglio DM, Sutter ME, Schwartz MD, 2010. Acute chloroform ingestion successfully treated with intravenously administered N-acetylcysteine. J Med Toxicol 6(2):143–146. 10.1007/s13181-010-0071-0.20552315
Deml E, Oesterle D. 1985. Dose-dependent promoting activity of chloroform in rat liver foci bioassay. Cancer Lett 29:59–63.2866029
Deringer MK, Dunn TB, Heston WE. 1953. Results of exposure of strain C3H mice to chloroform. Proc Soc Exp Biol Med 83(3):474–479. 10.3181/00379727-83-20389.13088880
Derricott CE, Knight EA, Acree WE, 2015. Using water-solvent systems to estimate in vivo blood-tissue partition coefficients. Chem Cent J 9:58. 10.1186/s13065-015-0134-z.26478743
Deshon HD. 1979. Carbon tetrachloride. In: Grayson M, Eckroth D, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 5. 3^rd^ ed. New York, NY: John Wiley and Sons, 693–703.
Dettling A, Stadler K, Eisenbach C, 2016. Systemic inflammatory response due to chloroform intoxication-an uncommon complication. Int J Legal Med 130(2):401–404. 10.1007/s00414-015-1156-8.25676899
Dewalle FB, Chian ESK. 1981. Detection of trace organics in well water near a solid waste landfill. J Am Water Works Assoc 73:206–211.
DHA. 2022. Real-time neurobehavioral effects of single and combined chemical exposures via inhalation in rats. Defense Health Agency, Research and Development Directorate (J-9) Restoral Program. AD1156482. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/AD1156482.xhtml. May 8, 2024.
Dick D, Ng KM, Sauder DN, 1995. In vitro and in vivo percutaneous absorption of 14C-chloroform in humans. Hum Exp Toxicol 14(3):260–265. 10.1177/096032719501400305.7779456
Dilling W. 1977. Interphase transfer processes. II. Evaporation rates of chloromethanes, ethanes, ethylenes, propanes, and propylenes from dilute aqueous solution. Comparisons with theoretical predictions. Environ Sci Technol 11:405–409.
Dilling WL, Tefertiller NB, Kallos GJ. 1975. Evaporation rates of methylene chloride, chloroform, 1,1,1-trichloroethane, trichloroethylene, tetrachloroethylene, and other chlorinated compounds in dilute aqueous solutions. Environ Sci Technol 9(9):833–838.
Dimitriades B, Joshi SB. 1977. Application of reactivity criteria in oxidant-related emission control in the USA. In: International conference on photochemical oxidant pollution and its control. Research Triangle Park, NC: U.S. Environmental Protection Agency. 705–712. EPA600377001B. PB264233. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB264233.xhtml. February 21, 2023.
Dix KJ, Kedderis GL, Borghoff SJ. 1997. Vehicle-dependent oral absorption and target tissue dosimetry of chloroform in male rats and female mice. Toxicol Lett 91(3):197–209. 10.1016/s0378-4274(97)00023-4.9217240
Do MT, Birkett NJ, Johnson KC, 2005. Chlorination disinfection by-products and pancreatic cancer risk. Environ Health Perspect 113(4):418–424. 10.1289/ehp.7403.15811832
Docks EL, Krishna G. 1976. The role of glutathione in chloroform-induced hepatotoxicity. Exp Mol Pathol 24:13–22.1253933
Dodds L, King WD. 2001. Relation between trihalomethane compounds and birth defects. Occup Environ Med 58(7):443–446. 10.1136/oem.58.7.443.11404448
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 6, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
Donat-Vargas C, Kogevinas M, Castano-Vinyals G, 2023. Long-term exposure to nitrate and trihalomethanes in drinking water and prostate cancer: A multicase-control study in Spain (MCC-Spain). Environ Health Perspect 131(3):37004. 10.1289/EHP11391.36883836
Donat-Vargas C, Kogevinas M, Benavente Y, 2024. Lifetime exposure to brominated trihalomethanes in drinking water and swimming pool attendance are associated with chronic lymphocytic leukemia: a Multicase-Control Study in Spain (MCC-Spain). J Expo Sci Environ Epidemiol 34(1):47–57. 10.1038/s41370-023-00600-7.37726507
Doring HJ. 1975. Reversible and irreversible forms of contractile failure caused by disturbances by general anesthetics in myocardial ATP utilization. In: Fleckenstein A, Dhalla NS, eds. Recent advances in studies on cardiac structure and metabolism: Basic functions of cations in myocardial activity. Vol. 5. Baltimore, MD: University Park Press, 395–403.
Dorman DC, Miller KL, D'Antonio A, 1997. Chloroform-induced olfactory mucosal degeneration and osseous ethmoid hyperplasia are not associated with olfactory deficits in Fischer 344 rats. Toxicology 122(1–2):39–50. 10.1016/s0300-483x(97)00076-0.9274800
DOT. 1980. Chemical kinetic and photochemical data sheets for atmospheric reactions. Washington, DC: U.S. Department of Transportation. ADA091631. https://apps.dtic.mil/sti/pdfs/ADA091631.pdf. February 21, 2023.
Doyle TJ, Zheng W, Cerhan JR, 1997. The association of drinking water source and chlorination by-products with cancer incidence among postmenopausal women in Iowa: a prospective cohort study. Am J Public Health 87(7):1168–1176. 10.2105/ajph.87.7.1168.9240108
Du J, Liu D, Zhang Z, 2024. Comparative effectiveness of sequential and synergistic (VUV/)UV and chlorine disinfection on DBPs and humic acid reduction. Sep Purif Technol 335:126083. 10.1016/j.seppur.2023.126083.
Dunnick JK, Melnick RL. 1993. Assessment of the carcinogenic potential of chlorinated water: experimental studies of chlorine, chloramine, and trihalomethanes. J Natl Cancer Inst 85(10):817–822. 10.1093/jnci/85.10.817.8487327
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants of the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38.
Ekstrom T, Warholm M, Kronevi T, 1988. Recovery of malondialdehyde in urine as a 2,4-dinitrophenylhydrazine derivative after exposure to chloroform or hydroquinone. Chem Biol Interact 67:25–31.3168081
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
El-Shenawy NS, Abdel-Rahman MS. 1993. Evaluation of chloroform cardiotoxicity utilizing a modified isolated rat cardiac myocytes. Toxicol Lett 69(3):249–256.8212065
Enhorning G, Potoschnik R, Possmayer F, 1986. Pulmonary surfactant films affected by solvent vapors. Anesth Analg 65:1275–1280.3777456
EPA. 1978. Teratology and acute toxicology of selected chemical pesticides administered by inhalation. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600178003. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91013F9I.txt. February 21, 2023.
EPA. 1980. Effects of chloroform in the drinking water of rats and mice: Ninety-day subacute toxicity study. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600180030. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100SIV9.txt. February 21, 2023.
EPA. 1982. Volatile organic chemicals in the atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600S383027. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000TMEP.txt. February 20, 2023.
EPA. 1985a. Health assessment document for chloroform. Washington, DC: U.S. Environmental Protection Agency. PB86105004. EPA600884004F. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100RB9S.txt. February 21, 2023.
EPA. 1985b. Survey of chloroform emission sources. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA450385026. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000JE7F.txt. February 21, 2023.
EPA. 1986. Guidelines for carcinogen risk assessment. U.S. Environmental Protection Agency. EPA630R000049. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=54933. June 29, 2021.
EPA. 1987. Volatile organic chemicals in 10 public-access buildings. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB87191607. EPA600D87152. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB87191607.xhtml. February 21, 2023.
EPA. 1988a. Land disposal restrictions for third scheduled wastes; final rule. U.S. Environmental Protection Agency. Fed Reg 53(159):31138–31145.
EPA. 1988b. National ambient volatile organic compounds (VOCS) database update. U.S. Environmental Protection Agency. PB88195631. EPA600388010a. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88195631.xhtml. February 21, 2023.
EPA. 1988c. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. PB88179874. EPA600687008. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=500022JL.txt. February 21, 2023.
EPA. 1989. Land disposal restrictions for third scheduled wastes; proposed rule. 40 CFR Parts 148, 261, 264, 265,268, and 271. U.S. Environmental Protection Agency. Fed Reg 54:48372–48396.
EPA. 1990a. Removal and fate of RCRA and CERCLA toxic organic pollutants in wastewater treatment. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600S289026. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000TM68.txt. February 20, 2023.
EPA. 1990b. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency. EPA600890066A. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001JXM.txt. February 21, 2023.
EPA. 1994. Methods for derivation inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. PB2000100284. EPA600890066F. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2000100284.xhtml. February 20, 2023.
EPA. 1995. Method 551.1. Determination of chlorination disinfection byproducts, chlorinated solvents, and halogenated pesticides/herbicides in drinking water by liquid-liquid chromatography with electron-capture detection. Revision 1. Cincinnati, OH: U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2015-06/documents/epa-551.1.pdf. January 26, 2023.
EPA. 1996. Proposed guidelines for carcinogen risk assessment. U.S. Environmental Protection Agency. EPA600P92003C. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=55868. June 29, 2021.
EPA. 2005. Guidelines for carcinogen risk assessment. U.S. Environmental Protection Agency. EPA630P03001F. https://www.epa.gov/sites/default/files/2013-09/documents/cancer_guidelines_final_3–25-05.pdf. June 29, 2021.
EPA. 2012. Vapor intrusion database. U.S. Environmental Protection Agency. https://www.epa.gov/vaporintrusion/vapor-intrusion-database. February 6, 2023.
EPA. 2014. Method 8021B: Revision 3: aromatic and halogenated volatiles by gas chromatography using photoionization and/or electrolytic conductivity detectors. U.S. Environmental Protection Agency. SW-846 Update V. https://www.epa.gov/sites/default/files/2015-12/documents/8021b.pdf. January 26, 2023.
EPA. 2016. Vapor intrusion screening level calculator. U.S. Environmental Protection Agency. https://www.epa.gov/vaporintrusion. May 8, 2024.
EPA. 2018a. Method 8260D: Volatile organic compounds by gas chromatography/mass spectrometry. U.S. Environmental Protection Agency. SW-846. https://www.epa.gov/sites/default/files/2018-06/documents/method_8260d_update_vi_final_06–11-2018.pdf. February 21, 2023.
EPA. 2018b. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018c. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018d. About acute exposure guideline levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2022. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2023a. 2020 CDR data. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data#2020. October 26, 2022.
EPA. 2023b. Chloroform. Pesticide product and label system. U.S. Environmental Protection Agency. https://ordspub.epa.gov/ords/pesticides/f?p=113:6:::::P6_ACTIVE_INACTIVE:9. January 12, 2023.
EPA. 2023c. Inert use information | InertFinder | pesticides. U.S. Environmental Protection Agency. https://ordspub.epa.gov/ords/pesticides/f?p=INERTFINDER:1::::1. February 20, 2023.
EPA. 2023d. Annual summary data: chloroform. AQS: Concentration by monitor. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/airdata/download_files.html. January 16, 2023.
EPA. 2023e. National primary drinking water regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141. https://www.govinfo.gov/content/pkg/CFR-2023-title40-vol25/pdf/CFR-2023-title40-vol25-part141.pdf. May 3, 2024.
EPA. 2023f. 2020 National emission inventory (NEI) data: Chloroform. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2020-national-emissions-inventory-nei-data. May 8, 2024.
Eschenbrenner AB, Miller E. 1945. Induction of hepatomas in mice by repeated oral administration of chloroform, with observations on sex differences. J Natl Cancer Inst 5:251–255. 10.1093/jnci/5.4.251.
Evans MV, Eklund CR, Williams DN, 2020. Global optimization of the Michaelis-Menten parameters using physiologically-based pharmacokinetic (PBPK) modeling and chloroform vapor uptake data in F344 rats. Inhal Toxicol 32(3):97–109. 10.1080/08958378.2020.1742818.32241199
Ewaid SH, Abed SA, Al-Ansari N. 2020. Acute toxicity of the water chlorination byproduct (chloroform) in male mice. AIP Conf Proceed 2290(1):020007. 10.1063/5.0027353.
Fan VS, Savage RE, Buckley TJ. 2007. Methods and measurements for estimating human dermal uptake of volatile organic compounds and for deriving dermal permeability coefficients. Toxicol Mech Methods 17(5):295–304. 10.1080/15376510601017801.20020953
Fang C, Behr M, Xie F, 2008. Mechanism of chloroform-induced renal toxicity: non-involvement of hepatic cytochrome P450-dependent metabolism. Toxicol Appl Pharmacol 227(1):48–55. 10.1016/j.taap.2007.10.014.18031782
Farrow P. 1984. Death by chloroform. Police J 57(4):347–355. 10.1177/0032258X8405700406.
FDA. 2023. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.govinfo.gov/content/pkg/CFR-2023-title21-vol2/pdf/CFR-2023-title21-vol2-sec165-110.pdf. May 3, 2024.
FDA. 2024a. Chloroform. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/index.cfm?set=FoodSubstances&id=CHLOROFORM. May 3, 2024.
FDA. 2024b. Part 175. Indirect food additives: Adhesives and components of coatings. Subpart B. Substances for use only as components of adhesives. Sec. 175.105 Adhesives. Code of Federal Regulations. U.S. Food and Drug Administration. 21 CFR 175.105. https://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfCFR/CFRSearch.cfm?fr=175.105. July 25, 2024.
FDA. 2024c. Part 177. Indirect food additives: Polymers. Subpart B. Substances for use as basic components of single and repeated use food contact surfaces. Sec. 177.1580 Polycarbonate resins. Code of Federal Regulations. U.S. Food and Drug Administration. 21 CFR 177.1580. https://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfCFR/CFRSearch.cfm?fr=177.1580. July 25, 2024.
FDA. 2024d. Part 177. Indirect food additives: Polymers. Subpart B. Substances for use as basic components of single and repeated use food contact surfaces. Sec. 177.1585 Polyestercarbonate resins. Code of Federal Regulations. U.S. Food and Drug Administration. 21 CFR 177.1585. https://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfCFR/CFRSearch.cfm?fr=177.1585. July 25, 2024.
Featherstone HW. 1947. Chloroform. Anesthesiology 8:362–371.20255057
Feingold A, Holaday DA. 1977. The pharmacokinetics of metabolism of inhalation anaesthetics: A simulation study. Br J Anaesth 49:155–162.836747
Ferrario JB, Lawler GC, DeLeon IR, 1985. Volatile organic pollutants in biota and sediments of Lake Pontchartrain. Bull Contam Toxicol 34(2):246–255.
Flanagan RJ, Pounder DJ. 2010. A chloroform-related death: analytical and forensic aspects. Forensic Sci Int 197(1–3):89–96. 10.1016/j.forsciint.2009.12.061.20071113
Fleming-Jones ME, Smith RE. 2003. Volatile organic compounds in foods: a five year study. J Agric Food Chem 51(27):8120–8127. 10.1021/jf0303159.14690406
Florentin A, Hautemaniere A, Hartemann P. 2011. Health effects of disinfection by-products in chlorinated swimming pools. Int J Hyg Environ Health 214(6):461–469. 10.1016/j.ijheh.2011.07.012.21885333
Font-Ribera L, Kogevinas M, Zock JP, 2010. Short-term changes in respiratory biomarkers after swimming in a chlorinated pool. Environ Health Perspect 118(11):1538–1544. 10.1289/ehp.1001961.20833607
Font-Ribera L, Gracia-Lavedan E, Aragones N, 2018. Long-term exposure to trihalomethanes in drinking water and breast cancer in the Spanish multicase-control study on cancer (MCC-SPAIN). Environ Int 112:227–234. 10.1016/j.envint.2017.12.031.29289867
Fry BJ, Taylor R, Hathaway DE. 1972. Pulmonary elimination of chloroform and its metabolite in man. Arch Int Pharmacodyn 196:98–111.5059373
Gaillard Y, Masson-Seyer MF, Giroud M, 2006. A case of drug-facilitated sexual assault leading to death by chloroform poisoning. International Journal of Legal Medicine 120(4):241–245. 10.1007/s00414-005-0020-7.16059710
Gao Y, Zhang Y, Kamijima M, 2014. Quantitative assessments of indoor air pollution and the risk of childhood acute leukemia in Shanghai. Environ Pollut 187:81–89. 10.1016/j.envpol.2013.12.029.24463471
Gargas ML, Burgess RJ, Voisard DE, 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98(1):87–99. 10.1016/0041-008x(89)90137-3.2929023
Gearhart JM, Seckel C, Vinegar A. 1993. In vivo metabolism of chloroform in B6C3F1 mice determined by the method of gas uptake: the effects of body temperature on tissue partition coefficients and metabolism. Toxicol Appl Pharmacol 119(2):258–266.8480334
Gehring PJ. 1968. Hepatotoxic potency of various chlorinated hydrocarbon vapours relative to their narcotic and lethal potencies in mice. Toxicol Appl Pharmacol 13(3):287–298. 10.1016/0041-008X(68)90102-6.5726658
Gemma S, Vittozzi L, Testai E. 2003. Metabolism of chloroform in the human liver and identification of the competent P450s. Drug Metab Dispos 31(3):266–274. 10.1124/dmd.31.3.266.12584152
Geter DR, Chang LW, Hanley NM, 2004a. Analysis of in vivo and in vitro DNA strand breaks from trihalomethane exposure. J Carcinog 3(1):2. 10.1186/1477-3163-3-2.14969591
Geter DR, George MH, Moore TM, 2004b. The effects of a high animal fat diet on the induction of aberrant crypt foci in the colons of male F344/N rats exposed to trihalomethanes in the drinking water. Toxicol Lett 147(3):245–252. 10.1016/j.toxlet.2003.11.006.15104116
Gettler AO, Blume H. 1931. Chloroform in the brain, lungs, and liver. Quantitative recovery and determination. Arch Pathol 11:554–560.
Gibbons J, Laha S. 1999. Water purification systems: a comparative analysis based on the occurrence of disinfection by-products. Environ Pollut 106(3):425–428. 10.1016/s0269-7491(99)00097-4.15093038
Giusti GV, Chiarotti M. 1981. Double 'suicide' by chloroform in a pair of twins. Med Sci Law 21(1):2–3. 10.1177/002580248102100102.7194412
Gocke E, King MT, Eckhardt K, 1981. Mutagenicity of cosmetics ingredients licensed by the European Communities. Mutat Res 90:91–109.6799819
Gold LS, Stewart PA, Milliken K, 2011. The relationship between multiple myeloma and occupational exposure to six chlorinated solvents. Occup Environ Med 68(6):391–399. 10.1136/oem.2009.054809.20833760
Gomez MID, Castro JA. 1980. Nuclear activation of carbon tetrachloride and chloroform. Res Commun Chem Pathol Pharmacol 27:191–194.7361000
Goodman LS, Gilman A. 1980. Trichloroethylene and chloroform. In: The pharmacological basis of therapeutics. 6^th^ ed. New York, NY: MacMillan Publishing, 291–292, 1646.
Gopinath C, Ford EJH. 1975. The role of microsomal hydroxylases in the modification of chloroform and carbon tetrachloride. Toxicol Appl Pharmacol 63:281–291.
Gordon SM, Wallace LA, Pellizzari ED, 1988. Human breath measurements in a clean-air chamber to determine half-lives for volatile organic compounds. Atmos Environ 22:2165–2170.
Gordon SM, Wallace LA, Callahan PJ, 1998. Effect of water temperature on dermal exposure to chloroform. Environ Health Perspect 106(6):337–345. 10.1289/ehp.98106337.9618350
Gosselink MJ, Siegel AM, Suk E, 2012. A case of 'cybersuicide' attempt using chloroform. Gen Hosp Psychiatry 34(4):e7–8. 10.1016/j.genhosppsych.2012.01.001.22305368
Gossett JM. 1987. Measurement of Henry’s law constant for Cl and C2 chlorinated hydrocarbons. Environ Sci Technol 21:202–206.
Grazuleviciene R, Nieuwenhuijsen MJ, Vencloviene J, 2011. Individual exposures to drinking water trihalomethanes, low birth weight and small for gestational age risk: a prospective Kaunas cohort study. Environ Health 10:32. 10.1186/1476-069X-10-32.21501533
Grazuleviciene R, Kapustinskiene V, Vencloviene J, 2013. Risk of congenital anomalies in relation to the uptake of trihalomethane from drinking water during pregnancy. Occup Environ Med 70(4):274–282. 10.1136/oemed-2012-101093.23404756
Green T, Lee R, Toghill A, 2001. The toxicity of styrene to the nasal epithelium of mice and rats: studies on the mode of action and relevance to humans. Chem Biol Interact 137(2):185–202. 10.1016/s0009-2797(01)00236-8.11551533
Greene SC, White NR. 2014. Images in emergency medicine: Young woman with cardiac arrest. Defatting dermatitis as a result of chloroform exposure. Ann Emerg Med 64(3):231, 247. 10.1016/j.annemergmed.2013.11.015.25149963
Gron C, Laturnus F, Jacobsen OS. 2012. Reliable test methods for the determination of a natural production of chloroform in soils. Environ Monit Assess 184(3):1231–1241. 10.1007/s10661-011-2035-5.21487715
Gupta M, Gupta A, Suidan MT, 1996. Biotransformation rates of chloroform under anaerobic conditions. II. Sulfate reduction. Water Res 30:1387–1394.
Haddad S, Tardif GC, Tardif R. 2006. Development of physiologically based toxicokinetic models for improving the human indoor exposure assessment to water contaminants: trichloroethylene and trihalomethanes. J Toxicol Environ Health A 69(23):2095–2136. 10.1080/15287390600631789.17060096
Hajimiragha H, Ewers U, Jansen-Rosseck R, 1986. Human exposure to volatile halogenated hydrocarbons from the general environment. Int Arch Occup Environ Health 58:141–150.3744568
Hakim A, Jain AK, Jain R. 1992. Chloroform ingestion causing toxic hepatitis. J Assoc Physicians India 40(7):477.1484034
Harada K, Ichiyama T, Ikeda H, 1997. An autopsy case of acute chloroform intoxication after intermittent inhalation for years. Nihon Hoigaku Zasshi 51(4):319–323.9366139
Hard GC, Boorman GA, Wolf DC. 2000. Re-evaluation of the 2-year chloroform drinking water carcinogenicity bioassay in Osborne-Mendel rats supports chronic renal tubule injury as the mode of action underlying the renal tumor response. Toxicol Sci 53(2):237–244. 10.1093/toxsci/53.2.237.10696771
Harley KG, Calderon L, Nolan JES, 2021. Changes in Latina Women's exposure to cleaning chemicals associated with switching from conventional to "green" household cleaning products: The LUCIR Intervention Study. Environ Health Perspect 129(9):97001. 10.1289/EHP8831.34468180
Harris RA, Groh GI. 1985. Membrane disordering effects of anesthetics are enhanced by gangliosides. Anesthesiology 62:115–119.3918480
Harris RN, Ratnayake JH, Garry VF, 1982. Interactive hepatotoxicity of chloroform and carbon tetrachloride. Toxicol Appl Pharmacol 63:281–291.7089978
Harris RH, Highland JH, Rocricks JV, 1984. Adverse health effects at a Tennessee hazardous waste disposal site. Haz Waste 1:183–204.
Hartig S, Fries S, Balcarcel RR. 2005. Reduced mitochondrial membrane potential and metabolism correspond to acute chloroform toxicity of in vitro hepatocytes. J Appl Toxicol 25(4):310–317. 10.1002/jat.1067.16025433
Haydon DA, Requena J, Simon AJB. 1988. The potassium conductance of the resting squid axon and its blockage by clinical concentrations of general anaesthetics. J Physiol 402:363–374.3236243
Heavner DL, Morgan WT, Ogden MW. 1996. Determination of volatile organic compounds and respirable suspended particulate matter in New Jersey and Pennsylvania homes and workplaces. Environ Int 22(2):159–183. 10.1016/0160-4120(96)00003-7.
Heck JE, Park AS, Qiu J, 2013. An exploratory study of ambient air toxics exposure in pregnancy and the risk of neuroblastoma in offspring. Environ Res 127:1–6. 10.1016/j.envres.2013.09.002.24139061
Heck JE, Park AS, Qiu J, 2014. Risk of leukemia in relation to exposure to ambient air toxics in pregnancy and early childhood. International Journal of Hygiene and Environmental Health 217(6):662–668. 10.1016/j.ijheh.2013.12.003.24472648
Heilbrunn G, Liebert E, Szanto PB. 1945. Chronic chloroform poisoning: Clinical and pathologic report of a case. Arch Neurol Psych 53:68–72.
Henson JM, Yates MV, Cochran JW, 1988. Microbial removal of halogenated methanes, ethanes, and ethylenes in an aerobic soil exposed to methane. Fed Eur Microbial Sot Microbial Ecol 53:193–201.
Herren-Freund SL, Pereira MA. 1987. The carcinogenicity of organic chemicals found in drinking water. In: Proceedings, water quality technology conference: Portland, Oregon, November 16–20, 1986. American Water Works Association, 485–500.
Hertzberg RC, Teuschler LK, McDonald A, 2024. Evaluation of the interaction-based hazard index formula using data on four trihalomethanes from U.S. EPA's multiple-purpose design study. Toxics 12(5):305. 10.3390/toxics12050305.38787084
Hewitt WR, Brown EM. 1984. Nephrotoxic interactions between ketonic solvents and halogenated aliphatic chemicals. Fundam Appl Toxicol 4:902–908.6394413
Hewitt WR, Miyajima H, Cote MG, 1979. Acute alteration of chloroform-induced hepato- and nephrotoxicity by mirex and Kepone. Toxicol Appl Pharmacol 48:509–527.89712
Hewitt LA, Palmason C, Masson S, 1990. Evidence for the involvement of organelles in the mechanism of ketone-potentiated chloroform-induced hepatotoxicity. Liver 10:35–48.2308479
Heywood R, Sortwell RJ, Noel PRB, 1979. Safety evaluation of toothpaste containing chloroform. III. Long-term study in beagle dogs. J Environ Pathol Toxicol 2(3):835–851.422938
Hickey RF, Vanderwielen J, Switzenbaum MS. 1987. Effects of organic toxicants on methane production and hydrogen gas levels during the anaerobic digestion of waste activated sludge. Water Res 21(11):1417–1427.
Hinckley AF, Bachand AM, Reif JS. 2005. Late pregnancy exposures to disinfection by-products and growth-related birth outcomes. Environ Health Perspect 113(12):1808–1813. 10.1289/ehp.8282.16330369
Hoekstra EJ, Duyzer JH, Deleer EWB, 2001. Chloroform-concentration gradients in soil air and atmospheric air, and emission fluxes from soil. Atmos Environ 35:61–70.
Hoffman CS, Mendola P, Savitz DA, 2008. Drinking water disinfection by-product exposure and fetal growth. Epidemiology 19(5):729–737. 10.1097/EDE.0b013e3181812bd4.18633330
Hoigne J, Bader H. 1988. The formation of trichloronitromethane (chloropicrin) and chloroform in a combined ozonation/chlorination treatment of drinking water. Water Res 22(3):313–319.
Holbrook M. 2003. Chloroform. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 6. John Wiley & Sons, 279–290. 10.1002/0471238961.0308121508151202.a01.pub2.
Hooth MJ, McDorman KS, Hester SD, 2002. The carcinogenic response of Tsc2 mutant Long-Evans (Eker) rats to a mixture of drinking water disinfection by-products was less than additive. Toxicol Sci 69(2):322–331. 10.1093/toxsci/69.2.322.12377981
Howard MO, Bowen SE, Garland EL, 2011. Inhalant use and inhalant use disorders in the United States. Addict Sci Clin Pract 6(1):18–31.22003419
Hu K, Schwarz DW. 1987. Electrophysiological evaluation of chloroform-induced inner ear damage. Arch Otorhinolaryngol 244(4):222–228. 10.1007/bf00455310.3500704
Huang AT, Batterman S. 2009. Formation of trihalomethanes in foods and beverages. Food Addit Contam 26(7):947–957. 10.1080/02652030902897739.
Huang AT, Batterman S. 2010. Sorption of trihalomethanes in foods. Environ Int 36(7):754–762. 10.1016/j.envint.2010.05.014.20598747
Huang WC, Liu M, Zhang FG, 2022. Removal of disinfection byproducts and toxicity of chlorinated water by post-treatments of ultraviolet/hydrogen peroxide and ultraviolet/peroxymonosulfate. J Clean Prod 352:131563. 10.1016/j.jclepro.2022.131563.
Hubrich C, Stuhl F. 1980. The ultraviolet absorption of some halogenated methanes and ethanes of atmospheric interest. J Photochem 12:93–107.
Hunkeler D, Laier T, Breider F, 2012. Demonstrating a natural origin of chloroform in groundwater using stable carbon isotopes. Environ Sci Technol 46:6096–6101. 10.1021/es204585d.22554551
Hutchens KS, Kung M. 1985. "Experimentation" with chloroform. Am J Med 78(4):715–718. 10.1016/0002-9343(85)90421-8.3985046
Hwang JH, Kim JI. 2022. A case report of toxic hepatitis caused by chloroform in automotive parts manufacturer coating process. Ann Occup Environ Med 34:e22. 10.35371/aoem.2022.34.e22.36147588
IARC. 1979. Chloroform. In: IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Volume 20: Some halogenated hydrocarbons. Lyon, France: World Health Organization, 401–427. https://publications.iarc.fr/Book-And-Report-Series/Iarc-Monographs-On-The-Identification-Of-Carcinogenic-Hazards-To-Humans/Some-Halogenated-Hydrocarbons-1979. February 21, 2023.
IARC. 1999. Chloroform. IARC monographs on the evaluation of carcinogenic risks to humans. Volume 73. Some chemicals that cause tumours of the kidney or urinary bladder in rodents and some other substances. Lyon, France: International Agency for Research on Cancer. 131–182. https://publications.iarc.fr/91. May 26, 2021.
Ikatsu H, Nakajima T. 1992. Hepatotoxic interaction between carbon tetrachloride and chloroform in ethanol treated rats. Arch Toxicol 66(8):580–586.1463393
Ikatsu H, Shinoda S, Nakajima T. 1998. CYP2E1 Level in rat liver injured by the interaction between carbon tetrachloride and chloroform. J Occup Health 40(3):223–229. 10.1539/joh.40.223.
Ilett KF, Reid WD, Sipes IG, 1973. Chloroform toxicity in mice: Correlation of renal and hepatic necrosis with covalent binding of metabolites to tissue macromolecules. Exp Mol Pathol 19:215–229.4754791
Infante-Rivard C, Amre D, Sinnett D. 2002. GSTT1 and CYP2E1 polymorphisms and trihalomethanes in drinking water: effect on childhood leukemia. Environ Health Perspect 110(6):591–593. 10.1289/ehp.02110591.
Infante-Rivard C, Siemiatycki J, Lakhani R, . 2005. Maternal exposure to occupational solvents and childhood leukemia. Environ Health Perspect 113(6):787–792. 10.1289/ehp.7707.15929905
IRIS. 2001. Chloroform. CASRN 67–66-3. Integrated Risk Information System. Chemical assessment summary. U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0025_summary.pdf. May 26, 2021.
Isaacs KK, Evans MV, Harris TR. 2004. Visualization-based analysis for a mixed-inhibition binary PBPK model: determination of inhibition mechanism. J Pharmacokinet Pharmacodyn 31(3):215–242. 10.1023/b:jopa.0000039565.11358.94.15518245
Islam MS, Zhao L, McDougal JN, 1995. Uptake of chloroform by skin during short exposures to contaminated water. Risk Anal 15(3):343–352. 10.1111/j.1539-6924.1995.tb00327.x.7604168
Islam MS, Zhao L, Zhou J, 1996. Systemic uptake and clearance of chloroform by hairless rats following dermal exposure. I. Brief exposure to aqueous solutions. Risk Anal 16(3):349–357. 10.1111/j.1539-6924.1996.tb01469.x.8693161
Islam MS, Zhao L, Zhou J, 1999a. Systemic uptake and clearance of chloroform by hairless rats following dermal exposure: II. Absorption of the neat solvent. Am Ind Hyg Assoc J 60(4):438–443. 10.1080/00028899908984462.10462777
Islam MS, Zhao L, McDougal JN, 1999b. Uptake of chloroform by skin on brief exposures to the neat liquid. Am Ind Hyg Assoc J 60(1):5–15. 10.1080/00028899908984417.10028612
Iszatt N, Nieuwenhuijsen MJ, Bennett J, 2013. Chlorination by-products in tap water and semen quality in England and Wales. Occup Environ Med 70(11):754–760. 10.1136/oemed-2012-101339.23759536
Ito Y, Lind RC, Begay CK, 2000. Late administration of dimethyl sulfoxide minimizes the hepatic microvascular inflammatory response to chloroform in rats. Hepatol Res 18(3):203–217. 10.1016/s1386-6346(00)00068-1.11058825
Jakobson I, Wahlberg JE, Holmberg B, 1982. Uptake via the blood and elimination of 10 organic solvents following epicutaneous exposure of anesthetized guinea pigs. Toxicol Appl Pharmacol 63:181–187.7089968
Jan CR, Chen LW, Lin MW. 2000. Ca(2+) mobilization evoked by chloroform in Madin-Darby canine kidney cells. J Pharmacol Exp Ther 292(3):995–1001.10688615
Jayaweera D, Islam S, Gunja N, 2017. Chloroform ingestion causing severe gastrointestinal injury, hepatotoxicity and dermatitis confirmed with plasma chloroform concentrations. Clin Toxicol 55(2):147–150. 10.1080/15563650.2016.1249795.
Jeffers PM, Ward LM, Woytowitch LM, 1989. Homogenous hydrolysis rate constants for selected chlorinated methanes, ethanes, ethenes, and propanes. Environ Sci Technol 23:967–969.
Jenkins A, Greenblatt EP, Faulkner HJ, 2001. Evidence for a common binding cavity for three general anesthetics within the GABAA receptor. J Neurosci 21(6):RC136. 10.1523/JNEUROSCI.21-06-j0002.2001.11245705
Jia C, Yu X, Masiak W. 2012. Blood/air distribution of volatile organic compounds (VOCs) in a nationally representative sample. Sci Total Environ 419:225–232. 10.1016/j.scitotenv.2011.12.055.22285084
Jiao J, Zheng T, Lan Q, 2012. Occupational solvent exposure, genetic variation of DNA repair genes, and the risk of non-Hodgkin's lymphoma. Eur J Cancer Prev 21(6):580–584. 10.1097/CEJ.0b013e328351c762.22430443
Jo WK, Weisel CP, Lioy PJ. 1990. Routes of chloroform exposure and body burden from showering with chlorinated tap water. Risk Anal 10(4):575–580.2287784
Johansson JS. 1997. Binding of the volatile anesthetic chloroform to albumin demonstrated using tryptophan fluorescence quenching. J Bio Chem 272(29):17961–17965. 10.1074/jbc.272.29.17961.9218421
Jones WM, Margolis G, Stephen CR. 1958. Hepatotoxicity of inhalation anesthetic drugs. Anesthesiology 19(6):715–723. 10.1097/00000542-195811000-00001.13595250
Jones RR, DellaValle CT, Weyer PJ, 2019. Ingested nitrate, disinfection by-products, and risk of colon and rectal cancers in the Iowa Women's Health Study cohort. Environ Int 126:242–251. 10.1016/j.envint.2019.02.010.30822653
Jorgenson TA, Meierhenry EF, Rushbrook CJ, 1985. Carcinogenicity of chloroform in drinking water to male Osborne-Mendel rats and female B6C3F1 mice. Fundam Appl Toxicol 5(4):760–769. 10.1016/0272-0590(85)90200-3.4043598
Kanada M, Miyagawa M, Sato M, 1994. Neurochemical profile of effects of 28 neurotoxic chemicals on the central nervous system in rats (1) effects of oral administration on brain contents of biogenic amines and metabolites. Ind Health 32:145–164.7698903
Kanan A, Selbes M, Karanfil T. 2015. Occurrence and formation of disinfection by-products in indoor U.S. swimming pools. ACS Symp Ser 1190:405–430. 10.1021/bk-2015-1190.ch021.
Kaneko T, Wang P, Sato A. 2000. Relationship between blood/air partition coefficients of lipophilic organic solvents and blood triglyceride levels. Toxicology 143(2):203–208. 10.1016/s0300-483x(99)00170-5.10755706
Kang YJ, Ahn J, Hwang YI. 2014. Acute liver injury in two workers exposed to chloroform in cleanrooms: a case report. Ann Occup Environ Med 26(1):49. 10.1186/s40557-014-0049-5.25411642
Kargalioglu Y, McMillan BJ, Minear RA, 2002. Analysis of the cytotoxicity and mutagenicity of drinking water disinfection by-products in Salmonella typhimurium. Teratog Carcinog Mutagen 22(2):113–128. 10.1002/tcm.10010.11835289
Kasai T, Nishizawa T, Arito H, 2002. Acute and subchronic inhalation toxicity of chloroform in rats and mice. J Occup Health 44(4):193–202. 10.1539/joh.44.193.
Kasso WV, Wells MR. 1981. A survey of trihalomethanes in the drinking water system of Murfreesboro, Tennessee, USA. Bull Environ Contam Toxicol 27:295–302.7028190
Kaufman JA, Wright JM, Evans A, 2018. Associations between disinfection by-product exposures and craniofacial birth defects. J Occup Environ Med 60(2):109–119. 10.1097/jom.0000000000001191.29023340
Kaufman JA, Wright JM, Evans A, 2020. Disinfection by-product exposures and the risk of musculoskeletal birth defects. Environ Epidemiol 4(1):e081. 10.1097/ee9.0000000000000081.32154492
Kawamura K, Kaplan IR. 1983. Organic compounds in the rainwater of Los Angeles. Environ Sci Technol 17:497–501.22283170
Keegan TE, Simmons JE, Pegram RA. 1998. NOAEL and LOAEL determinations of acute hepatotoxicity for chloroform and bromodichloromethane delivered in an aqueous vehicle to F344 rats. J Toxicol Environ Health 55(1):65–75. 10.1080/009841098158629.
Kerger BD, Suder DR, Schmidt CE, 2005. Airborne exposure to trihalomethanes from tap water in homes with refrigeration-type and evaporative cooling systems. J Toxicol Environ Health A 68(6):401–429. 10.1080/15287390590903577.15799243
Khallef M, Cenkci S, Akyil D, 2018. Ames and random amplified polymorphic DNA tests for the validation of the mutagenic and/or genotoxic potential of the drinking water disinfection by-products chloroform and bromoform. J Environ Sci Health A Toxic Hazard Subst Environ Eng 53(2):154–159. 10.1080/10934529.2017.1383134.
Kim H. 2008. A case of acute toxic hepatitis after suicidal chloroform and dichloromethane ingestion. Am J Emerg Med 26:1073.e1073–1073.e1076. 10.1016/j.ajem.2008.03.050.
Kim NY, Park SW, Suh JK. 1996. Two fatal cases of dichloromethane or chloroform poisoning. J Forensic Sci 41(3):527–529.8656200
Kimura ET, Ebert DM, Dodge PW. 1971. Acute toxicity and limits of solvent residue for sixteen organic solvents. Toxicol Appl Pharmacol 19(4):699–704. 10.1016/0041-008x(71)90301-2.5132037
King RB. 1993. Topical aspirin in chloroform and the relief of pain due to herpes zoster and postherpetic neuralgia. Arch Neural 50:1046–1053.
King WD, Dodds L, Allen AC. 2000. Relation between stillbirth and specific chlorination by-products in public water supplies. Environ Health Perspect 108(9):883–886. 10.1289/ehp.00108883.
King WD, Dodds L, Armson BA, 2004. Exposure assessment in epidemiologic studies of adverse pregnancy outcomes and disinfection byproducts. J Expo Anal Environ Epidemiol 14(6):466–472. 10.1038/sj.jea.7500345.15026776
Kirkland DJ, Smith KL, Van ANJ. 1981. Failure of chloroform to induce chromosome damage or sister-chromatid exchanges in cultured human lymphocytes and failure to induce reversion in Escherichia coli. Food Cosmet Toxicol 19:651–656.6273272
Klaunig JE, Ruth RJ, Pereira MA. 1986. Carcinogenicity of chlorinated methane and ethane compounds administered in drinking water to mice. Environ Health Perspect 69:89–95.3816740
Kohr RM. 1990. Suicide by chloroform ingestion following self-mutilation. Am J Forensic Med Pathol 11(4):324–328. 10.1097/00000433-199012000-00012.2275471
Kramer MD, Lynch CF, Isacson P, 1992. The association of waterborne chloroform with intrauterine growth retardation. Epidemiology 3(5):407–413. 10.1097/00001648-199209000-00005.1391132
Kundu B, Richardson SD, Granville CA, 2004. Comparative mutagenicity of halomethanes and halonitromethanes in Salmonella TA100: structure-activity analysis and mutation spectra. Mutat Res 554(1–2):335–350. 10.1016/j.mrfmmm.2004.05.015.15450430
Kutob SD, Plaa GL. 1962. The effect of acute ethanol intoxication on chloroform-induced liver damage. J Pharmacol Exp Ther 135:245–251.14460945
La Merrill M, Birnbaum LS. 2011. Childhood obesity and environmental chemicals. Mt Sinai J Med 78(1):22–48. 10.1002/msj.20229.21259261
Land PC, Owen EL, Linde HW. 1981. Morphologic changes in mouse spermatozoa after exposure to inhalation anesthetics during early spermatogenesis. Anesthesiology 54:53–56. 10.1097/00000542-198101000-00010.6109470
Landauer MR, Lynch MR, Balster RL, 1982. Trichloromethane-induced taste aversions in mice. Neurobehav Toxicol Teratol 4(3):305–309.7099349
Landi S, Naccarati A, Ross MK, 2003. Induction of DNA strand breaks by trihalomethanes in primary human lung epithelial cells. Mutat Res 538(1–2):41–50. 10.1016/s1383-5718(03)00086-x.12834753
LaRegina J, Bozzelli JW, Harkov R, 1986. Volatility organic compounds at hazardous waste sites and a sanitary landfill in New Jersey. An up-to-date review of the present situation. Environ Prog 5:18–27.
Larson JL, Wolf DC, Butterworth BE. 1993. Acute hepatotoxic and nephrotoxic effects of chloroform in male F-344 rats and female B6C3F1 mice. Fundam Appl Toxicol 20(3):302–315. 10.1006/faat.1993.1040.8504904
Larson JL, Sprankle CS, Butterworth BE. 1994a. Lack of chloroform-induced DNA repair in vitro and in vivo in hepatocytes of female B6C3F1 mice. Environ Mol Mutagen 23(2):132–136.8143701
Larson JL, Wolf DC, Butterworth BE. 1994b. Induced cytotoxicity and cell proliferation in the hepatocarcinogenicity of chloroform in female B6C3F1 mice: comparison of administration by gavage in corn oil vs ad libitum in drinking water. Fundam Appl Toxicol 22(1):90–102. 10.1006/faat.1994.1012.8125218
Larson JL, Wolf DC, Morgan KT, 1994c. The toxicity of 1-week exposures to inhaled chloroform in female B6C3F1 mice and male F-344 rats. Fundam Appl Toxicol 22(3):431–446. 10.1006/faat.1994.1049.8050638
Larson JL, Wolf DC, Butterworth BE. 1994d. Induced cytolethality and regenerative cell proliferation in the livers and kidneys of male B6C3F1 mice given chloroform by gavage. Fundam Appl Toxicol 23(4):537–543. 10.1006/faat.1994.1138.7867905
Larson JL, Wolf DC, Butterworth BE. 1995a. Induced regenerative cell proliferation in livers and kidneys of male F-344 rats given chloroform in corn oil by gavage or ad libitum in drinking water. Toxicology 95(1–3):73–86. 10.1016/0300-483x(94)02886-y.7825192
Larson JL, Wolf DC, Méry S, 1995b. Toxicity and cell proliferation in the liver, kidneys and nasal passages of female F-344 rats, induced by chloroform administered by gavage. Food Chem Toxicol 33(6):443–456. 10.1016/0278-6915(95)00013-r.7797172
Larson JL, Templin MV, Wolf DC, 1996. A 90-day chloroform inhalation study in female and male B6C3F1 mice: implications for cancer risk assessment. Fundam Appl Toxicol 30(1):118–137. 10.1006/faat.1996.0049.8812250
Laturnus F, Lauritsen FR, Grøn C. 2000. Chloroform in a pristine aquifer system: Toward an evidence of biogenic origin. Water Resour Res 36(10):2999–3009. 10.1029/2000wr900194.
Laturnus F, Haselmann KF, Borch T, 2002. Terrestrial natural sources of trichloromethane (chloroform, CHCl3) - an overview. Biogeochemistry 60:121–139.
Le Curieux F, Gauthier L, Erb F, 1995. Use of the SOS chromotest, the Ames-fluctuation test and the newt micronucleus test to study the genotoxicity of four trihalomethanes. Mutagenesis 10(4):333–341. 10.1093/mutage/10.4.333.7476270
Lee H, Bae HC, Kim J, 2015. Chloroform upregulates early growth response-1-dependent thymic stromal lymphopoietin expression via the JNK and ERK pathways in human keratinocytes. Int J Dermatol 54(12):e521–526. 10.1111/ijd.12946.26474944
Lehmann KB, Flury FF. 1943. Chlorinated hydrocarbons. In: Lehman KB, Flury FF, eds. Toxicology and hygiene of industrial solvents. Baltimore, MD: Williams and Wilkins, 138–145, 191–196.
Levallois P, Gingras S, Marcoux S, 2012. Maternal exposure to drinking-water chlorination by-products and small-for-gestational-age neonates. Epidemiology 23(2):267–276. 10.1097/EDE.0b013e3182468569.22317810
Lévesque B, Ayotte P, LeBlanc A, 1994. Evaluation of dermal and respiratory chloroform exposure in humans. Environ Health Perspect 102(12):1082–1087.7713021
Lévesque B, Ayotte P, Tardif R, 2000. Evaluation of the health risk associated with exposure to chloroform in indoor swimming pools. J Toxicol Environ Health 61(4):225–243. 10.1080/00984100050136553.
Li LH, Jiang XZ, Liang YX, 1993. Studies on the toxicity and maximum allowable concentration of chloroform. Biomed Environ Sci 6(2):179–186.8397901
Liang JC, Hsu TC, Henry JE. 1983. Cytogenetic assays for mitotic poisons. The grasshopper embryo system for volatile liquids. Mutat Res 113:467–479.6621578
Liao KH, Tan YM, Conolly RB, 2007. Bayesian estimation of pharmacokinetic and pharmacodynamic parameters in a mode-of-action-based cancer risk assessment for chloroform. Risk Anal 27(6):1535–1551. 10.1111/j.1539-6924.2007.00987.x.18093051
Lilly PD, Ross TM, Pegram RA. 1997. Trihalomethane comparative toxicity: acute renal and hepatic toxicity of chloroform and bromodichloromethane following aqueous gavage. Fundam Appl Toxicol 40(1):101–110. 10.1006/faat.1997.2372.9398492
Lim GE, Stals SI, Petrik JJ, 2004. The effects of in utero and lactational exposure to chloroform on postnatal growth and glucose tolerance in male Wistar rats. Endocrine 25(3):223–228. 10.1385/endo:25:3:223.15758249
Lin CH, Du CL, Chan CC, 2005. Saved by a material safety data sheet. Occup Med 55(8):635–637. 10.1093/occmed/kqi146.
Lin N, Rosemberg MA, Li W, 2022. Occupational exposure and health risks of volatile organic compounds of hotel housekeepers: Field measurements of exposure and health risks. Indoor Air 31(1):26–39. 10.1111/ina.12709.
Lin N, Ding N, Meza-Wilson E, 2023. Volatile organic compounds in disposable diapers and baby wipes in the US: A survey of products and health risks. Environ Sci Technol 57(37):13732–13743. 10.1021/acs.est.3c02862.37683294
Lind RC, Gandolfi AJ. 1997. Late dimethyl sulfoxide administration provides a protective action against chemically induced injury in both the liver and the kidney. Toxicol Appl Pharmacol 142(1):201–207. 10.1006/taap.1996.8009.9007050
Lind RC, Begay CK, Gandolfi AJ. 2000. Hepatoprotection by dimethyl sulfoxide. III. Role of inhibition of the bioactivation and covalent bonding of chloroform. Toxicol Appl Pharmacol 166(2):145–150. 10.1006/taap.2000.8949.10896856
Lionte C. 2010. Lethal complications after poisoning with chloroform-case report and literature review. Hum Exp Toxicol 29(7):615–622. 10.1177/0960327109357142.20051454
Lipscomb JC, Barton HA, Tornero-Velez R, 2004. The metabolic rate constants and specific activity of human and rat hepatic cytochrome P-450 2E1 toward toluene and chloroform. J Toxicol Environ Health 67(7):537–553. 10.1080/15287390490425588.
Lipsky MM, Skinner M, O’Connell C. 1993. Effects of chloroform and bromodichloromethane on DNA synthesis in male F344 rat kidney. Environ Health Perspect 101(Suppl 5):249–252. 10.1289/ehp.93101s5249.8013415
Liu S, Yao Y, Lu S, 2013. The role of renal proximal tubule P450 enzymes in chloroform-induced nephrotoxicity: utility of renal specific P450 reductase knockout mouse models. Toxicol Appl Pharmacol 272(1):230–237. 10.1016/j.taap.2013.05.022.23732084
Liu C, Wang YX, Chen YJ, 2020. Blood and urinary biomarkers of prenatal exposure to disinfection byproducts and oxidative stress: A repeated measurement analysis. Environ Int 137:105518. 10.1016/j.envint.2020.105518.32018134
Liu C, Sun Y, Mustieles V, 2021. Prenatal exposure to disinfection byproducts and intrauterine growth in a Chinese cohort. Environ Sci Technol 55(23):16011–16022. 10.1021/acs.est.1c04926.34813313
Liu W, Cao S, Ma J, 2023a. Exposures to volatile organic compounds, serum vitamin D, and kidney function: association and interaction assessment in the US adult population. Environ Sci Pollut Res Int 30(3):7605–7616. 10.1007/s11356-022-22637-1.36044140
Liu C, Chen YJ, Sun B, 2023b. Blood trihalomethane concentrations in relation to sperm mitochondrial DNA copy number and telomere length among 958 healthy men. Environ Res 216(Pt 4):114737. 10.1016/j.envres.2022.114737.36372149
Long JL, Stensel HD, Ferguson JF, 1993. Anaerobic and aerobic treatment of chlorinated aliphatic compounds. J Environ Eng 119(2):300–320. 10.1061/(asce)0733-9372(1993)119:2(300).
Longo V, Ingelman-Sundberg M. 1993. Acetone-dependent regulation of cytochromes P4502E1 and P4502B1 in rat nasal mucosa. Biochem Pharmacol 46(11):1945–1951. 10.1016/0006-2952(93)90635-a.8267643
Lopes TJ, Bender DA. 1998. Nonpoint sources of volatile organic compounds in urban areas-relative importance of land surfaces and air. Environ Pollut 101(2):221–230. 10.1016/s0269-7491(98)00048-7.15093084
Luke NS, Sams R, DeVito MJ, 2010. Development of a quantitative model incorporating key events in a hepatotoxic mode of action to predict tumor incidence. Toxicol Sci 115(1):253–266. 10.1093/toxsci/kfq021.20106946
Lundberg I, Ekdahl M, Kronevi T, 1986. Relative hepatotoxicity of some industrial solvents after intraperitoneal injection or inhalation exposure in rats. Environ Res 40(2):411–420. 10.1016/s0013-9351(86)80116-5.3732212
Lunt RL. 1953. Delayed chloroform poisoning in obstetric practice. Br Med J 1:489–490.13009257
Lurker PA, Clark CS, Elia VJ, 1983. Worker exposure to chlorinated organic compounds from the activated-sludge wastewater treatment process. Am Ind Hyg Assoc J 44:109–112.6837435
Luzhetskiy KP, Shur PZ, Ustinova OY, 2015. Individual risk assessment of metabolic disorders in children at exposure to chloroform in drinking water. Health Risk Anal 4(28–35):28–33.
Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Chloroform. In: Handbook of chemical property estimation methods. Environmental behavior of organic compounds. New York, NY: McGraw-Hill Book Co, 15.19–15.31.
Lynberg M, Nuckols JR, Langlois P, 2001. Assessing exposure to disinfection by-products in women of reproductive age living in Corpus Christi, Texas, and Cobb County, Georgia: descriptive results and methods. Environ Health Perspect 109(6):597–604. 10.1289/ehp.01109597.11445514
Lyons MA, Yang RS, Mayeno AN, 2008. Computational toxicology of chloroform: reverse dosimetry using Bayesian inference, Markov chain Monte Carlo simulation, and human biomonitoring data. Environ Health Perspect 116(8):1040–1046. 10.1289/ehp.11079.18709138
Mabey W, Mill T. 1978. Critical review of hydrolysis of organic compounds in water under environmental conditions. J Phys Chem Ref Data 7:383–415.
Mahle DA, Gearhart JM, Grigsby CC, 2007. Age-dependent partition coefficients for a mixture of volatile organic solvents in Sprague-Dawley rats and humans. J Toxicol Environ Health A 70(20):1745–1751. 10.1080/15287390701458991.17885931
Mailhot H. 1987. Prediction of algal bioaccumulation and uptake of nine organic compounds by ten physicochemical properties. Environ Sci Technol 21:1009–1013.19995001
Mally A, Chipman JK. 2002. Non-genotoxic carcinogens: early effects on gap junctions, cell proliferation and apoptosis in the rat. Toxicology 180(3):233–248. 10.1016/s0300-483x(02)00393-1.12393293
Malten KE, Spruit D, Boemaars HGM, 1968. Horny layer injury by solvents. Berufsdermatosen 16:135–147.5671948
Masuda Y, Nakayama N. 1982. Protective effect of diethyldithiocarbamate and carbon disulfide against liver injury induced by various hepatotoxic agents. Biochem Pharmacol 31:2713–2725.6291543
Masuda Y, Nakayama N. 1983. Protective action of diethyldithiocarbamate and carbon disulfide against renal injury induced by chloroform in mice. Biochem Pharmacol 32(21):3127–3135.6315019
McCarthy MC, Hafner HR, Montzka SA. 2006. Background concentrations of 18 air toxics for North America. J Air Waste Manag Assoc 56(1):3–11. 10.1080/10473289.2006.10464436.16499141
McCarty LP, Malek RS, Larsen ER. 1979. The effects of deuteration on the metabolism of halogenated anesthetics in the rat. Anesthesiology 51:106–110.453609
McDonald MN, Vire DE. 1992. Chloroform in the endodontic operatory. J Endodontics 18(6):301–303.
McDorman KS, Hooth MJ, Starr TB, 2003a. Analysis of preneoplastic and neoplastic renal lesions in Tsc2 mutant Long-Evans (Eker) rats following exposure to a mixture of drinking water disinfection by-products. Toxicology 187(1):1–12. 10.1016/s0300-483x(03)00004-0.12679048
McDorman KS, Chandra S, Hooth MJ, 2003b. Induction of transitional cell hyperplasia in the urinary bladder and aberrant crypt foci in the colon of rats treated with individual and a mixture of drinking water disinfection by-products. Toxicol Pathol 31(2):235–242. 10.1080/01926230390183733.12696585
McDorman KS, Pachkowski BF, Nakamura J, 2005. Oxidative DNA damage from potassium bromate exposure in Long-Evans rats is not enhanced by a mixture of drinking water disinfection by-products. Chem Biol Interact 152(2–3):107–117. 10.1016/j.cbi.2005.02.003.15840384
McHugh T, Beckley L, Sullivan T, 2017. Evidence of a sewer vapor transport pathway at the USEPA vapor intrusion research duplex. Sci Total Environ 598:772–779. 10.1016/j.scitotenv.2017.04.135.28456127
McKone TE. 1993. Linking a PBPK model for chloroform with measured breath concentrations in showers: implications for dermal exposure models. J Expo Anal Environ Epidemiol 3(3):339–365.8260842
McLean AEM. 1970. The effect of protein deficiency and microsomal enzyme induction by DDT and phenobarbitone on the acute toxicity of chloroform and a pyrrolizidine alkaloid, retrorsine. Br J Exp Pathol 51:317–321.5429075
McMartin DN, O'Connor JA, Kaminsky LS. 1981. Effects of differential changes in rat hepatic and renal cytochrome P-450 concentrations on hepatotoxicity and nephrotoxicity of chloroform. Res Commun Chem Pathol Pharmacol 31(1):99–110.7255876
Medgyesi DN, Trabert B, Sampson J, 2022. Drinking water disinfection byproducts, ingested nitrate, and risk of endometrial cancer in postmenopausal women. Environ Health Perspect 130(5):57012. 10.1289/EHP10207.35622390
Meek ME, Beauchamp R, Long G, 2002. Chloroform: exposure estimation, hazard characterization, and exposure-response analysis. J Toxicol Environ Health 5(3):283–334. 10.1080/10937400290070080.
Meek ME, Bucher JR, Cohen SM, 2003. A framework for human relevance analysis of information on carcinogenic modes of action. Crit Rev Toxicol 33(6):591–653. 10.1080/713608373.14727733
Meenakshisundaram R, Joseph JV, Perumal P, 2021. A chemist with a strange etiology of rhabdomyolysis: A case report of a rare toxicological emergency. Clin Pract Cases Emerg Med 5(4):432–435. 10.5811/cpcem.2021.7.52923.34813437
Mehendale HM. 1991. Role of hepatocellular regeneration and hepatolobular healing in the final outcome of liver injury. A two-stage model of toxicity. Biochem Pharmacol 42(6):1155–1162. 10.1016/0006-2952(91)90249-5.1716097
Mehendale HM. 2005. Tissue repair: an important determinant of final outcome of toxicant-induced injury. Toxicol Pathol 33(1):41–51. 10.1080/01926230590881808.15805055
Mehendale HM, Purushotham KR, Lockard VG. 1989. The time course of liver injury and [3H]thymidine incorporation in chlordecone-potentiated CHCl3 hepatotoxicity. Exp Mol Pathol 51(1):31–47. 10.1016/0014-4800(89)90005-1.2475365
Melnick RL, Kohn MC, Dunnick JK, 1998. Regenerative hyperplasia is not required for liver tumor induction in female B6C3F1 mice exposed to trihalomethanes. Toxicol Appl Pharmacol 148(1):137–147. 10.1006/taap.1997.8302.9465273
Mery S, Larson JL, Butterworth BE, 1994. Nasal toxicity of chloroform in male F-344 rats and female B6C3F1 mice following a 1-week inhalation exposure. Toxicol Appl Pharmacol 125(2):214–227. 10.1006/taap.1994.1067.7513449
MHLW. 1994a. [Report of an inhalation-induced carcinogenicity study of chloroform in rats and mice]. Japan: Ministry of Health, Labor and Welfare. Study No. 0115, 0116. https://anzeninfo.mhlw.go.jp/user/anzen/kag/pdf/gan/Chloroform_Cancer_MAIN.pdf. May 6, 2024. (Japanese)
MHLW. 1994b. [Report of an inhalation-induced carcinogenicity study of chloroform in rats and mice]: Appendix (J1~R2): [Carcinogenicity test] No. 0115; 0116. Japan: Ministry of Health, Labor and Welfare. Study No. 0115, 0116. https://anzeninfo.mhlw.go.jp/user/anzen/kag/pdf/gan/Chloroform_Cancer_APPENDIX_3.pdf. May 6, 2024. (Japanese)
Min JY, Min KB. 2016. Blood trihalomethane levels and the risk of total cancer mortality in US adults. Environ Pollut 212:90–96. 10.1016/j.envpol.2016.01.047.26840521
Minet-Quinard R, Goncalves-Mendes N, Gallot D, 2023. Volatile organic compounds detected in amniotic fluid of women during normal pregnancy. Expo Health:online. 10.1007/s12403-023-00617-1.
Mink FL, Brown TJ, Rickabaugh J. 1986. Absorption, distribution and excretion of C-trihalomethanes in mice and rats. Bull Environ Contam Toxicol 37:752–758.3779162
Minor EA, Newman MS, Kupec JT. 2018. Chronic, recreational chloroform-induced liver injury. Case Rep Hepatol 2018:1619546. 10.1155/2018/1619546.
Mirsalis JC, Tyson CK, Butterworth BE. 1982. Detection of genotoxic carcinogens in the in vivo-in vitro hepatocyte DNA repair assay. Environ Mutagen 4:553–562.7140674
Mitchell AD, Myhr BC, Rudd CJ, 1988. Evaluation of the L5178Y mouse lymphoma cell system: Methods used and chemicals evaluated. Environ Mol Mutagen 12(Suppl 13):1–18.
Miyagawa M, Katsuta O, Chida T, 1998. Occurrence of toxicity and cell proliferation after a single gavage administration of chloroform to male F344 rats. J Toxicol Sci 23(3):205–211. 10.2131/jts.23.3_205.
Moore DH, Chasseaud LF, Majeed SK, 1982. The effect of dose and vehicle on early tissue damage and regenerative activity after chloroform administration to mice. Food Chem Toxicol 20(6):951–954. 10.1016/s0015-6264(82)80235-6.6891681
Morimoto K, Koizumi A. 1983. Trihalomethanes induce sister chromatid exchanges in human lymphocytes in vitro and mouse bone marrow cells in vivo. Environ Res 32:72–79.6617620
Morris JB, Hassett DN, Blanchard KT. 1993. A physiologically based pharmacokinetic model for nasal uptake and metabolism of nonreactive vapors. Toxicol Appl Pharmacol 123(1):120–129. 10.1006/taap.1993.1228.8236250
Mostafa AA, Zharan FM, Guirgis AA, 2009. Hypomethylation and histological changes induced by chloroform administered by oral gavages in corn oil to mice. Aust J Basic Appl Sci 3(3):1569–1576.
Müller SP, Wolna P, Wünscher U, 1997. Cardiotoxicity of chlorodibromomethane and trichloromethane in rats and isolated rat cardiac myocytes. Arch Toxicol 71(12):766–777. 10.1007/s002040050459.9388010
Mumtaz MM, Ray M, Crowell SR, 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Munson AE, Sain LE, Sanders VM, 1982. Toxicology of organic drinking water contaminants: Trichloromethane, bromodichloromethane, dibromochloromethane and tribromomethane. Environ Health Perspect 46:117–126. 10.1289/ehp.8246117.7151752
Murray FJ, Schwetz BA, McBride JB, 1979. Toxicity of inhaled chloroform in pregnant mice and their offspring. Toxicol Appl Pharmacol 50(3):515–522. 10.1016/0041-008X(79)90406-X.516065
Myhr BC, Caspary WJ. 1988. Evaluation of the L5178Y mouse lymphoma cell mutagenesis assay: intralaboratory results for sixty-three coded chemicals tested at Litton Bionetics, Inc. Environ Mol Mutagen 12(Suppl 13):103–194. 10.1002/em.2860120505.3416838
Nagano K, Kano H, Arito H, 2006. Enhancement of renal carcinogenicity by combined inhalation and oral exposures to chloroform in male rats. J Toxicol Environ Health 69(20):1827–1842. 10.1080/15287390600630146.
Nakagawa T, Hamanaka T, Nishimura S, 2000. The quantitative analysis of three action modes of volatile anesthetics on purple membrane. Biochimica et Biophysica Acta 1468(1–2):139–149. 10.1016/s0005-2736(00)00253-4.11018659
Nakai JS, Stathopulos PB, Campbell GL, 1999. Penetration of chloroform, trichloroethylene, and tetrachloroethylene through human skin. J Toxicol Environ Health 58(3):157–170. 10.1080/009841099157368.
Namkung E, Rittmann BE. 1987. Estimating volatile organic compound emissions from publicly owned treatment works. J Water Pollut Control Fed 59:670–678.
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
Nashelsky MB, Dix JD, Adelstein EH. 1995. Homicide facilitated by inhalation of chloroform. J Forensic Sci 40(1):134–138.7876797
NCI. 1976. Report on carcinogenesis bioassay of chloroform. Bethesda, MD: National Cancer Institute. PB264018. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB264018.xhtml. February 21, 2023.
Neta G, Stewart PA, Rajaraman P, 2012. Occupational exposure to chlorinated solvents and risks of glioma and meningioma in adults. Occup Environ Med 69(11):793–801. 10.1136/oemed-2012-100742.22864249
Nicholson BC, Maguire BP, Bursill DB. 1984. Henry’s law constants for the trihalomethanes: Effects of water composition and temperature. Environ Sci Technol 28:518–521.
Nieuwenhuijsen MJ, Toledano MB, Eaton NE, 2000. Chlorination disinfection byproducts in water and their association with adverse reproductive outcomes: a review. Occup Environ Med 57(2):73–85. 10.1136/oem.57.2.73.10711274
NIOSH. 2018. Method 3900: Volatile organic compounds, C1 to C10, canister method. NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/nmam/pdf/3900.pdf. January 26, 2023.
NIOSH. 2019. Chloroform. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0127.html. May 26, 2021.
NITE. 1980. Chloroform - bioaccumulation: aquatic/sediment. Japanese Chemicals and Collaborative Knowledge Database. Japanese National Institute of Technology and Evaluation. https://www.nite.go.jp/chem/jcheck/template.action?ano=27654&mno=2-0037&cno=67-66-3&request_locale=en. January 17, 2023.
NITE. 2010. Chloroform - biodegradation in water: screening tests. Japanese Chemicals and Collaborative Knowledge Database. Japanese National Institute of Technology and Evaluation. https://www.nite.go.jp/chem/jcheck/template.action?ano=331&mno=2-0037&cno=67-66-3&request_locale=en. January 17, 2023.
Nitter TB, Svendsen KVH. 2019. Modelling the concentration of chloroform in the air of a Norwegian swimming pool facility-A repeated measures study. Sci Total Environ 664:1039–1044. 10.1016/j.scitotenv.2019.02.113.30901778
NLM. 2023. Chloroform. PubChem. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/6212. January 16, 2023.
Norman AM, Kissel JC, Shirai JH, 2008. Effect of PBPK model structure on interpretation of in vivo human aqueous dermal exposure trials. Toxicol Sci 104(1):210–217. 10.1093/toxsci/kfn070.18381354
NTP. 1987a. Cytogenetic study of chloroform in rodent chromosome aberrations test. National Toxicology Program. 002–01867-0013–0000-8; 142011_CA. https://cebs.niehs.nih.gov/cebs/genetox/002-01867-0013-0000-8/. March 22, 2023.
NTP. 1987b. Cytogenetic study of chloroform in rodent sister chromatid exchange test. National Toxicology Program. 002–01867-0002–0000-7; 142011_SCE. https://cebs.niehs.nih.gov/cebs/genetox/002-01867-0012-0000-7/. March 22, 2023.
NTP. 1988a. Chloroform: Reproduction and fertility assessment in CD-1 mice when administered by gavage. Research Triangle Park, NC: National Toxicology Program. PB89148639. NTP-86-FACB-052. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB89148639.xhtml. January 24, 2023.
NTP. 1988b. Cytogenetic study of chloroform in Chinese hamster ovary cell chromosome aberrations test. National Toxicology Program. 002–01867-0002–0000-6; 564651_CA. https://cebs.niehs.nih.gov/cebs/genetox/002-01867-0002-0000-6/. March 22, 2023.
NTP. 1988c. Cytogenetic study of chloroform in Chinese hamster ovary cell sister chromatid exchange test. National Toxicology Program. 002–01867-0001–0000-5; 564651_SCE. https://cebs.niehs.nih.gov/cebs/genetox/002-01867-0001-0000-5/. March 22, 2023.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments – February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. February 20, 2023.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2016. Substances listed in the fourteenth report on carcinogens. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/listed_substances_508.pdf. February 20, 2023.
NTP. 2018a. Genetic toxicology - micronucleus; G04: In vivo micronucleus summary data; Test compound: chloroform. National Toxicology Program. https://cebs.niehs.nih.gov/cebs/get_file/accno/10316_13723/file/142011_G04_In_Vivo_Micronucleus_Summary_Data.pdf. March 22, 2023.
NTP. 2018b. Genetic toxicology - bacterial mutagenicity; G06: Ames summary data; Test compound: chloroform. National Toxicology Program. https://cebs.niehs.nih.gov/cebs/get_file/accno/12588_15995/file/749633_G06_Ames_Summary_Data.pdf. March 22, 2023.
NTP. 2021. Chloroform. 15th Report on carcinogens. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/chloroform.pdf. January 23, 2023.
Odabasi M. 2008. Halogenated volatile organic compounds from the use of chlorine-bleach-containing household products. Environ Sci Technol 42(5):1445–1451. 10.1021/es702355u.18441786
Ohligschläger A, Menzel K, Ten Kate A, 2019. Chloromethanes. In: Ullmann's encyclopedia of industrial chemistry. Weinheim, Germany: Wiley-VCH Verlag GmbH & Co. KGaA, 1–31. 10.1002/14356007.a06_233.pub4.
Olson DA, Corsi RL. 2004. In-home formation and emissions of trihalomethanes: the role of residential dishwashers. J Expo Anal Environ Epidemiol 14(2):109–119. 10.1038/sj.jea.7500295.15014541
OSHA. 2022a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-2. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2022-title29-vol6/pdf/CFR-2022-title29-vol6-sec1910–1000.pdf. May 3, 2024.
OSHA. 2022b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2022-title29-vol7/pdf/CFR-2022-title29-vol7-sec1915–1000.pdf. May 3, 2024.
OSHA. 2022c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2022-title29-vol8/pdf/CFR-2022-title29-vol8-sec1926-55.pdf. May 3, 2024.
Paasivirta J, Knuutinen J, Knuutila M, 1988. Lignin and organic chlorine compounds in lake water and the role of the chlorobleaching effluents. Chemosphere 17:147–158.
Paixao P, Aniceto N, Gouveia LF, 2013. Tissue-to-blood distribution coefficients in the rat: utility for estimation of the volume of distribution in man. Eur J Pharm Sci 50(3–4):526–543. 10.1016/j.ejps.2013.08.020.23994235
Palmer AK, Street AE, Roe JC, 1979. Safety evaluation of toothpaste containing chloroform. II. Long term studies in rats. J Environ Pathol Toxicol 2:821–833.422937
Pankow D, Damme B. 1999. Carbon monoxide generation from trihalomethane metabolism in rats. Indoor Built Environ 8(3):203–208. 10.1177/1420326x9900800314.
Park KS, Sorensen DL, Sims JL, 1988. Volatilization of wastewater trace organics in slow rate land treatment systems. Haz Waste Haz Mat 5(3):219–229.
Pavel MA, Petersen EN, Wang H, 2020. Studies on the mechanism of general anesthesia. Proc Natl Acad Sci U S A 117(24):13757–13766. 10.1073/pnas.2004259117.32467161
Pegram RA, Andersen ME, Warren SH, 1997. Glutathione S-transferase-mediated mutagenicity of trihalomethanes in Salmonella typhimurium: contrasting results with bromodichloromethane off chloroform. Toxicol Appl Pharmacol 144(1):183–188. 10.1006/taap.1997.8123.9169083
Pelekis M, Gephart LA, Lerman SE. 2001. Physiological-model-based derivation of the adult and child pharmacokinetic intraspecies uncertainty factors for volatile organic compounds. Regul Toxicol Pharmacol 33(1):12–20. 10.1006/rtph.2000.1436.11259175
Peoples AJ, Pfaffenberger CD, Shafik TM, 1979. Determination of volatile purgeable halogenated hydrocarbons in human adipose tissue and blood serum. Bull Environ Contam Toxicol 23:244–249.497433
Pereira MA. 1994. Route of administration determines whether chloroform enhances or inhibits cell proliferation in the liver of B6C3F1 mice. Fundam Appl Toxicol 23(1):87–92.7958568
Pereira MA, Grothaus M. 1997. Chloroform in drinking water prevents hepatic cell proliferation induced by chloroform administered by gavage in corn oil to mice. Fundam Appl Toxicol 37(1):82–87. 10.1006/faat.1997.2308.9193925
Pereira MA, Kramer PM, Conran PB, 2001. Effect of chloroform on dichloroacetic acid and trichloroacetic acid-induced hypomethylation and expression of the c-myc gene and on their promotion of liver and kidney tumors in mice. Carcinogenesis 22(9):1511–1519. 10.1093/carcin/22.9.1511.11532874
Perocco P, Prodi G. 1981. DNA damage by haloalkanes in human lymphocytes cultured in vitro. Cancer Lett 13:213–218.6457684
Pfaffenberger CD, Peoples AJ, Enos HF. 1980. Distribution of volatile halogenated organic compounds between rat blood serum and adipose tissue. Int J Environ Anal Chem 8:55–65.7399799
Philip BK, Anand SS, Palkar PS, 2006. Subchronic chloroform priming protects mice from a subsequently administered lethal dose of chloroform. Toxicol Appl Pharmacol 216(1):108–121. 10.1016/j.taap.2006.04.012.16815507
Phoon WH, Goh KT, Lee LT, 1983. Toxic jaundice from occupational exposure to chloroform. Med J Malaysia 38(1):31–34.6633331
Picardal FW, Arnold RG, Couch H, 1993. Involvement of cytochromes in the anaerobic biotransformation of tetrachloromethane by Shewanella putrefaciens 200. Appl Environ Microbial 59(11):3763–3770.
Piersol GM, Tumen HJ, Kau LS. 1933. Fatal poisoning following the ingestion of chloroform. Med Clin North Am 17:587–601.
Piwoni MD, Wilson JT, Walters DM, 1986. Behavior of organic pollutants during rapid-infiltration of wastewater into soil. I. Processes, definition, and characterization using a microcosm. Haz Waste Haz Mat 3:43–55.
Pleil JD, Lindstrom AB. 1997. Exhaled human breath measurement method for assessing exposure to halogenated volatile organic compounds. Clin Chem 43(5):723–730.9166222
Pohl LR, Gillette JR. 1984. Determination of toxic pathways of metabolism by deuterium substitution. Drug Metab Rev 15:1335–1351.6398777
Pohl LR, Martin JL, Taburet AM, 1980. Oxidative bioaction of haloforms into hepatotoxins. In: Coon MJ, Conney AH, Estabrook RW, , eds. Microsomes, drug oxidations, and chemical carcinogenesis. Vol. 2. Elsevier, 881–884.
Pohl LR, Branchflower RV, Highet RJ, 1981. The formation of diglutathionyl dithiocarbonate as a metabolite of chloroform, bromotrichloromethane, and carbon tetrachloride. Drug Metab Dispos 9:334–339.6114833
Porter CK, Putnam SD, Hunting KL, 2005. The effect of trihalomethane and haloacetic acid exposure on fetal growth in a Maryland county. Am J Epidemiol 162(4):334–344. 10.1093/aje/kwi211.16014784
Potter CL, Chang LW, DeAngelo AB, 1996. Effects of four trihalomethanes on DNA strand breaks, renal hyaline droplet formation and serum testosterone in male F-344 rats. Cancer Lett 106(2):235–242. 10.1016/0304-3835(96)04331-5.8844978
Poulin P, Krishnan K. 1996. A tissue composition-based algorithm for predicting tissue:air partition coefficients of organic chemicals. Toxicol Appl Pharmacol 136(1):126–130. 10.1006/taap.1996.0015.8560465
Poulin P, Krishnan K. 2001. Molecular structure-based prediction of human abdominal skin permeability coefficients for several organic compounds. J Toxicol Environ Health A 62(3):143–159. 10.1080/009841001458271.11212942
Pratt GC, Palmer K, Wu CY, 2000. An assessment of air toxics in Minnesota. Environ Health Perspect 108(9):815–825. 10.1289/ehp.00108815.11017885
Price PS, Conolly RB, Chaisson CF, 2003. Modeling interindividual variation in physiological factors used in PBPK models of humans. Crit Rev Toxicol 33(5):469–503.14594104
Purdue MP, Stewart PA, Friesen MC, 2017. Occupational exposure to chlorinated solvents and kidney cancer: a case-control study. Occup Environ Med 74(4):268–274. 10.1136/oemed-2016-103849.27803178
Purushotham KR, Lockard VG, Mehendale HM. 1988. Amplification of chloroform hepatotoxicity and lethality by dietary chlordecone (kepone) in mice. Toxicol Pathol 16(1):27–34. 10.1177/019262338801600104.2453913
Qu H, Cao J, Wang P, 2022. Volatile organic compounds and dominant bacterial community during aerobic composting of vegetable waste and cow manure co-complexing. BioResources 17(1):1338–1353. 10.15376/biores.17.1.1338-1353.
Ramírez N, Marcé RM, Borrull F. 2011. Determination of volatile organic compounds in industrial wastewater plant air emissions by multi-sorbent adsorption and thermal desorption-gas chromatography-mass spectrometry. Int J Environ Anal Chem 91(10):911–928. 10.1080/03067310903584073.
Ramsey JC, Andersen ME. 1984. A physiologically-based description of the inhalation pharmacokinetics of styrene in rats and humans. Toxicol Appl Pharmacol 73:159–175.6710512
Rao KN, Virji MA, Moraca MA, 1993. Role of serum markers for liver function and liver regeneration in the management of chloroform poisoning. J Anal Toxicol 17(2):99–102. 10.1093/jat/17.2.99.8492575
Ray SD, Mehendale HM. 1990. Potentiation of CCl4 and CHCl3 hepatotoxicity and lethality by various alcohols. Fundam Appl Toxicol 15(3):429–440. 10.1016/0272-0590(90)90029-j.2258008
Reddy TV, Daniel FB, Lin EL, 1992. Chloroform inhibits the development of diethylnitrosamine-initiated, phenobarbital-promoted gamma-glutamyltranspeptidase and placental form glutathione S-transferase-positive foci in rat liver. Carcinogenesis 13(8):1325–1330.1354081
Reitz RH, Mendrala AL, Corley RA, 1990. Estimating the risk of liver cancer associated with human exposures to chloroform using physiologically based pharmacokinetic modeling. Toxicol Appl Pharmacol 105:443–459.2237918
RePORTER. 2024. Chloroform. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. May 8, 2024.
Rhee E, Speece RE. 1992. Maximal biodegradation rates of chloroform and trichloroethylene in anaerobic treatment. Water Sci Technol 25(3):121–130.
Risse M, Erdmann F, Schütz H, 2001. Multiple homicides as a result of chloroform poisoning: case report and experimental study. Forensic Sci Int 124(2–3):209–213. 10.1016/s0379-0738(01)00589-8.11792514
Rivera-Núñez Z, Wright JM. 2013. Association of brominated trihalomethane and haloacetic acid exposure with fetal growth and preterm delivery in Massachusetts. J Occup Environ Med 55(10):1125–1134. 10.1097/JOM.0b013e3182a4ffe4.24064786
Rivera-Núñez Z, Wright JM, Meyer A. 2018. Exposure to disinfectant by-products and the risk of stillbirth in Massachusetts. Occup Environ Med 75(10):742–751. 10.1136/oemed-2017-104861.30061312
Robbiano L, Mereto E, Migliazzi Morando A, 1998. Increased frequency of micronucleated kidney cells in rats exposed to halogenated anaesthetics. Mutat Res 413(1):1–6. 10.1016/s1383-5718(97)00187-3.9602852
Roe FJC, Palmer AK, Worden AN. 1979. Safety evaluation of toothpaste containing chloroform. I. Long-term studies in mice. J Environ Pathol Toxicol 2(3):799–819.422936
Rooney AA, Boyles AL, Wolfe MS, 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rostad CE, Martin BS, Barber LB, 2000. Effect of a constructed wetland on disinfection byproducts: Removal processes and production of precursors. Environ Sci Technol 34(13):2703–2710. 10.1021/es9900407.
Rowe BL, Toccalino PL, Moran MJ, 2007. Occurrence and potential human-health relevance of volatile organic compounds in drinking water from domestic wells in the United States. Environ Health Perspect 115(11):1539–1546. 10.1289/ehp.10253.18007981
Roy A, Weisel CP, Gallo MA, 1996a. Studies of multiroute exposure/dose reconstruction using physiologically based pharmacokinetic models. Toxicol Indust Health 12(2):153–163.
Roy A, Weisel CP, Lioy PJ, 1996b. A distributed parameter physiologically-based pharmacokinetic model for dermal and inhalation exposure to volatile organic compounds. Risk Anal 16(2):147–160. 10.1111/j.1539-6924.1995.tb00773.x.8638037
Royston GD. 1924. Delayed chloroform poisoning following delivery. Am J Obstet Gynecol 10:808–814.
Ruddick JA, Villeneuve DC, Chu I, 1983. A teratological assessment of four trihalomethanes in the rat. J Environ Sci Health B 18(3):333–349. 10.1080/03601238309372373.6875216
Ruder AM, Yiin JH, Waters MA, 2013. The Upper Midwest Health Study: gliomas and occupational exposure to chlorinated solvents. Occup Environ Med 70(2):73–80. 10.1136/oemed-2011-100588.23104734
Ruiz P, Ray M, Fisher J, 2011. Development of a human Physiologically Based Pharmacokinetic (PBPK) Toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Ryan TJ, Hart EM, Kappler LL. 2002. VOC exposures in a mixed-use university art building. AIHA J 63(6):703–708. 10.1080/15428110208984758.
Sa CS, Boaventura RA, Pereira IB. 2011. Analysis of trihalomethanes in water and air from indoor swimming pools using HS-SPME/GC/ECD. J Environ Sci Health A Tox Hazard Subst Environ Eng 46(4):355–363. 10.1080/10934529.2011.542385.21337249
Sabljic A. 1984. Predictions of the nature and strength of soil sorption of organic pollutants by molecular topology. J Agric Food Chem 32:243–246.
Salas LA, Cantor KP, Tardon A, 2013. Biological and statistical approaches for modeling exposure to specific trihalomethanes and bladder cancer risk. Am J Epidemiol 178(4):652–660. 10.1093/aje/kwt009.23648803
Sarangapani R, Clewell HJ, Cruzan G, 2002. Comparing respiratory-tract and hepatic exposure-dose relationships for metabolized inhaled vapors: a pharmacokinetic analysis. Inhal Toxicol 14(8):835–854. 10.1080/08958370290084656.12122566
Sasso AF, Schlosser PM, Kedderis GL, 2013. Application of an updated physiologically based pharmacokinetic model for chloroform to evaluate CYP2E1-mediated renal toxicity in rats and mice. Toxicol Sci 131(2):360–374. 10.1093/toxsci/kfs320.23143927
Sate A, Nakajima T, Koyama Y. 1981. Dose-related effects of a single dose of ethanol on the metabolism in rat liver of some aromatic and chlorinated hydrocarbons. Toxicol Appl Pharmacol 60:8–15.7281179
Savitz DA, Singer PC, Herring AH, 2006. Exposure to drinking water disinfection by-products and pregnancy loss. Am J Epidemiol 164(11):1043–1051. 10.1093/aje/kwj300.16957027
Sawhney BL. 1989. Movement of organic chemicals through landfill and hazardous waste disposal sites. SSSA Spec Publ 22:447–474. 10.2136/sssaspecpub22.c18.
Scholler KL. 1970. Modification of the effects of chloroform on the rat liver. Br J Anaesth 42:603–605.5453242
Scholz EP, Alter M, Zitron E, 2006. In vitro modulation of HERG channels by organochlorine solvent trichlormethane as potential explanation for proarrhythmic effects of chloroform. Toxicol Lett 165(2):156–166. 10.1016/j.toxlet.2006.03.004.16647228
Schroeder HG. 1965. Acute and delayed chloroform poisoning. Br J Anaesth 37:972–975.5856656
Schwarz DW, Schwarz IE, Hu K. 1988. Histopathology of chloroform-induced inner ear damage. J Otolaryngol 17(1):32–37.3343718
Schwetz BA, Leong BK, Gehring PJ. 1974. Embryo- and fetotoxicity of inhaled chloroform in rats. Toxicol Appl Pharmacol 28(3):442–451. 10.1016/0041-008x(74)90229-4.4851839
Scott PS, Andrew JP, Bundy BA, 2020. Observations of volatile organic and sulfur compounds in ambient air and health risk assessment near a paper mill in rural Idaho, U.S.A. Atmos Pollut Res 11(10):1870–1881. 10.1016/j.apr.2020.07.014.33162775
Sehata S, Maejima T, Watanabe M, 2002. Twenty-six-week carcinogenicity study of chloroform in CB6F1 rasH2-transgenic mice. Toxicol Pathol 30(3):328–338. 10.1080/01926230252929909.12051550
Sekar A, Varghese GK, Varma MKR. 2022. Chloroform - An emerging pollutant in the air. In: Singh P, Agarwal AK, Gupta T, , eds. New trends in emerging environmental contaminants. Energy, environment, and sustainability. Singapore: Springer, 101–129. 10.1007/978-981-16-8367-1_6.
Selgrade MK, Gilmour MI. 2010. Suppression of pulmonary host defenses and enhanced susceptibility to respiratory bacterial infection in mice following inhalation exposure to trichloroethylene and chloroform. J Immunotoxicol 7(4):350–356. 10.3109/1547691x.2010.520139.20925451
Shatkin J, Szejnwald-Brown H. 1991. Pharmacokinetics of the dermal route of exposure to volatile organic chemicals in water: a computer simulation model. Environ Res 56:90–108.1915193
Shendell DG, Winer AM, Stock TH, 2004. Air concentrations of VOCs in portable and traditional classrooms: results of a pilot study in Los Angeles County. J Expo Anal Environ Epidemiol 14(1):44–59. 10.1038/sj.jea.7500297.14726944
Shepherd JL, Corsi RL, Kemp J. 1996. Chloroform in indoor air and wastewater: The role of residential washing machines. J Air Waste Manag Assoc 46(7):631–642. 10.1080/10473289.1996.10467497.28081390
Shi J, Zhang K, Xiao T, 2024. Exposure to disinfection by-products and risk of cancer: A systematic review and dose-response meta-analysis. Ecotoxicol Environ Saf 270:115925. 10.1016/j.ecoenv.2023.115925.38183752
Silva LK, Backer LC, Ashley DL, 2013. The influence of physicochemical properties on the internal dose of trihalomethanes in humans following a controlled showering exposure. J Expo Sci Environ Epidemiol 23(1):39–45. 10.1038/jes.2012.80.22829048
Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. In: Scott D, Bridges BA, Sobels FH, eds. Progress in genetic toxicology. Elsevier/North Holland Press, 249–258.
Singer PP, Jones GR. 2006. An unusual autoerotic fatality associated with chloroform inhalation. J Anal Toxicol 30(3):216–218. 10.1093/jat/30.3.216.16803657
Singh HB, Salas JL, Smith AJ. 1981. Measurements of some potentially hazardous chemicals in urban environments. Atmos Environ 15:601–612.
Sipes IG, Krishna G, Gillette JR. 1977. Bioactivation of carbon tetrachloride, chloroform and bromotrichloromethane: Role of cytochrome P-450. Life Sci 20:1541–1548.17803
Smith AA, Volpitto PP, Gramling ZW, 1973. Chloroform, halothane, and regional anesthesia: A comparative study. Anesth Analg 52(1):1–11.4734294
Smith JH, Maita K, Sleight SD, 1984. Effect of sex hormone status on chloroform nephrotoxicity and renal mixed function oxidases in mice. Toxicology 30:305–316.6729829
Smith AE, Gray GM, Evans JS. 1995. The ability of predicted internal dose measures to reconcile tumor bioassay data for chloroform. Regul Toxicol Pharmacol 21(3):339–351. 10.1006/rtph.1995.1048.7480887
Smyth HF, Carpenter CP, Weil CS, 1962. Range-finding toxicity data: List VI. Am Ind Hyg Assoc J 23:95–107. 10.1080/00028896209343211.13914538
Sofuoglu SC, Lebowitz MD, O'Rourke MK, 2003. Exposure and risk estimates for Arizona drinking water. J Am Water Works Assoc 95(7):67–79. 10.1002/j.1551-8833.2003.tb10409.x.
Squillace PJ, Moran MJ, Lapham WW, 1999. Volatile organic compounds in untreated ambient groundwater of the United States, 1985–1995. Environ Sci Technol 33(23):4176–4187. 10.1021/es990234m.
Squillace PJ, Moran MJ, Price CV. 2004. VOCs in shallow groundwater in new residential/commercial areas of the United States. Environ Sci Technol 38(20):5327–5338. 10.1021/es0349756.15543733
Sridhar N, Krishnakishore C, Sandeep Y, 2011. Chloroform poisoning-a case report. Renal Failure 33(10):1037–1039. 10.3109/0886022x.2011.618920.22013938
Stacey NH. 1987a. Reduced glutathione and toxicity of cadmium/chloroform mixtures in isolated rat hepatocytes. In Vitro Toxicol 1:189–192.
Stacey NH. 1987b. Assessment of the toxicity of chemical mixtures with isolated rat hepatocytes: Cadmium and chloroform. Fundam Appl Toxicol 9:616–622.3692018
Stefanovic J, Starsia Z, Murgasova I, 1987. In vitro effects of organic solvents on immunity indicators in serum. J Hyg Epidemiol Microbial Immunol 31(1):1–7.
Stephens RD, Ball ND, Mar DM. 1986. A multimedia study of hazardous waste land fill gas migration. In: Pollutants in a multimedia environment. New York, NY: Plenum Press, 265–287.
Stevens JL, Anders MW. 1981. Effect of cysteine, diethyl maleate, and phenobarbital treatments on the hepatotoxicity of [lH]- and [2H]chloroform. Chem Biol Interact 37:207–217.7285244
Stoner GD, Conran PB, Greisiger EA, 1986. Comparison of two routes of chemical administration on the lung adenoma response in strain A/J mice. Toxicol Appl Pharmacol 82:19–31.3945940
Storms WW. 1973. Chloroform parties. J Am Med Assoc 225:160.
St-Pierre A, Krishnan K, Tardif R. 2003. Evaluation of the influence of chloroacetic acids on the pharmacokinetics of trihalomethanes in the rat. J Toxicol Environ Health A 66(23):2267–2280. 10.1080/713853999.14612337
St-Pierre A, Krishnan K, Tardif R. 2005. Characterization of the metabolic interaction between trihalomethanes and chloroacetic acids using rat liver microsomes. J Toxicol Environ Health A 68(4):287–298. 10.1080/15287390590895847.15799452
Sturrock J. 1977. Lack of mutagenic effect of halothane or chloroform on cultured cells using the azaguanine test system. Br J Anaesth 49:207–210.911573
Suehiro Y, Uchida T, Tsuge M, 2023. Acute liver injury in a non-alcoholic fatty liver disease patient with chloroform exposure: a case report. Clin J Gastroenterol 16(2):250–253. 10.1007/s12328-023-01760-7.36715860
Summerhayes RJ, Morgan GG, Edwards HP, 2012. Exposure to trihalomethanes in drinking water and small-for-gestational-age births. Epidemiology 23(1):15–22. 10.1097/EDE.0b013e31823b669b.22157301
Summerhayes RJ, Rahman B, Morgan GG, 2021. Meta-analysis of small for gestational age births and disinfection byproduct exposures. Environ Res 196:110280. 10.1016/j.envres.2020.110280.33035558
Sun Y, Wang YX, Liu C, 2020. Trimester-specific blood trihalomethane and urinary haloacetic acid concentrations and adverse birth outcomes: Identifying windows of vulnerability during pregnancy. Environ Health Perspect 128(10):107001. 10.1289/EHP7195.33026246
Sun Y, Chen C, Mustieles V, 2021a. Association of blood trihalomethane concentrations with risk of all-cause and cause-specific mortality in U.S. Adults: A prospective cohort study. Environ Sci Technol 55(13):9043–9051. 10.1021/acs.est.1c00862.34152769
Sun Y, Xia PF, Korevaar TIM, 2021b. Relationship between blood trihalomethane concentrations and serum thyroid function measures in U.S. adults. Environ Sci Technol 55(20):14087–14094. 10.1021/acs.est.1c04008.34617747
Sun Y, Xia PF, Xie J, 2022. Association of blood trihalomethane concentrations with asthma in US adolescents: nationally representative cross-sectional study. Eur Respir J 59(5):2101440. 10.1183/13993003.01440-2021.34625481
Sun Y, Wang YX, Liu C, 2023a. Exposure to trihalomethanes and bone mineral density in US adolescents: A Cross-Sectional Study (NHANES). Environ Sci Technol 57(51):21616–21626. 10.1021/acs.est.3c07214.38091484
Sun Y, Wang YX, Mustieles V, 2023b. Blood trihalomethane concentrations and allergic sensitization: A nationwide cross-sectional study. Sci Total Environ 871:162100. 10.1016/j.scitotenv.2023.162100.36764558
Swartz MD, Cai Y, Chan W, 2015a. Air toxics and birth defects: a Bayesian hierarchical approach to evaluate multiple pollutants and spina bifida. Environ Health 14:16. 10.1186/1476-069X-14-16.25971584
Swartz MD, Cai Y, Chan W, 2015b. Supplemental material: Air toxics and birth defects: a Bayesian hierarchical approach to evaluate multiple pollutants and spina bifida. Environ Health 14 10.1186/1476-069X-14-16.
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press, 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Take M, Yamamoto S, Ohnishi M, 2010. Chloroform distribution and accumulation by combined inhalation plus oral exposure routes in rats. J Environ Sci Health A Toxic Hazard Subst Environ Eng 45(12):1616–1624. 10.1080/10934529.2010.506121.
Take M, Takeuchi T, Haresaku M, 2014. Estimation of chloroform inhalation dose by other routes based on the relationship of area under the blood concentration-time curve (AUC)-inhalation dose to chloroform distribution in the blood of rats. J Environ Sci Health A Tox Hazard Subst Environ Eng 49(3):253–261. 10.1080/10934529.2014.846191.24279616
Tan YM, Butterworth BE, Gargas ML, 2003. Biologically motivated computational modeling of chloroform cytolethality and regenerative cellular proliferation. Toxicol Sci 75(1):192–200. 10.1093/toxsci/kfg152.12805651
Tan YM, Liao KH, Conolly RB, 2006. Use of a physiologically based pharmacokinetic model to identify exposures consistent with human biomonitoring data for chloroform. J Toxicol Environ Health 69(18):1727–1756. 10.1080/15287390600631367.
Tan YM, Liao KH, Clewell HJ. 2007. Reverse dosimetry: interpreting trihalomethanes biomonitoring data using physiologically based pharmacokinetic modeling. J Expo Sci Environ Epidemiol 17(7):591–603. 10.1038/sj.jes.7500540.17108893
Tan YM, Chan M, Chukwudebe A, 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Tao L, Wang W, Li L, 2005. DNA hypomethylation induced by drinking water disinfection byproducts in mouse and rat kidney. Toxicol Sci 87(2):344–352. 10.1093/toxsci/kfi257.16014735
Tardif R, Charest-Tardif G, Brodeur J, 1997. Physiologically based pharmacokinetic modeling of a ternary mixture of alkyl benzenes in rats and humans. Toxicol Appl Pharmacol 144(1):120–134. 10.1006/taap.1996.8096.9169076
Taylor DC, Brown DM, Keeble R, 1974. Metabolism of chloroform. II. A sex difference in the metabolism of [14C]chloroform in mice. Xenobiotica 4:165–174.
Templin MV, Jamison KC, Wolf DC, 1996a. Comparison of chloroform-induced toxicity in the kidneys, liver, and nasal passages of male Osborne-Mendel and F-344 rats. Cancer Lett 104(1):71–78. 10.1016/0304-3835(96)04234-6.8640749
Templin MV, Larson JL, Butterworth BE, 1996b. A 90-day chloroform inhalation study in F-344 rats: profile of toxicity and relevance to cancer studies. Fundam Appl Toxicol 32(1):109–125. 10.1006/faat.1996.0113.8812246
Templin MV, Jamison KC, Sprankle CS, 1996c. Chloroform-induced cytotoxicity and regenerative cell proliferation in the kidneys and liver of BDF1 mice. Cancer Lett 108(2):225–231. 10.1016/s0304-3835(96)04427-8.8973599
Templin MV, Constan AA, Wolf DC, 1998. Patterns of chloroform-induced regenerative cell proliferation in BDF1 mice correlate with organ specificity and dose-response of tumor formation. Carcinogenesis 19(1):187–193. 10.1093/carcin/19.1.187.9472711
Teschke K, Ahrens W, Andersen A, 1999. Occupational exposure to chemical and biological agents in the nonproduction departments of pulp, paper, and paper product mills: an international study. Am Ind Hyg Assoc J 60(1):73–83. 10.1080/00028899908984424.10028618
Testai E, Gramenzi F, Di MS, 1987. Oxidative and reductive biotransformation of chloroform in mouse liver microsomes. Arch Toxicol Suppl 11:42–44. 10.1007/978-3-642-72558-6_6.3477199
Testai E, DiMarzio S, Vittiozzi L. 1990. Multiple activation of chloroform in hepatic microsomes from uninduced B6C3F1 mice. Toxicol Appl Pharmacol 104:496–503.2385839
Testai E, Di Marzio S, di Domenico A, 1995. An in vitro investigation of the reductive metabolism of chloroform. Arch Toxicol 70(2):83–88. 10.1007/bf02733667.8773179
Testai E, De Curtis V, Gemma S, 1996. The role of different cytochrome P450 isoforms in in vitro chloroform metabolism. J Biochem Toxicol 11(6):305–312. 10.1002/(sici)1522-7146(1996)11:6<305::aid-jbt6>3.0.co;2-o.9176742
Teuschler LK, Gennings C, Stiteler WM, 2000. A multiple-purpose design approach to the evaluation of risks from mixtures of disinfection by-products. Drug Chem Toxicol 23(1):307–321. 10.1081/dct-100100117.10711404
Teuschler LK, Rice GE, Wilkes CR, 2004. A feasibility study of cumulative risk assessment methods for drinking water disinfection by-product mixtures. J Toxicol Environ Health A 67(8–10):755–777. 10.1080/15287390490428224.15192867
Thompson DJ, Warner SD, Robinson VB. 1974. Teratology studies on orally administered chloroform in the rat and rabbit. Toxicol Appl Pharmacol 29(3):348–357. 10.1016/0041-008x(74)90107-0.4283698
Thrall KD, Gies RA, Muniz J, 2002. Route-of-entry and brain tissue partition coefficients for common superfund contaminants. J Toxicol Environ Health A 65(24):2075–2086. 10.1080/00984100290071838.12515587
Toraason M, Breitenstein MJ, Wey HE. 1992. Reversible inhibition of intercellular communication among cardiac myocytes by halogenated hydrocarbons. Fundam Appl Toxicol 18(1):59–65.1601210
Torkelson TR, Oyen F, Rowe VK. 1976. The toxicity of chloroform as determined by single and repeated exposure of laboratory animals. Am Ind Hyg Assoc J 37(12):697–705. 10.1080/0002889768507551.1008029
Townsend E. 1939. Acute yellow atrophy of the liver. Two cases, with one recovery. Br Med J 2:558–560.20782634
Travis CC, Holton GA, Etnier EL, 1986. Assessment of inhalation and ingestion population exposures from incinerated hazardous wastes. Environ Int 12:533–540.
Trevisan A, Chiara F, Mongillo M, 2012. Sex-related differences in renal toxicodynamics in rodents. Expert Opin Drug Metab Toxicol 8(9):1173–1188. 10.1517/17425255.2012.698262.22769852
TRI22. 2024. Chloroform. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency. https://enviro.epa.gov/triexplorer/tri_release.chemical. May 8, 2024.
Tsai WT. 2017. Fate of chloromethanes in the atmospheric environment: Implications for human health, ozone formation and depletion, and global warming impacts. Toxics 5(4):23. 10.3390/toxics5040023.29051455
Tsuruta H. 1975. Percutaneous absorption of organic solvents. 1. Comparative study of the in vivo percutaneous absorption of chlorinated solvents in mice. Ind Health 13:227–236.
Tumasonis CF, McMartin DN, Bush B. 1985. Lifetime toxicity of chloroform and bromodichloromethane when administered over a lifetime in rats. Ecotoxicol Environ Safety 9(2):233–240. 10.1016/0147-6513(85)90026-0.3987603
Tumasonis CF, McMartin DN, Bush B. 1987. Toxicity of chloroform and bromodichloromethane when administered over a lifetime in rats. J Environ Pathol Toxicol Oncol 7:55–64.
Uchrin CG, Mangels G. 1986. Chloroform sorption to New Jersey coastal plain groundwater aquifer solids. Environ Toxicol Chem 5:339–343.
Uehleke H, Werner T, Greim H, 1977. Metabolic activation of haloalkanes and tests in vitro for mutagenicity. Xenobiotica 7(7):393–400. 10.3109/00498257709035798.329590
USGS. 2003. A national survey of methyl tert-butyl ether and other volatile organic compounds in drinking-water sources: Results of the random survey. Denver, CO: U.S. Geological Survey. Water-Resources Investigations Report 02–4079. https://pubs.usgs.gov/wri/2002/4079/wrir20024079.pdf. February 14, 2023.
USGS. 2004. Chloroform in the hydrologic system - sources, transport, fate, occurrence, and effects on human health and aquatic organisms. Reston, VA: U.S. Geological Survey. Scientific Investigations Report 2004–5137. https://pubs.usgs.gov/sir/2004/5137/sir20045137.pdf. January 26, 2023.
USGS. 2006. Sources and occurrence of chloroform and other trihalomethanes in drinking-water supply wells in the United States, 1986–2001. Reston, VA: U.S. Geological Survey. Scientific Investigations Report 2006–5015. https://pubs.usgs.gov/sir/2006/5015/sir2006-5015.pdf. January 26, 2023.
USGS. 2015a. The quality of our Nation’s waters: Water quality in principal aquifers of the United States, 1991–2010. U.S. Geological Survey. Circular 1360. 10.3133/cir1360.
USGS. 2015b. The quality of our Nation’s waters: Water quality in principal aquifers of the United States, 1991–2010: Appendices 1–3. U.S. Geological Survey. Circular 1360. https://pubs.er.usgs.gov/publication/cir1360. February 6, 2023.
USITC. 2023. Import for consumption: Chloroform. U.S. International Trade Commission. https://dataweb.usitc.gov/. October 20, 2023.
Van Abbé, N. J., Green TJ, Jones E, 1982. Bacterial mutagenicity studies on chloroform in vitro. Food Chem Toxicol 20(5):557–561. 10.1016/s0278-6915(82)80064-1.6754557
van Beelen P, van Vlaardingen PLA, Fleuren-Kemila AK. 1994. Toxic effects of pollutants on the mineralization of chloroform in river sediments. Ecotoxicol Environ Safety 27(2):158–167.7516282
Van Dyke RA, Chenoweth MB, Poznak AV. 1964. Metabolism of volatile anesthetics. I. Conversion in vivo of several anesthetics to 14CO2 and chloride. Biochem Pharmacol 13:1239–1247.14222521
van Vlaardingen PLA, van Beelen P. 1992. Toxic effects of pollutants on methane production in sediments of the River Rhine. Bull Environ Contam Toxicol 49(5):780–786.1392319
Varma MM, Ampy FR, Verma K, 1988. In vitro mutagenicity of water contaminants in complex mixtures. J Appl Toxicol 8:243–248.3183290
Vasilev D, Havel D, Liebscher S, 2021. Three water restriction schedules used in rodent behavioral tasks transiently impair growth and differentially evoke a stress hormone response without causing dehydration. eNeuro 8(6):0424. 10.1523/ENEURO.0424-21.2021.
Veith GD, Macek KJ, Petrocelli SR, 1980. An evaluation of using partition coefficients and water solubility to estimate bioconcentration factors for organic chemicals in fish. In: Aquatic toxicology. American Society for Testing and Materials, 116–129.
Vendura K, Strauch H, Pragst F, 1996. [Fatal chloroform poisoning with subsequent crime]. Archiv fur Kriminologie 198(3–4):83–88. (German)9005805
Vickstrom KE, Azizian MF, Semprini L. 2017. Transformation of carbon tetrachloride and chloroform by trichloroethene respiring anaerobic mixed cultures and supernatant. Chemosphere 182:65–75. 10.1016/j.chemosphere.2017.04.139.28494362
Villanueva CM, Gracia-Lavedan E, Ibarluzea J, 2011. Exposure to trihalomethanes through different water uses and birth weight, small for gestational age, and preterm delivery in Spain. Environ Health Perspect 119(12):1824–1830. 10.1289/ehp.1002425.21810554
Villanueva CM, Gracia-Lavedan E, Bosetti C, 2017. Colorectal cancer and long-term exposure to trihalomethanes in drinking water: A multicenter case-control study in Spain and Italy. Environ Health Perspect 125(1):56–65. 10.1289/EHP155.27383820
Villanueva CM, Gracia-Lavedan E, Julvez J, 2018. Drinking water disinfection by-products during pregnancy and child neuropsychological development in the INMA Spanish cohort study. Environ Int 110:113–122. 10.1016/j.envint.2017.10.017.29107351
Villanueva CM, Espinosa A, Gracia-Lavedan E, 2021. Exposure to widespread drinking water chemicals, blood inflammation markers, and colorectal cancer. Environ Int 157:106873. 10.1016/j.envint.2021.106873.34543938
Vittozzi L, Gemma S, Sbraccia M, 2000. Comparative characterization of CHCl_3_ metabolism and toxicokinetics in rodent strains differently susceptible to chloroform-induced carcinogenicity. Environ Toxicol Chem 8(2):103–110. 10.1016/s1382-6689(00)00031-4.
Vittozzi L, Gemma S, Sbraccia M, 2001. Erratum to "Comparative characterization of CHCl_3_ metabolism and toxicokinetics in rodent strains differently susceptible to chloroform-induced carcinogenicity" [Environ. Toxicol. Pharmacol. 8 (2000) 103–110]. Environ Toxicol Pharmacol 9(4):193. 10.1016/s1382-6689(00)00072-7.11292583
Vlaanderen J, van Veldhoven K, Font-Ribera L, 2017. Acute changes in serum immune markers due to swimming in a chlorinated pool. Environ Int 105:1–11. 10.1016/j.envint.2017.04.009.28478232
Vlad IA, Armstrong J, Gault A. 2014. A painless burn: systemic toxicity after dermal exposure to chloroform. Emerg Med Australas 26(6):648–649. 10.1111/1742-6723.12304.25330841
Wada K, Fukuyama T, Nakashima N, 2015. Assessment of the in vivo genotoxicity of cadmium chloride, chloroform, and D,L-menthol as coded test chemicals using the alkaline comet assay. Mutat Res 786–788:114–119. 10.1016/j.mrgentox.2015.04.004.
Wallace CJ. 1950. Hepatitis and nephrosis due to cough syrup containing chloroform. Calif Med 731:442–443.
Wallace LA. 1997. Human exposure and body burden for chloroform and other trihalomethanes. Crit Rev Environ Sci Technol 27(2):113–194. 10.1080/10643389.1997.10737059.
Wallace LA, Pellizzari ED, Hartwell TD, 1987a. The TEAM study: Personal exposures to toxic substances in air, drinking water, and breath of 400 residents of New Jersey, North Carolina, and North Dakota. Environ Res 43:290–307.3608934
Wallace LA, Hartwell TD, Perritt K, 1987b. The influence of personal activities on exposure to volatile organic compounds. In: Seifert B, Esdorn H, Fischer M, , eds. Indoor Air '87: proceedings of the 4^th^ International Conference on Indoor Air Quality and Climate, Berlin (West) 17–21 August 1987. Berlin, Germany: Institute of Water, Soil, and Air Hygiene, 117–121.
Wang PY, Kaneko T, Tsukada H, 1994. Dose and route dependency of metabolism and toxicity of chloroform in ethanol-treated rats. Arch Toxicol 69:18–23.7717850
Wang PY, Kaneko T, Sato A, 1995. Dose and route dependent alteration of metabolism and toxicity of chloroform in fed and fasting rats. Toxicol Appl Pharm 135(1):119–126.
Wang PY, Kaneko T, Tsukada H, 1997. Dose- and route-dependent alterations in metabolism and toxicity of chemical compounds in ethanol-treated rats: difference between highly (chloroform) and poorly (carbon tetrachloride) metabolized hepatotoxic compounds. Toxicol Appl Pharmacol 142(1):13–21. 10.1006/taap.1996.8025.9007029
Wang Z, Hall SD, Maya JF, 2003. Diabetes mellitus increases the in vivo activity of cytochrome P450 2E1 in humans. Br J Clin Pharmacol 55(1):77–85. 10.1046/j.1365-2125.2003.01731.x.12534643
Wei C, Chen Y, Yang Y, 2022. Assessing volatile organic compounds exposure and prostate-specific antigen: National Health and Nutrition Examination Survey, 2001–2010. Front Public Health 10:957069. 10.3389/fpubh.2022.957069.35968491
Wei C, Pan Y, Zhang W, 2023. Comprehensive analysis between volatile organic compound (VOC) exposure and female sex hormones: a cross-sectional study from NHANES 2013–2016. Environ Sci Pollut Res Int 30(42):95828–95839. 10.1007/s11356-023-29125-0.37561291
Weir LR, Schenck E, Meakin J, 2005. Biophotonic imaging in HO-1.luc transgenic mice: real-time demonstration of gender-specific chloroform induced renal toxicity. Mutat Res 574(1–2):67–75. 10.1016/j.mrfmmm.2005.01.023.15914208
Weisel CP, Alimokhtari S, Sanders PF. 2008. Indoor air VOC concentrations in suburban and rural New Jersey. Environ Sci Technol 42(22):8231–8238. 10.1021/es8005223.19068799
Whitaker AM, Jones CS. 1965. Report of 1500 chloroform anesthetics administered with a precision vaporizer. Anesth Analg 44:60–65.14264816
White AE, Takehisa S, Eger EI, 1979. Sister chromatid exchanges induced by inhaled anesthetics. Anesthesiology 50:426–430.453561
WHO. 2004. Chloroform. Geneva: World Health Organization. Concise International Chemical Assessment Document 58. http://apps.who.int/iris/bitstream/handle/10665/42884/9241530588.pdf;jsessionid=386B27164E2523 1BA273DE2D7C2AA226?sequence=1. February 6, 2023.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. https://www.who.int/publications/i/item/9789289002134. April 25, 2012.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Wickliffe JK, Stock TH, Howard JL, 2020. Increased long-term health risks attributable to select volatile organic compounds in residential indoor air in southeast Louisiana. Sci Rep 10(1):21649. 10.1038/s41598-020-78756-7.33303920
Williams AL, Bates CA, Pace ND, 2018. Impact of chloroform exposures on reproductive and developmental outcomes: A systematic review of the scientific literature. Birth Defects Res 110(17):1267–1313. 10.1002/bdr2.1382.30350414
Wilson J, Enfield CG, Dunlap WJ, 1981. Transport and fate of selected organic pollutants in a sandy soil. J Environ Qual 10:501–506.
Windham GC, Waller K, Anderson M, 2003. Chlorination by-products in drinking water and menstrual cycle function. Environ Health Perspect 111(7):935–941; discussion A409. 10.1289/ehp.5922.12782495
Withey JR, Collins BT, Collins PG. 1983. Effect of vehicle on the pharmacokinetics and uptake of four halogenated hydrocarbons from the gastrointestinal tract of the rat. J Appl Toxicol 3:249–253.6662999
WMO. 2018. Update on ozone-depleting substances (ODSs) and other gases of interest to the Montreal Protocol. Scientific assessment of ozone depletion: 2018. Geneva, Switzerland: World Meteorological Organization. 1.1–1.87. Global Ozone Research and Monitoring Project—Report No. 58. https://ozone.unep.org/sites/default/files/2019-05/SAP-2018-Assessment-report.pdf. February 3, 2023.
Wolf CR, Mansuy D, Nastainczyk W, 1977. The reduction of polyhalogenated methanes by liver microsomal cytochrome P-450. Mol Pharmacol 13:698–705.18662
Wolfe J, Kandra J, Engdahl L, 2020. Domestic workers chartbook: A comprehensive look at the demographics, wages, benefits, and poverty rates of the professionals who care for our family members and clean our homes. Washington, DC: Economic Policy Institute. https://www.epi.org/publication/domestic-workers-chartbook-a-comprehensive-look-at-the-demographics-wages-benefits-and-poverty-rates-of-the-professionals-who-care-for-our-family-members-and-clean-our-homes/. October 20, 2023.
Wood JA, Porter ML. 1987. Hazardous pollutants in class II landfills. J Air Pollut Control Assoc 37:609–615.
WQP. 2024. Chloroform. Water Quality Portal database. National Water Quality Monitoring Council. https://www.waterqualitydata.us/. May 8, 2024.
Wright JM, Schwartz J, Dockery DW. 2004. The effect of disinfection by-products and mutagenic activity on birth weight and gestational duration. Environ Health Perspect 112(8):920–925. 10.1289/ehp.6779.15175183
Xu X, Weisel CP. 2005. Human respiratory uptake of chloroform and haloketones during showering. J Expo Anal Environ Epidemiol 15(1):6–16. 10.1038/sj.jea.7500374.15138448
Xu X, Mariano TM, Laskin JD, 2002. Percutaneous absorption of trihalomethanes, haloacetic acids, and haloketones. Toxicol Appl Pharmacol 184(1):19–26.12392965
Yamamoto S, Kasai T, Matsumoto M, 2002. Carcinogenicity and chronic toxicity in rats and mice exposed to chloroform by inhalation. J Occup Health 44(5):283–293. 10.1539/joh.44.283.
Yan Z, Qian H, Yao J, 2024. Mechanistic insight into the role of typical microplastics in chlorination disinfection: Precursors and adsorbents of both MP-DOM and DBPs. J Hazard Mater 462:132716. 10.1016/j.jhazmat.2023.132716.37820530
Yang Y, Xu X, Georgopoulos PG. 2010. A Bayesian population PBPK model for multiroute chloroform exposure. J Expo Sci Environ Epidemiol 20(4):326–341. 10.1038/jes.2009.29.19471319
Yoshida T, Andoh K, Fukuhara M. 1999. Estimation of absorption of trihalomethanes and carbon tetrachloride in low-level exposure by inhalation pharmacokinetic analysis in rats. Arch Environ Contam Toxicol 36(3):347–354. 10.1007/s002449900481.10047604
Zaganjor I, Luben TJ, Desrosiers TA, 2020. Maternal exposure to disinfection by-products and risk of hypospadias in the National Birth Defects Prevention Study (2000–2005). Int J Environ Res Public Health 17(24):9564. 10.3390/ijerph17249564.33371304
Zeng Q, Li M, Xie SH, 2013. Baseline blood trihalomethanes, semen parameters and serum total testosterone: a cross-sectional study in China. Environ Int 54:134–140. 10.1016/j.envint.2013.01.016.23454109
Zeng Q, Chen YZ, Xu L, 2014. Evaluation of exposure to trihalomethanes in tap water and semen quality: a prospective study in Wuhan, China. Reprod Toxicol 46:56–63. 10.1016/j.reprotox.2014.03.005.24632126
Zepp RG, Braun AM, Hoigne J, 1987. Photoproduction of hydrated electrons from natural organic solutes in aquatic environments. Environ Sci Technol 21:485–490.22296137
Zhang L, Xu L, Zeng Q, 2012. Comparison of DNA damage in human-derived hepatoma line (HepG2) exposed to the fifteen drinking water disinfection byproducts using the single cell gel electrophoresis assay. Mutat Res 741(1–2):89–94. 10.1016/j.mrgentox.2011.11.004.22108252
Zhang J, Wang W, Pei Z, 2021. Mutagenicity assessment to pesticide adjuvants of toluene, chloroform, and trichloroethylene by Ames test. Int J Environ Res Public Health 18(15):8095. 10.3390/ijerph18158095.34360388
Zhang Y, Feng Y, He M, 2023. Association of blood trihalomethane concentrations with hypertension in US adults: A nationwide cross-sectional study. Sci Total Environ 904:166712. 10.1016/j.scitotenv.2023.166712.37657551
Zhou Y, Wu HJ, Zhang YH, 2011. Ionic mechanisms underlying cardiac toxicity of the organochloride solvent trichloromethane. Toxicology 290(2–3):295–304. 10.1016/j.tox.2011.10.009.22024336
Zhu SM, Li C, Xu JJ, 2022. Exposure to chloramine and chloroform in tap water and adverse perinatal outcomes in Shanghai. Int J Environ Res Public Health 19(11):6508. 10.3390/ijerph19116508.35682093