# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Rae T. Benedict, Ph.D. (Lead)
  Custodio Muianga, M.P.H., Ph.D.
  Mohammad Shoeb, Ph.D.
- ATSDR, Office of Innovation and Analytics,
  Toxicology Section, Atlanta, GA
- Kimberly Zaccaria, Ph.D., D.A.B.T.
  Zachariah Guerrette, Ph.D., D.A.B.T.
  Mario Citra, Ph.D.
  Nathan Craig, Ph.D.
  Deborah Herber, Ph.D.
  Jessica Myers, Ph.D.
  Marc Odin, Ph.D.
  Savannah Sierco, M.S.
  SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

- Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

- ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Research and Development; EPA, Office of Water.

## PEER REVIEWERS

1. Udayan Apte, Ph.D., D.A.B.T., FAASLD; Professor, Department of Pharmacology Toxicology and Therapeutics; Associate Director, KU Liver Center; University of Kansas Medical Center; Kansas City, Kansas
2. Georg Thomas Wondrak, Ph.D.; Professor, Department of Pharmacology and Toxicology; Professor, Cancer Biology; Director of Graduate Studies, RK Coit College of Pharmacy; University of Arizona; Tucson, Arizona
3. Jerry Campbell, Ph.D.; Managing Consultant; Ramboll; Raleigh, North Carolina
4. Nick M. Filipov, Ph.D., ATS; Lalita and Raghubir Sharma Distinguished Professor in Toxicology; Director, Interdisciplinary Toxicology Program; Department of Physiology and Pharmacology; College of Veterinary Medicine; University of Georgia; Athens, Georgia; peer-review of the study by DHA (2022) only
5. Jason Cannon, Ph.D.; Acting Head and Professor of Toxicology; School of Health Sciences; Assistant Vice Provost for Interdisciplinary Graduate Programs; Purdue University; West Lafayette, Indiana; peer-review of the study by DHA (2022) only

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile's final content. The responsibility for the content of this profile lies with ATSDR.