# VERSION HISTORY

Date | Description
October 2024 | Final toxicological profile released
January 2024 | Draft for public comment toxicological profile released
September 1997 | Final toxicological profile released
April 1993 | Final toxicological profile released
January 1989 | Final toxicological profile released