# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding chloroform in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for chloroform.

Table 7-1 Regulations and Guidelines Applicable to Chloroform

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated | IRIS 2001
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018b
| 1-Day health advisory (10-kg child) | 4 mg/L
| 10-Day health advisory (10-kg child) | 4 mg/L
| DWEL | 0.35 mg/L
| Lifetime health advisory | 0.07 mg/L
| National primary drinking water regulations | | EPA 2023e
| Total trihalomethanes—MCL | 0.080 mg/L
| Chloroform—MCLG | 0.07 mg/L
| RfD | 0.01 mg/kg/day^a^ | IRIS 2001
WHO | Drinking water quality guidelines | | WHO 2022
| Guideline value | 0.3 mg/L
| TDI | 15 μg/kg body weight
FDA | Substances added to food^b^ | Approved for some indirect additives uses | FDA 2024a
| Allowable level in bottled water | | FDA 2023
| Total trihalomethanes | 0.080 mg/L
Cancer
HHS | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2021
EPA | Carcinogenicity classification | Likely to be carcinogenic to humans^c,d^ | IRIS 2001
| IUR | 2.3×10^−5^ per μg/m^3^ ^e^
IARC | Carcinogenicity classification | Group 2B^f^ | IARC 1999
Occupational
OSHA | PEL (ceiling limits) for general industry and construction | 50 ppm (240 mg/m^3^) | OSHA 2022a, 2022c
| PEL (8-hour TWA) for shipyards | 50 ppm (240 mg/m^3^) | OSHA 2022b
NIOSH | STEL (60-minute) | 2 ppm (9.78 mg/m^3^)^h^ | NIOSH 2019
| IDLH | 500 ppm^h^
Emergency Criteria
EPA | AEGLs-air | | EPA 2018c
| AEGL 1^i^ | Not recommended
| AEGL 2^i^
| 10-minute | 120 ppm
| 30-minute | 80 ppm
| 60-minute | 64 ppm
| 4-hour | 40 ppm
| 8-hour | 29 ppm
| AEGL 3^i^
| 10-minute | 4,000 ppm
| 30-minute | 4,000 ppm
| 60-minute | 3,200 ppm
| 4-hour | 2,000 ppm
| 8-hour | 1,600 ppm
DOE | PACs-air | | DOE 2018a
| PAC-1^j^ | 2 ppm
| PAC-2^j^ | 64 ppm
| PAC-3^j^ | 3,200 ppm

a RfD for noncancer effect also considered to be protective against cancer risk (IRIS 2001).

b The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS.”

c Under the EPA’s 1986 guidelines for carcinogen risk assessment (EPA 1986), Group B2 contains agents classified as probable human carcinogens.

d Using draft revised guidelines for carcinogen risk assessment (EPA 1996), which were finalized later (EPA 2005), chloroform was classified as: (1) likely to be carcinogenic to humans by all routes of exposure under high-exposure conditions that lead to cytotoxicity and regenerative hyperplasia in susceptible tissues, and (2) not likely to be carcinogenic to humans by any route of exposure under exposure conditions that do not cause cytotoxicity and cell regeneration.

e EPA reported that this IUR was developed in 1987 and does not incorporate newer data or the updated EPA cancer assessment guidelines. Per EPA, the methodology used to derive the IUR has two shortcomings: (1) it utilized a route-to-route extrapolation approach that did not employ a PBPK model, and (2) it incorporated a linear extrapolation approach for dose-response that implicitly assumes a risk of cancer at all nonzero exposures to chloroform (i.e., no threshold). EPA’s mode-of-action analysis added in 2001, however, concluded that for cancer, chloroform exhibits a “threshold” by all routes of exposure. Thus, a chloroform dose exists that does not elicit cytotoxicity and presents no cancer risk. Therefore, the assumption underlying EPA’s IUR dose-response approach (linear extrapolation with no threshold) is inconsistent with EPA’s subsequent mode-of-action analysis.

f Group 2B: possibly carcinogenic to humans.

g Value not to be exceeded at any time.

h NIOSH considers the compound to be a potential occupational carcinogen.

i Definitions of AEGL terminology are available from EPA (2018d).

j Definitions of PAC terminology are available from DOE (2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FAO = Food and Agriculture Organization; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; IUR = inhalation unit risk; JECFA = Joint FAO/WHO Expert Committee on Food Additives; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PBPK = physiologically based pharmacokinetic; PEL = permissible exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure limit; TDI = tolerable daily intake; TWA = time-weighted average; WHO = World Health Organization