# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of chloroform is presented in Table 4-1.

Table 4-1 Chemical Identity of Chloroform

Characteristic | Information | Reference
Chemical name | Chloroform, trichloromethane | NLM 2023
Synonym(s) and registered trade name(s) | Chloroform, methenyl trichloride, methane trichloride, methyl trichloride, Freon 20, R 20, R 20 refrigerant | NLM 2023
Chemical formula | CHCl3 | NLM 2023
SMILES | C(Cl)(Cl)Cl | NLM 2023
Chemical structure | [image] | NLM 2023
CAS Registry Number | 67-66-3 | NLM 2023

CAS = Chemical Abstracts Service; SMILES = Simplified Molecular Input Line Entry System

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of chloroform is presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of Chloroform

Property | Information | Reference
Molecular weight | 119.37 g/mol | NLM 2023
Color | Colorless | NLM 2023
Physical state | Liquid | NLM 2023
Melting point | −63.2°C | NLM 2023
| −63.47°C
Boiling point | 61.12°C | NLM 2023
Density at 20°C | 1.484 g/cm^3^ | NLM 2023
| 1.4832 g/cm^3^
Density at 25°C | 1.4778 g/cm^3^
Vapor density (air = 1) | 4.12 | NLM 2023
Odor | Pleasant, ethereal, nonirritating, sweet | NLM 2023
Odor threshold:
Water | 2.4 ppm (w/v) | NLM 2023
Air | 51–307 ppm (w/v) | NLM 2023
Solubility:
Water at 25°C | 7,950 mg/L | NLM 2023
Organic solvents | Miscible with principal organic solvents, alcohol, benzene, ether, petroleum ether, carbon tetrachloride, carbon disulfide, oils | NLM 2023
Partition coefficients:
Log K_ow_ | 1.97 | NLM 2023
Log K_oc_ | 1.5–2.29 | NLM 2023
Vapor pressure:
at 20°C | 159 mm Hg | Boublik et al. 1984
at 25°C | 197 mm Hg | NLM 2023
Henry’s law constant:
at 20°C | 3.00×10^−3^ atm-m^3^/mol | Nicholson et al. 1984
at 24.8°C | 3.67×10^−3^ atm-m^3^/mol | Gossett 1987; NLM 2023
Autoignition temperature | >1,000°C | Deshon 1979
| Not flammable | NLM 2023
Flashpoint | None | Deshon 1979
Flammability limits | No data
Conversion factors^a^ | 1 ppm (v/v)=4.95 mg/m^3^
| 1 mg/m^3^=0.20 ppm (v/w)
Explosive limits | No data

a An atmospheric pressure of 1 atm is assumed and a temperature of 20°C.