# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR CHLOROFORM

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to chloroform, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to chloroform:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Asses the Risk Of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to chloroform. The inclusion criteria used to identify relevant studies examining the health effects of chloroform are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species
Human^a^
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects^b^
Renal effects^b^
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer

a Inclusion criteria were refined for human studies as described in Section B.1.1, Prioritization of Human Data.

b Inclusion criteria were refined for animal studies evaluating hepatic and renal effects as described in Section B.1.1, Prioritization of Animal Data.

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen were conducted to identify studies examining the health effects of chloroform. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the Draft Toxicological Profile for Chloroform released for public comment in 2024; thus, the literature search was restricted to studies published between September 2020 and February 2024. See Appendix B for the databases searched and the search strategy.

A total of 10,843 and 4,744 records relevant to all sections of the toxicological profile were identified in the initial and update literature search, respectively (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of chloroform.

Title and Abstract Screen. In the Title and Abstract Screen step, 107 documents (inclusive of both literature searches) were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 191 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 191 documents (258 studies), 88 documents (137 studies) were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted from Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for Chloroform and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Sections 2.2–2.19 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-1, 2-2, and 2-3, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for chloroform identified in human and animal studies are presented in Tables C-4 and C-5, respectively. Available human studies evaluating noncancer effects include numerous case studies and case-series reports, a limited number of occupational exposure studies, and general population exposure studies (primarily focusing on exposure to chloroform as a disinfection byproduct in residential water supplies). When evaluated together, these studies suggest that the respiratory, hepatic, renal, and neurological systems and the developing fetus may be susceptible to chloroform toxicity. Animal studies evaluated a comprehensive set of endpoints following inhalation and oral exposure; dermal studies were limited to two acute-duration studies evaluating a limited number of endpoints. Respiratory and hepatic effects were considered sensitive outcomes following inhalation exposure in animals, and hepatic, renal, and developmental effects were considered sensitive outcomes following oral exposure in animals (i.e., effects were observed at low concentrations or doses; see Tables 2-1 and 2-2 and Figures 1-3, 1-4, 2-1, and 2-2 for further detail). Based on effects noted in human and animal studies, epidemiological and experimental studies examining these respiratory, hepatic, renal, neurological, and developmental outcomes were carried through to Steps 4–8 of the systematic review. Case studies and case-series reports were not included in the formal systematic review due to inherent high risk of bias and low confidence based on study design. However, consistent findings from numerous case studies were considered during the adjustment of the confidence rating (with regards to consistency and/or severity of observed effects). There were 136 studies (published in 88 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Chloroform Evaluated in Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort | | | 1 | 2 | | | 3 | 1 | | | | 1 | 2 | | | 1
Cohort | | | 1 | 2 | | | 1 | 0 | | | | 1 | 2 | | | 1
Case-control | | 6 | 4 | 4 | 1 | 3 | 13 | 3 | | | | 1 | 3 | | 1 | | 10
Case-control | | 6 | 4 | 4 | 1 | 3 | 13 | 3 | | | | 1 | 3 | | 0 | | 2
Population | | 1 | | | | | 1 | 1 | | | | 1
Population | | 0 | | | | | 0 | 0 | | | | 0
Case series | | | 2 | 3 | 1 | | 4 | | | | | | 2
Case series | | | 2 | 3 | 1 | | 3 | | | | | | 2
Oral studies
Cohort | | | | | | | | | | | | | | 6 | 15 | | 3
Cohort | | | | | | | | | | | | | | 2 | 3 | | 3
Case-control | | 5 | 4 | 4 | 2 | 1 | 12 | 4 | | | | 1 | 9 | 3 | 6 | 1 | 8
Case-control | | 5 | 4 | 4 | 2 | 1 | 12 | 4 | | | | 1 | 9 | 0 | 3 | 1 | 3
Population | | | | | 1 | | 1 | 1 | | | | | | 2 | 2 | 1 | 2
Population | | | | | 1 | | 1 | 1 | | | | | | 0 | 1 | 1 | 0
Case series
Dermal studies
Cohort
Case-control | | | | 1 | | | 1 | | 6 | | | | 1
Case-control | | | | 1 | | | 1 | | 6 | | | | 1
Population
Case series
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-4 Overview of the Health Outcomes for Chloroform Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 14 | 9 | | | | | 11 | 11 | | | | 6 | 8 | 7 | 6
Acute-duration | 9 | 8 | | | | | 10 | 9 | | | | 3 | 8 | 5 | 6
Intermediate-duration | 15 | 10 | 4 | 4 | 2 | | 15 | 15 | 2 | 4 | 4 | 6 | 4 | 6
Intermediate-duration | 7 | 6 | 0 | 0 | 0 | 0 | 14 | 12 | 0 | 0 | 0 | 0 | 0 | 0
Chronic-duration | 3 | 2 | 2 | 2 | 2 | 2 | 2 | 3 | 2 | 2 | 2 | 2 | 2 | 2 | | | 3
Chronic-duration | 2 | 2 | 0 | 0 | 0 | 0 | 2 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | | | 1
Oral studies
Acute-duration | 21 | 3 | 1 | 3 | 3 | | 22 | 18 | 2 | 1 | | 1 | 7 | 3 | 5 | | 1
Acute-duration | 12 | 3 | 1 | 1 | 2 | | 19 | 14 | 2 | 1 | | 1 | 7 | 3 | 4
Intermediate-duration | 22 | 8 | 4 | 8 | 6 | 2 | 19 | 16 | | 2 | 5 | 6 | 7 | 5 | 4 | | 7
Intermediate-duration | 8 | 3 | 1 | 1 | 1 | 0 | 15 | 6 | | 0 | 1 | 1 | 1 | 1 | 2 | | 3
Chronic-duration | 10 | 3 | 3 | 2 | 4 | 2 | 4 | 7 | 2 | 1 | 2 | 2 | 4 | 3 | | | 9
Chronic-duration | 4 | 1 | 1 | 0 | 0 | 0 | 3 | 3 | 0 | 0 | 0 | 0 | 0 | 0 | | | 7
Dermal studies
Acute-duration | 1 | | | | | | 1 | 1 | 2
Acute-duration | 1 | | | | | | 0 | 1 | 2
Intermediate-duration
Chronic-duration
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed by reviewers using the guidelines provided in OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-6, C-7, and C-8, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias
Were the comparison groups appropriate?
Confounding bias
Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Performance bias
Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Performance bias
Were experimental conditions identical across study groups?
Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of chloroform health effects studies (observational epidemiology and animal experimental studies) are presented in Tables C-9 and C-10, respectively.

Table C-8 Summary of Risk of Bias Assessment for Chloroform—Observational Epidemiology Studies

| Risk of bias criteria and ratings
| Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?^*^ | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?^*^ | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Respiratory effects
Cross-sectional studies
Font-Ribera et al. 2010 | + | − | + | + | ++ | ++ | Second
Outcome: Hepatic effects
Cohort studies
Aiking et al. 1994 | + | − | + | + | − | ++ | Second
Bomski et al. 1967 | + | − | − | − | − | − | Third
Challen et al. 1958 | + | + | + | + | + | + | First
Li et al. 1993 | + | − | − | + | − | − | Second
Outcome: Renal effects
Cohort studies
Aiking et al. 1994 | + | − | + | + | − | ++ | Second
Li et al. 1993 | + | − | − | + | − | − | Second
Outcome: Neurological effects
Cohort studies
Challen et al. 1958 | + | + | + | + | − | + | Second
Li et al. 1993 | + | − | − | + | + | − | Second
Outcome: Developmental effects
Cohort studies
Botton et al. 2015 | + | − | ++ | + | + | ++ | Second
Cao et al. 2016 | + | − | ++ | ++ | + | ++ | Second
Costet et al. 2011 | + | − | ++ | + | + | ++ | Second
Dodds and King 2001 | + | − | − | − | + | ++ | Second
Grazuleviciene et al. 2011 | + | − | ++ | ++ | + | ++ | Second
Grazuleviciene et al. 2013 | + | − | ++ | ++ | + | ++ | Second
Hinckley et al. 2005 | + | − | ++ | − | + | ++ | Second
Hoffman et al. 2008 | + | − | ++ | − | + | ++ | Second
Liu et al. 2021 | + | − | ++ | + | + | + | Second
Rivera-Núñez and Wright 2013 | + | + | + | − | + | ++ | Second
Sun et al. 2020 | + | − | ++ | + | + | ++ | Second
Villanueva et al. 2018 | + | − | ++ | ++ | ++ | ++ | Second
Villanueva et al. 2011 | − | − | ++ | − | + | ++ | Second
Zhu et al. 2022 | + | − | ++ | − | + | ++ | Second
Population studies
Porter et al. 2005 | + | − | ++ | − | + | − | Second
Wright et al. 2004 | + | − | ++ | − | + | ++ | Second
Case-control studies
Bonou et al. 2017 | ++ | − | ++ | + | + | ++ | Second
Kaufman et al. 2018 | ++ | − | ++ | − | ++ | ++ | Second
Kaufman et al. 2020 | ++ | − | ++ | − | ++ | ++ | Second
Kramer et al. 1992 | − | − | ++ | − | − | − | Third
Levallois et al. 2012 | + | − | ++ | + | + | ++ | Second
Summerhayes et al. 2012 | + | − | ++ | − | + | ++ | Second
Swartz et al. 2015a, 2015b | + | ++ | ++ | − | + | ++ | Second
Zaganjor et al. 2020 | + | − | ++ | + | ++ | ++ | Second

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; −− = definitely high risk of bias

* Key question

Table C-9 Summary of Risk of Bias Assessment for Chloroform—Experimental Animal Studies

| Risk of bias criteria and ratings
| Selection bias | | Performance bias | | Attrition / exclusion bias | Detection bias | | Selective reporting bias
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were the experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Respiratory effects
Inhalation acute-duration exposure
Constan et al. 1999 (Sv/129 mice) | + | + | ++ | ++ | ++ | ++ | ++ | ++ | First
Constan et al. 1999 (B6C3F1 mice) | + | + | ++ | ++ | ++ | ++ | ++ | ++ | First
de Oliveira et al. 2015 | − | + | ++ | + | ++ | + | + | ++ | First
Kasai et al. 2002 (rat) | − | + | ++ | + | ++ | ++ | + | − | First
Larson et al. 1994c; Mery et al. 1994 (mouse) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1994c; Mery et al. 1994 (rat) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1996 | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (4 days) | − | + | ++ | + | ++ | + | + | ++ | First
Inhalation intermediate-duration exposure
Kasai et al. 2002 (mouse) | − | + | ++ | + | ++ | ++ | + | − | First
Kasai et al. 2002 (rat) | − | + | ++ | + | ++ | ++ | + | − | First
Larson et al. 1996 (13 weeks; 5 days/week) | − | + | ++ | + | ++ | − | + | ++ | First
Larson et al. 1996 (13 weeks; 7 days/week) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1996 (3 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1996 (6 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (13 weeks; 5 days/week) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (13 weeks; 7 days/week) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (3 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (6 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Inhalation chronic-duration exposure
Yamamoto et al. 2002 (mouse) | − | + | ++ | + | ++ | ++ | + | + | First
Yamamoto et al. 2002 (rat) | − | + | ++ | + | ++ | ++ | + | + | First
Oral acute-duration exposure
Larson et al. 1995b | + | + | ++ | + | ++ | + | + | + | First
Templin et al. 1996a (Fischer 344) | + | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996a (Osborne-Mendel) | + | + | ++ | + | ++ | + | + | ++ | First
Oral intermediate-duration exposure
Chu et al. 1982a | − | + | + | + | − | + | + | − | First
Chu et al. 1982b | − | + | + | + | + | + | + | + | First
Dorman et al. 1997 | | + | − | + | − | + | + | + | First
NTP 1988a | ++ | + | ++ | + | ++ | + | + | ++ | First
EPA 1980 (mouse) | ++ | + | − | + | + | + | + | ++ | First
EPA 1980 (rat) | ++ | + | − | + | + | + | + | ++ | First
Larson et al. 1995b | + | + | ++ | + | ++ | + | ++ | + | First
Sehata et al. 2002 (CB6F1) | − | + | ++ | + | + | + | ++ | ++ | First
Oral chronic-duration exposure
Dunnick and Melnick 1993; NCI 1976 (mouse) | + | + | ++ | + | ++ | ++ | + | ++ | First
Dunnick and Melnick 1993; NCI 1976 (rat) | + | + | ++ | + | ++ | ++ | + | ++ | First
Roe et al. 1979 (Experiment 1) | + | + | − | + | − | ++ | − | + | Second
Outcome: Liver effects
Inhalation acute-duration exposure
Baeder and Hofmann 1988 | − | + | ++ | + | ++ | + | − | ++ | Second
Constan et al. 1999 (Sv/129 mice) | + | + | ++ | + | ++ | + | + | ++ | First
Constan et al. 1999 (B6C3F1 mice) | + | + | ++ | + | ++ | + | + | ++ | First
Kasai et al. 2002 (rat) | − | + | ++ | + | ++ | ++ | + | ++ | First
Larson et al. 1994c; Mery et al. 1994 (mouse) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1994c; Mery et al. 1994 (rat) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1996 | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (4 days) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996c (2 weeks) | + | + | ++ | + | + | + | + | ++ | First
Templin et al. 1996c (4 days) | + | + | ++ | + | + | + | + | ++ | First
Inhalation intermediate-duration exposure
Kasai et al. 2002 (rat) | − | + | ++ | + | ++ | ++ | + | ++ | First
Larson et al. 1996 (13 weeks; 5 days/week) | − | + | ++ | + | ++ | − | + | ++ | First
Larson et al. 1996 (13 weeks; 7 days/week) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1996 (3 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1996 (6 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (13 weeks; 5 days/week) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (13 weeks; 7 days/week) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (3 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (6 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1998 (13 weeks) | + | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1998 (3 weeks) | + | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1998 (7 weeks) | + | + | ++ | + | ++ | + | + | ++ | First
Torkelson et al. 1976 (rat 1–4 hours/day) | − | + | ++ | + | − | ++ | + | ++ | First
Torkelson et al. 1976 (rat 7 hours/day) | − | + | ++ | + | − | ++ | + | ++ | First
Inhalation chronic-duration exposure
Yamamoto et al. 2002 (mouse) | − | + | ++ | + | ++ | ++ | ++ | + | First
Yamamoto et al. 2002 (rat) | − | + | ++ | + | ++ | ++ | ++ | + | First
Oral acute-duration exposure
Chu et al. 1982b | − | + | ++ | + | − | + | + | + | First
Ewaid et al. 2020 | + | + | − | + | − | + | + | + | First
Jones et al. 1958 | −− | + | − | + | − | − | + | + | Second
Keegan et al. 1998 | − | + | ++ | + | ++ | + | ++ | ++ | First
Larson et al. 1993 (mouse) | + | + | ++ | + | ++ | + | + | + | First
Larson et al. 1993 (rat) | + | + | ++ | + | ++ | + | + | + | First
Larson et al. 1994b (GO) | + | + | + | + | + | + | + | + | First
Larson et al. 1994b (W) | + | + | + | + | + | + | + | + | First
Larson et al. 1994d | + | + | ++ | + | + | + | + | + | First
Larson et al. 1995a (DW) | + | + | ++ | + | + | + | + | + | First
Larson et al. 1995a (G) | + | + | ++ | + | + | + | + | + | First
Larson et al. 1995b | + | + | ++ | + | ++ | + | + | + | First
Lilly et al. 1997 | − | + | ++ | + | ++ | + | ++ | + | First
Miyagawa et al. 1998 | − | + | + | + | + | − | + | + | First
Moore et al. 1982 (G) | + | + | + | + | + | − | + | ++ | First
Moore et al. 1982 (GO) | + | + | + | + | + | − | + | ++ | First
Munson et al. 1982 | − | + | + | + | − | − | ++ | + | First
Templin et al. 1996a (Fischer 344) | + | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996a (Osborne-Mendel) | + | + | ++ | + | ++ | + | + | ++ | First
Thompson et al. 1974 (Experiment 2, 6 F) | − | + | + | + | ++ | − | + | + | First
Wada et al. 2015 | + | + | + | + | ++ | + | + | ++ | First
Wang et al. 1997 | − | + | ++ | + | ++ | − | ++ | ++ | First
Oral intermediate-duration exposure
Bull et al. 1986 (GO) | + | + | ++ | + | + | − | + | + | First
Bull et al. 1986 (GW) | + | + | ++ | + | + | − | + | + | First
Chu et al. 1982a | − | + | + | + | − | − | + | ++ | First
Chu et al. 1982b | − | + | + | + | + | − | + | + | First
Eschenbrenner and Miller 1945 | − | + | + | + | + | − | − | + | Second
NTP 1988a | ++ | + | ++ | + | ++ | + | + | ++ | First
Heywood et al. 1979 | − | + | + | + | + | − | + | − | First
EPA 1980 (mouse) | ++ | + | − | + | + | + | + | ++ | First
EPA 1980 (rat) | ++ | + | − | + | + | + | + | ++ | First
Larson et al. 1994b (GO) | + | + | + | + | + | + | + | + | First
Larson et al. 1994b (W) | + | + | + | + | + | + | + | + | First
Larson et al. 1994d | + | + | ++ | + | + | + | + | ++ | First
Larson et al. 1995a (GO) | + | + | ++ | + | + | + | + | + | First
Larson et al. 1995a (W) | + | + | ++ | + | + | + | + | + | First
Larson et al. 1995b | + | + | ++ | + | ++ | + | + | + | First
Melnick et al. 1998 | − | + | ++ | + | + | + | + | ++ | First
Mostafa et al. 2009 | − | + | −− | + | ++ | − | + | + | First
Munson et al. 1982 | − | + | + | + | − | − | + | + | First
Sehata et al. 2002 (CB6F1) | − | + | ++ | + | + | + | ++ | ++ | First
Oral chronic-duration exposure
Heywood et al. 1979 | − | + | + | + | − | ++ | − | ++ | Second
Dunnick and Melnick 1993; NCI 1976 (mouse) | + | + | ++ | + | ++ | + | + | ++ | First
Dunnick and Melnick 1993; NCI 1976 (rat) | + | + | ++ | + | ++ | + | + | ++ | First
Roe et al. 1979 (Experiment 1) | + | + | − | + | − | ++ | + | + | First
Outcome: Kidney effects
Inhalation acute-duration exposure
Baeder and Hofmann 1988 | − | + | ++ | + | ++ | + | − | ++ | Second
Constan et al. 1999 (Sv/129 mice) | + | + | ++ | + | ++ | + | + | ++ | First
Constan et al. 1999 (B6C3F1 mice) | + | + | ++ | + | ++ | + | + | ++ | First
Kasai et al. 2002 (rat) | − | + | ++ | + | ++ | ++ | + | ++ | First
Larson et al. 1994c; Mery et al. 1994 (mouse) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1994c; Mery et al. 1994 (rat) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1996 | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (4 days) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996c (2 weeks) | + | + | ++ | + | + | + | + | ++ | First
Templin et al. 1996c (4days) | + | + | ++ | + | + | + | + | ++ | First
Inhalation intermediate-duration exposure
Kasai et al. 2002 (mouse) | − | + | ++ | + | ++ | ++ | + | ++ | First
Kasai et al. 2002 (rat) | − | + | ++ | + | ++ | ++ | + | ++ | First
Larson et al. 1996 (13 weeks; 5 days/week) | − | + | ++ | + | ++ | − | + | ++ | First
Larson et al. 1996 (13 weeks; 7 days/week) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1996 (3 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1996 (6 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (13 weeks; 5 days/week) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (13 weeks; 7 days/week) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (3 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (6 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1998 (13 weeks) | + | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1998 (3 weeks) | + | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1998 (7 weeks) | + | + | ++ | + | ++ | + | + | ++ | First
Torkelson et al. 1976 (rat 1–4 hours/day) | − | + | ++ | + | − | ++ | + | ++ | First
Torkelson et al. 1976 (rat 7 hours/day) | − | + | ++ | + | − | ++ | + | ++ | First
Inhalation chronic-duration exposure
Yamamoto et al. 2002 (mouse) | − | + | ++ | + | ++ | ++ | ++ | + | First
Yamamoto et al. 2002 (rat) | − | + | ++ | + | ++ | ++ | ++ | + | First
Oral acute-duration exposure
Chu et al. 1982b | − | + | ++ | + | − | + | + | + | First
Ewaid et al. 2020 | + | + | − | + | − | + | + | + | First
Keegan et al. 1998 | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1993 (rat) | + | + | ++ | + | ++ | + | + | + | First
Larson et al. 1993 (mouse) | + | + | ++ | + | ++ | + | + | + | First
Larson et al. 1994b (GO) | + | + | + | + | + | + | ++ | + | First
Larson et al. 1994b (W) | + | + | + | + | + | + | ++ | + | First
Larson et al. 1994d | + | + | ++ | + | + | + | + | ++ | First
Larson et al. 1995a (DW) | + | + | ++ | + | + | + | + | + | First
Larson et al. 1995a (G) | + | + | ++ | + | + | + | + | + | First
Larson et al. 1995b | + | + | ++ | + | ++ | + | + | + | First
Lilly et al. 1997 | − | + | ++ | + | ++ | + | ++ | + | First
Liu et al. 2013 | − | + | + | + | + | − | ++ | ++ | First
Miyagawa et al. 1998 | − | + | + | + | + | − | + | + | First
Moore et al. 1982 (G) | + | + | + | + | + | − | + | ++ | First
Moore et al. 1982 (GO) | + | + | + | + | + | − | + | ++ | First
Potter et al. 1996 | + | + | ++ | + | + | − | + | ++ | First
Templin et al. 1996a (Fischer 344) | + | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996a (Osborne-Mendel) | + | + | ++ | + | ++ | + | + | ++ | First
Thompson et al. 1974 (Experiment 2, 6 F) | − | + | + | + | ++ | − | + | + | First
Oral intermediate-duration exposure
Chu et al. 1982a | − | + | + | + | − | − | + | − | Second
Chu et al. 1982b | − | + | + | + | + | − | + | + | First
NTP 1988a | ++ | + | ++ | + | ++ | + | + | ++ | First
Heywood et al. 1979 | − | + | + | + | + | − | − | − | Second
Hooth et al. 2002; McDorman et al. 2003a, 2003b | + | + | ++ | + | ++ | + | + | ++ | First
EPA 1980 (mouse) | ++ | + | − | + | + | + | + | ++ | First
EPA 1980 (rat) | ++ | + | − | + | + | + | + | ++ | First
Larson et al. 1994b (GO) | + | + | + | + | + | + | ++ | + | First
Larson et al. 1994b (W) | + | + | + | + | + | + | ++ | + | First
Larson et al. 1994d | + | + | ++ | + | + | + | + | ++ | First
Larson et al. 1995a (GO) | + | + | ++ | + | + | + | + | + | First
Larson et al. 1995a (W) | + | + | ++ | + | + | + | + | + | First
Larson et al. 1995b | + | + | ++ | + | ++ | + | + | + | First
Lipsky et al. 1993 (GO) | − | + | ++ | + | + | − | + | + | First
Lipsky et al. 1993 (GW) | − | + | ++ | + | + | − | + | + | First
Sehata et al. 2002 (CB6F1) | − | + | ++ | + | + | + | ++ | + | First
Oral chronic-duration exposure
Heywood et al. 1979 | − | + | + | + | − | ++ | − | ++ | Second
Hard et al. 2000; Jorgenson et al. 1985 (rat) | + | + | ++ | + | − | ++ | ++ | ++ | First
Nagano et al. 2006 | + | + | ++ | + | + | + | + | ++ | First
Dunnick and Melnick 1993; NCI 1976 (rat) | + | + | ++ | + | ++ | + | + | ++ | First
Dunnick and Melnick 1993; NCI 1976 (mouse) | + | + | ++ | + | ++ | + | + | ++ | First
Roe et al. 1979 (Experiment 1) | + | + | − | + | − | ++ | + | ++ | First
Roe et al. 1979 (Experiment 3) | + | + | − | + | − | ++ | + | + | First
Outcome: Neurological effects
Inhalation acute-duration exposure
Constan et al. 1999 (Sv/129 mice) | + | − | ++ | − | ++ | + | − | ++ | Second
Constan et al. 1999 (B6C3F1 mice) | + | − | ++ | − | ++ | + | − | ++ | Second
DHA 2022 | − | + | ++ | + | ++ | ++ | + | ++ | First
EPA 1978 | − | + | ++ | − | ++ | − | − | ++ | Second
Gehring 1968 | − | + | ++ | − | ++ | − | − | ++ | Second
Larson et al. 1994c; Mery et al. 1994 (rat) | − | + | ++ | + | ++ | + | + | ++ | First
Lehmann and Flury 1943 (cat) | − | − | − | − | − | − | − | − | Third
Lehmann and Flury 1943 (mouse) | − | − | − | − | − | − | − | − | Third
Inhalation intermediate-duration exposure
Larson et al. 1996 (13 weeks; 7 days/week) | − | + | ++ | + | ++ | + | + | ++ | First
Larson et al. 1996 (3 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (13 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Templin et al. 1996b (3 weeks) | − | + | ++ | + | ++ | + | + | ++ | First
Inhalation chronic-duration exposure
Yamamoto et al. 2002 (mouse) | − | + | ++ | − | ++ | ++ | + | + | First
Yamamoto et al. 2002 (rat) | − | + | ++ | − | ++ | ++ | + | + | First
Oral acute-duration exposure
Balster and Borzelleca 1982 (14 days) | + | + | + | + | ++ | − | ++ | ++ | First
Balster and Borzelleca 1982 (once) | + | + | + | + | + | − | ++ | + | First
Bowman et al. 1978 | − | + | + | + | − | − | − | − | Third
NTP 1988a | ++ | + | ++ | + | + | + | + | − | First
Jones et al. 1958 | −− | + | − | + | − | − | − | + | Third
Landauer et al. 1982 | + | + | ++ | + | + | − | + | + | First
Oral intermediate-duration exposure
Balster and Borzelleca 1982 (30 days) | + | + | + | + | − | − | ++ | + | First
Balster and Borzelleca 1982 (60 days) | + | + | + | + | − | − | + | + | First
Balster and Borzelleca 1982 (90 days) | + | + | + | + | − | − | ++ | + | First
Chu et al. 1982a | − | + | − | + | − | − | + | − | Second
Chu et al. 1982b | − | + | − | + | + | − | + | + | First
Dorman et al. 1997 | −− | + | ++ | + | + | + | + | ++ | First
Sehata et al. 2002 (CB6F1) | − | + | ++ | + | + | + | + | + | First
Wada et al. 2015 | + | ++ | + | ++ | ++ | + | ++ | + | First
Oral chronic-duration exposure
Heywood et al. 1979 | − | − | + | − | − | ++ | − | + | Third
Dunnick and Melnick 1993; NCI 1976 (rat) | + | + | ++ | − | ++ | ++ | + | ++ | First
Dunnick and Melnick 1993; NCI 1976 (mouse) | + | + | ++ | − | ++ | ++ | + | ++ | First
Roe et al. 1979 (Experiment 1) | + | − | − | − | − | ++ | + | + | Second
Outcome: Developmental Effects
Inhalation acute-duration exposure
Baeder and Hofmann 1988 | − | + | ++ | + | ++ | + | + | ++ | First
EPA 1978 | − | + | ++ | + | ++ | − | + | − | Second
Murray et al. 1979 (GDs 1–7) | − | + | ++ | + | ++ | + | + | ++ | First
Murray et al. 1979 (GDs 6–15) | − | + | ++ | + | ++ | + | + | ++ | First
Murray et al. 1979 (GDs 8–15) | − | + | ++ | + | ++ | + | + | ++ | First
Schwetz et al. 1974 | − | + | ++ | + | − | + | + | ++ | First
Oral acute-duration exposure
Ruddick et al. 1983 | + | + | ++ | + | ++ | + | ++ | − | First
Thompson et al. 1974 (Experiment 1,25 F) | − | + | ++ | + | ++ | − | + | ++ | First
Thompson et al. 1974 (Experiment 2, 6 F) | − | + | ++ | + | ++ | − | + | ++ | First
Thompson et al. 1974 (rabbit, 1 time/day) | − | + | ++ | + | ++ | − | + | ++ | First
Thompson et al. 1974 (rabbit, 2 times/day) | − | + | ++ | + | ++ | − | + | ++ | First
Oral intermediate-duration exposure
Burkhalter and Balster 1979 | + | + | ++ | ++ | − | + | ++ | ++ | First
NTP 1988a | + | + | ++ | + | + | ++ | ++ | ++ | First
Lim et al. 2004 (5 weeks) | + | + | ++ | + | − | −− | ++ | ++ | First
Lim et al. 2004 (8 weeks) | + | + | ++ | + | − | −− | ++ | ++ | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; −− = definitely high risk of bias; (DW) = drinking water; F = females; (G) = gavage; GD = gestation day; (GO) = gavage in oil; (GW) = gavage in water; (W) = water

* Key question

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to chloroform and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to chloroform and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-11, C-12, C-13, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-10 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-11 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-12 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining respiratory, hepatic, renal, neurological, and developmental endpoints observed in the observational epidemiology and animal experimental studies are presented in Tables C-14 and C-15, respectively.

Table C-13 Presence of Key Features of Study Design for Chloroform—Observational Epidemiology Studies

| Key features
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Respiratory effects
Cross-sectional studies
Font-Ribera et al. 2010 | No | Yes | Yes | Yes | Moderate
Outcome: Hepatic effects
Cohort studies
Aiking et al. 1994 | No | Yes | Yes | Yes | Moderate
Bomski et al. 1967 | No | Yes | Yes | Yes | Moderate
Challen et al. 1958 | No | Yes | Yes | Yes | Moderate
Li et al. 1993 | No | Yes | Yes | Yes | Moderate
Outcome: Renal effects
Cohort studies
Aiking et al. 1994 | No | Yes | Yes | Yes | Moderate
Li et al. 1993 | No | Yes | Yes | Yes | Moderate
Outcome: Neurological effects
Cohort studies
Challen et al. 1958 | No | Yes | Yes | Yes | Moderate
Li et al. 1993 | No | Yes | Yes | Yes | Moderate
Outcome: Developmental effects
Cohort studies
Botton et al. 2015 | No | No | Yes | Yes | Low
Cao et al. 2016 | No | No | Yes | Yes | Low
Costet et al. 2011 | No | Yes | Yes | Yes | Moderate
Dodds and King 2001 | No | Yes | Yes | Yes | Moderate
Grazuleviciene et al. 2011 | No | Yes | Yes | Yes | Moderate
Grazuleviciene et al. 2013 | No | Yes | Yes | Yes | Moderate
Hinckley et al. 2005 | No | No | Yes | Yes | Low
Hoffman et al. 2008 | No | Yes | Yes | Yes | Moderate
Liu et al. 2021 | No | Yes | Yes | Yes | Moderate
Rivera-Núñez and Wright 2013 | No | No | Yes | Yes | Low
Sun et al. 2020 | No | Yes | Yes | Yes | Moderate
Villanueva et al. 2018 | No | Yes | Yes | Yes | Moderate
Villanueva et al. 2011 | No | No | Yes | Yes | Low
Zhu et al. 2022 | No | Yes | Yes | Yes | Moderate
Population studies
Porter et al. 2005 | No | Yes | Yes | Yes | Moderate
Wright et al. 2004 | No | Yes | Yes | Yes | Moderate
Case-control studies
Bonou et al. 2017 | No | Yes | Yes | Yes | Moderate
Kaufman et al. 2018 | No | Yes | Yes | Yes | Moderate
Kaufman et al. 2020 | No | Yes | Yes | Yes | Moderate
Kramer et al. 1992 | No | Yes | Yes | Yes | Moderate
Levallois et al. 2012 | No | Yes | Yes | Yes | Moderate
Summerhayes et al. 2012 | No | Yes | Yes | Yes | Moderate
Swartz et al. 2015a, 2015b | No | No | Yes | Yes | Low
Zaganjor et al. 2020 | No | Yes | Yes | Yes | Moderate

Table C-14 Presence of Key Features of Study Design for Chloroform—Experimental Animal Studies

| Key features
Reference | Concurrent control group | Sufficient number of subjects | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory effects
Inhalation acute-duration exposure
Constan et al. 1999 (Sv/129 mice) | Yes | Yes | Yes | Yes | High
Constan et al. 1999 (B6C3F1 mice) | Yes | Yes | Yes | Yes | High
de Oliveira et al. 2015 | Yes | Yes | Yes | Yes | High
Kasai et al. 2002 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1994c; Mery et al. 1994 (mouse) | Yes | Yes | Yes | Yes | High
Larson et al. 1994c; Mery et al. 1994 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (4 days) | Yes | Yes | Yes | Yes | High
Inhalation intermediate-duration exposure
Kasai et al. 2002 (mouse) | Yes | Yes | Yes | Yes | High
Kasai et al. 2002 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (13 weeks; 5 days/week) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (13 weeks; 7 days/week) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (3 weeks) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (6 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (13 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (13 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (3 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (6 weeks) | Yes | Yes | Yes | Yes | High
Inhalation chronic-duration exposure
Yamamoto et al. 2002 (mouse); additional information from unpublished study (MHLW 1994a, 1994b) | Yes | Yes | Yes | Yes | High
Yamamoto et al. 2002 (rat); additional information from unpublished study (MHLW 1994a, 1994b) | Yes | Yes | Yes | Yes | High
Oral acute-duration exposure
Larson et al. 1995b | Yes | Yes | Yes | No | Moderate
Templin et al. 1996a (Fischer 344) | Yes | Yes | Yes | Yes | High
Templin et al. 1996a (Osborne-Mendel) | Yes | Yes | Yes | Yes | High
Oral intermediate-duration exposure
Chu et al. 1982a | Yes | Yes | Yes | No | Moderate
Chu et al. 1982b | Yes | Yes | Yes | No | Moderate
Dorman et al. 1997 | Yes | Yes | Yes | Yes | High
NTP 1988a | Yes | Yes | Yes | Yes | High
EPA 1980 (mouse) | Yes | Yes | Yes | Yes | High
EPA 1980 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1995b | Yes | Yes | Yes | No | Moderate
Sehata et al. 2002 (CB6F1) | Yes | Yes | Yes | Yes | High
Oral chronic-duration exposure
Dunnick and Melnick 1993; NCI 1976 (mouse) | Yes | Yes | Yes | No | Moderate
Dunnick and Melnick 1993; NCI 1976 (rat) | Yes | Yes | Yes | No | Moderate
Roe et al. 1979 (Experiment 1) | Yes | Yes | No | No | Low
Outcome: Liver effects
Inhalation acute-duration exposure
Baeder and Hofmann 1988 | Yes | Yes | No | Yes | Moderate
Constan et al. 1999 (Sv/129 mice) | Yes | Yes | Yes | Yes | High
Constan et al. 1999 (B6C3F1 mice) | Yes | Yes | Yes | Yes | High
Kasai et al. 2002 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1994c; Mery et al. 1994 (mouse) | Yes | Yes | Yes | Yes | High
Larson et al. 1994c; Mery et al. 1994 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (4 days) | Yes | Yes | Yes | Yes | High
Templin et al. 1996c (2 weeks) | Yes | No | Yes | Yes | Moderate
Templin et al. 1996c (4 days) | Yes | No | Yes | Yes | Moderate
Inhalation intermediate-duration exposure
Kasai et al. 2002 (mouse) | Yes | Yes | Yes | Yes | High
Kasai et al. 2002 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (13 weeks; 5 days/week) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (13 weeks; 7 days/week) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (3 weeks) | Yes | No | Yes | Yes | Moderate
Larson et al. 1996 (6 weeks) | Yes | No | Yes | Yes | Moderate
Templin et al. 1996b (13 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (13 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (3 weeks) | Yes | No | Yes | Yes | Moderate
Templin et al. 1996b (6 weeks) | Yes | No | Yes | Yes | Moderate
Templin et al. 1998 (13 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1998 (3 weeks) | Yes | No | Yes | Yes | Moderate
Templin et al. 1998 (7 weeks) | Yes | No | Yes | Yes | Moderate
Torkelson et al. 1976 (rat 1–4 hours/day) | Yes | Yes | Yes | Yes | High
Torkelson et al. 1976 (rat 7 hours/day) | Yes | Yes | Yes | Yes | High
Inhalation chronic-duration exposure
Yamamoto et al. 2002 (mouse) | Yes | Yes | Yes | Yes | High
Yamamoto et al. 2002 (rat) | Yes | Yes | Yes | Yes | High
Oral acute-duration exposure
Chu et al. 1982b | Yes | Yes | Yes | No | Moderate
Ewaid et al. 2020 | Yes | No | Yes | No | Low
Jones et al. 1958 | No | Yes | Yes | No | Low
Keegan et al. 1998 | Yes | Yes | Yes | Yes | High
Larson et al. 1993 (mouse) | Yes | Yes | Yes | No | Moderate
Larson et al. 1993 (rat) | Yes | Yes | Yes | No | Moderate
Larson et al. 1994b (GO) | Yes | Yes | Yes | No | Moderate
Larson et al. 1994b (W) | Yes | Yes | Yes | No | Moderate
Larson et al. 1994d | Yes | Yes | Yes | No | Moderate
Larson et al. 1995a (DW) | Yes | Yes | Yes | No | Moderate
Larson et al. 1995a (G) | Yes | Yes | Yes | No | Moderate
Larson et al. 1995b | Yes | Yes | Yes | No | Moderate
Lilly et al. 1997 | Yes | Yes | Yes | Yes | High
Miyagawa et al. 1998 | Yes | Yes | Yes | No | Moderate
Moore et al. 1982 (G) | Yes | Yes | Yes | Yes | High
Moore et al. 1982 (GO) | Yes | Yes | Yes | Yes | High
Munson et al. 1982 | Yes | Yes | Yes | Yes | High
Templin et al. 1996a (Fischer 344) | Yes | Yes | Yes | Yes | High
Templin et al. 1996a (Osborne-Mendel) | Yes | Yes | Yes | Yes | High
Thompson et al. 1974 (Experiment 2, 6 F) | Yes | Yes | Yes | No | Moderate
Wada et al. 2015 | Yes | Yes | Yes | Yes | High
Wang et al. 1997 | Yes | Yes | Yes | Yes | High
Oral intermediate-duration exposure
Bull et al. 1986 (GO) | Yes | Yes | Yes | No | Moderate
Bull et al. 1986 (GW) | Yes | Yes | Yes | No | Moderate
Chu et al. 1982a | Yes | Yes | Yes | Yes | High
Chu et al. 1982b | Yes | Yes | Yes | Yes | High
Eschenbrenner and Miller 1945 | Yes | Yes | No | Yes | Moderate
NTP 1988a | Yes | Yes | Yes | Yes | High
Heywood et al. 1979 | Yes | Yes | Yes | No | Moderate
EPA 1980 (mouse) | Yes | Yes | Yes | Yes | High
EPA 1980 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1994b (GO) | Yes | Yes | Yes | No | Moderate
Larson et al. 1994b (W) | Yes | Yes | Yes | No | Moderate
Larson et al. 1994d | Yes | Yes | Yes | Yes | High
Larson et al. 1995a (GO) | Yes | Yes | Yes | No | Moderate
Larson et al. 1995a (W) | Yes | Yes | Yes | No | Moderate
Larson et al. 1995b | Yes | Yes | Yes | No | Moderate
Melnick et al. 1998 | Yes | Yes | Yes | Yes | High
Mostafa et al. 2009 | No | Yes | Yes | No | Low
Munson et al. 1982 | Yes | Yes | Yes | No | Moderate
Sehata et al. 2002 (CB6F1) | Yes | Yes | Yes | Yes | High
Oral chronic-duration exposure
Heywood et al. 1979 | Yes | Yes | Yes | No | Moderate
Dunnick and Melnick 1993; NCI 1976 (mouse) | Yes | Yes | Yes | No | Moderate
Dunnick and Melnick 1993; NCI 1976 (rat) | Yes | Yes | Yes | No | Moderate
Roe et al. 1979 (Experiment 1) | Yes | Yes | Yes | No | Moderate
Outcome: Kidney effects
Inhalation acute-duration exposure
Baeder and Hofmann 1988 | Yes | Yes | No | Yes | Moderate
Constan et al. 1999 (Sv/129 mice) | Yes | Yes | Yes | Yes | High
Constan et al. 1999 (B6C3F1 mice) | Yes | Yes | Yes | Yes | High
Kasai et al. 2002 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1994c; Mery et al. 1994 (mouse) | Yes | Yes | Yes | Yes | High
Larson et al. 1994c; Mery et al. 1994 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (4 days) | Yes | Yes | Yes | Yes | High
Templin et al. 1996c (2 weeks) | Yes | No | Yes | Yes | Moderate
Templin et al. 1996c (4 days) | Yes | No | Yes | Yes | Moderate
Inhalation intermediate-duration exposure
Kasai et al. 2002 (mouse) | Yes | Yes | Yes | Yes | High
Kasai et al. 2002 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (13 weeks; 5 days/week) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (13 weeks; 7 days/week) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (3 weeks) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (6 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (13 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (13 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (3 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (6 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1998 (13 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1998 (3 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1998 (7 weeks) | Yes | Yes | Yes | Yes | High
Torkelson et al. 1976 (rat 1–4 hours/day) | Yes | Yes | Yes | Yes | High
Torkelson et al. 1976 (rat 7 hours/day) | Yes | Yes | Yes | Yes | High
Inhalation chronic-duration exposure
Yamamoto et al. 2002 (mouse) | Yes | Yes | Yes | Yes | High
Yamamoto et al. 2002 (rat) | Yes | Yes | Yes | Yes | High
Oral acute-duration exposure
Chu et al. 1982b | Yes | Yes | Yes | No | Moderate
Ewaid et al. 2020 | Yes | No | Yes | No | Low
Keegan et al. 1998 | Yes | Yes | No | Yes | Moderate
Larson et al. 1993 (rat) | Yes | Yes | Yes | No | Moderate
Larson et al. 1993 (mouse) | Yes | Yes | Yes | No | Moderate
Larson et al. 1994b (GO) | Yes | Yes | Yes | No | Moderate
Larson et al. 1994b (W) | Yes | Yes | Yes | No | Moderate
Larson et al. 1994d | Yes | Yes | Yes | Yes | High
Larson et al. 1995a (DW) | Yes | Yes | Yes | No | Moderate
Larson et al. 1995a (G) | Yes | Yes | Yes | No | Moderate
Larson et al. 1995b | Yes | Yes | Yes | No | Moderate
Lilly et al. 1997 | Yes | Yes | Yes | Yes | High
Liu et al. 2013 | Yes | Yes | Yes | Yes | High
Miyagawa et al. 1998 | Yes | Yes | Yes | No | Moderate
Moore et al. 1982 (G) | Yes | Yes | Yes | Yes | High
Moore et al. 1982 (GO) | Yes | Yes | Yes | Yes | High
Potter et al. 1996 | Yes | Yes | Yes | Yes | High
Templin et al. 1996a (Fischer 344) | Yes | Yes | Yes | Yes | High
Templin et al. 1996a (Osborne-Mendel) | Yes | Yes | Yes | Yes | High
Thompson et al. 1974 (Experiment 2, 6 F) | Yes | Yes | Yes | No | Moderate
Oral intermediate-duration exposure
Chu et al. 1982a | Yes | Yes | Yes | Yes | High
Chu et al. 1982b | Yes | Yes | Yes | Yes | High
NTP 1988a | Yes | Yes | Yes | Yes | High
Heywood et al. 1979 | Yes | Yes | No | No | Low
Hooth et al. 2002; McDorman et al. 2003a, 2003b | Yes | Yes | Yes | Yes | High
EPA 1980 (mouse) | Yes | Yes | Yes | Yes | High
EPA 1980 (rat) | Yes | Yes | Yes | Yes | High
Larson et al. 1994b (GO) | Yes | Yes | Yes | No | Moderate
Larson et al. 1994b (W) | Yes | Yes | Yes | No | Moderate
Larson et al. 1994d | Yes | Yes | Yes | Yes | High
Larson et al. 1995a (GO) | Yes | Yes | Yes | No | Moderate
Larson et al. 1995a (W) | Yes | Yes | Yes | No | Moderate
Larson et al. 1995b | Yes | Yes | Yes | No | Moderate
Lipsky et al. 1993 (GO) | Yes | Yes | Yes | No | Moderate
Lipsky et al. 1993 (GW) | Yes | Yes | Yes | No | Moderate
Sehata et al. 2002 (CB6F1) | Yes | Yes | Yes | Yes | High
Oral chronic-duration exposure
Heywood et al. 1979 | Yes | Yes | Yes | No | Moderate
Hard et al. 2000; Jorgenson et al. 1985 (rat) | Yes | Yes | Yes | Yes | High
Nagano et al. 2006 | Yes | Yes | Yes | Yes | High
Dunnick and Melnick 1993; NCI 1976 (rat) | Yes | Yes | Yes | No | Moderate
Dunnick and Melnick 1993; NCI 1976 (mouse) | Yes | Yes | Yes | No | Moderate
Roe et al. 1979 (Experiment 1) | Yes | Yes | Yes | No | Moderate
Roe et al. 1979 (Experiment 3) | Yes | Yes | Yes | Yes | High
Outcome: Neurological effects
Inhalation acute-duration exposure
Constan et al. 1999 (Sv/129 mice) | Yes | Yes | No | Yes | Moderate
Constan et al. 1999 (B6C3F1 mice) | Yes | Yes | No | Yes | Moderate
DHA 2022 | Yes | Yes | Yes | Yes | High
EPA 1978 | Yes | Yes | No | Yes | Moderate
Gehring 1968 | Yes | Yes | No | Yes | Moderate
Larson et al. 1994c; Mery et al. 1994 (rat) | Yes | Yes | Yes | Yes | High
Lehmann and Flury 1943 (cat) | No | No | No | No | Very low
Lehmann and Flury 1943 (mouse) | No | No | No | No | Very low
Inhalation intermediate-duration exposure
Larson et al. 1996 (13 weeks; 7 days/week) | Yes | Yes | Yes | Yes | High
Larson et al. 1996 (3 weeks) | Yes | No | Yes | Yes | Moderate
Templin et al. 1996b (13 weeks) | Yes | Yes | Yes | Yes | High
Templin et al. 1996b (3 weeks) | Yes | No | Yes | Yes | Moderate
Inhalation chronic-duration exposure
Yamamoto et al. 2002 (mouse) | Yes | Yes | Yes | Yes | High
Yamamoto et al. 2002 (rat) | Yes | Yes | Yes | Yes | High
Oral acute-duration exposure
Balster and Borzelleca 1982 (14 days) | Yes | Yes | Yes | Yes | High
Balster and Borzelleca 1982 (once) | No | Yes | Yes | Yes | Moderate
Bowman et al. 1978 | No | Yes | No | No | Low
NTP 1988a | Yes | Yes | Yes | No | Moderate
Jones et al. 1958 | No | Yes | Yes | No | Low
Landauer et al. 1982 | Yes | Yes | Yes | Yes | High
Oral intermediate-duration exposure
Balster and Borzelleca 1982 (30 days) | Yes | Yes | Yes | Yes | High
Balster and Borzelleca 1982 (60 days) | Yes | Yes | Yes | Yes | High
Balster and Borzelleca 1982 (90 days) | Yes | Yes | Yes | Yes | High
Chu et al. 1982a | Yes | Yes | Yes | Yes | High
Chu et al. 1982b | Yes | Yes | Yes | Yes | High
Dorman et al. 1997 | Yes | Yes | Yes | Yes | High
Sehata et al. 2002 (CB6F1) | Yes | Yes | Yes | Yes | High
Wada et al. 2015 | Yes | Yes | Yes | Yes | High
Oral chronic-duration exposure
Heywood et al. 1979 | Yes | Yes | Yes | No | Moderate
Dunnick and Melnick 1993; NCI 1976 (rat) | Yes | Yes | Yes | No | Moderate
Dunnick and Melnick 1993; NCI 1976 (mouse) | Yes | Yes | Yes | No | Moderate
Roe et al. 1979 (Experiment 1) | Yes | Yes | Yes | No | Moderate
Outcome: Developmental Effects
Inhalation acute-duration exposure
Baeder and Hofmann 1988 | Yes | Yes | Yes | Yes | High
EPA 1978 | Yes | Yes | Yes | No | Moderate
Murray et al. 1979 (GDs 1–7) | Yes | Yes | Yes | Yes | High
Murray et al. 1979 (GDs 6–15) | Yes | Yes | Yes | Yes | High
Murray et al. 1979 (GDs 8–15) | Yes | Yes | Yes | Yes | High
Schwetz et al. 1974 | Yes | No | Yes | Yes | Moderate
Oral acute-duration exposure
Ruddick et al. 1983 | Yes | Yes | Yes | Yes | High
Thompson et al. 1974 (Experiment 1, 25 F) | Yes | Yes | Yes | Yes | High
Thompson et al. 1974 (Experiment 2, 6 F) | Yes | Yes | Yes | Yes | High
Thompson et al. 1974 (rabbit, 1 time/day) | Yes | Yes | Yes | Yes | High
Thompson et al. 1974 (rabbit, 2 times/day) | Yes | Yes | Yes | Yes | High
Oral intermediate-duration exposure
Burkhalter and Balster 1979 | Yes | No | Yes | Yes | Moderate
NTP 1988a | Yes | Yes | Yes | Yes | High
Lim et al. 2004 (5 weeks) | Yes | Yes | Yes | Yes | High
Lim et al. 2004 (8 weeks) | Yes | Yes | Yes | Yes | High

(DW) = drinking water; F = females; (G) = gavage; GD = gestation day; (G) = gavage in water; (GW) = gavage in water; (W) = water

A summary of the initial confidence ratings for each outcome is presented in Table C-15. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-16.

Table C-15 Initial Confidence Rating for Chloroform Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Respiratory effects
Inhalation acute-duration exposure
Human studies
Font-Ribera et al. 2010 | Moderate | Moderate
Animal studies
Constan et al. 1999 (Sv/129 mice) | High | High
Constan et al. 1999 (B6C3F1 mice) | High | High
de Oliveira et al. 2015 | High | High
Kasai et al. 2002 (rat) | High | High
Larson et al. 1994c; Mery et al. 1994 (mouse) | High | High
Larson et al. 1994c; Mery et al. 1994 (rat) | High | High
Larson et al. 1996 | High | High
Templin et al. 1996b (4 days) | High | High
Inhalation intermediate-duration exposure
Animal studies
Kasai et al. 2002 (mouse) | High | High
Kasai et al. 2002 (rat) | High | High
Larson et al. 1996 (13 weeks; 5 days/week) | High | High
Larson et al. 1996 (13 weeks; 7 days/week) | High | High
Larson et al. 1996 (3 weeks) | High | High
Larson et al. 1996 (6 weeks) | High | High
Templin et al. 1996b (13 weeks) | High | High
Templin et al. 1996b (13 weeks) | High | High
Templin et al. 1996b (3 weeks) | High | High
Templin et al. 1996b (6 weeks) | High | High
Inhalation chronic-duration exposure
Animal studies
Yamamoto et al. 2002 (mouse) | Moderate | Moderate
Yamamoto et al. 2002 (rat) | Moderate | Moderate
Oral acute-duration exposure
Animal studies
Larson et al. 1995b | Moderate | High
Templin et al. 1996a (Fischer 344) | High | High
Templin et al. 1996a (Osborne-Mendel) | High | High
Oral intermediate-duration exposure
Animal studies
Chu et al. 1982a | Moderate | High
Chu et al. 1982b | Moderate | High
Dorman et al. 1997 | High | High
NTP 1988a | High | High
EPA 1980 (mouse) | High | High
EPA 1980 (rat) | High | High
Larson et al. 1995b | Moderate | High
Sehata et al. 2002 (CB6F1) | High | High
Oral chronic-duration exposure
Animal studies
Dunnick and Melnick 1993; NCI 1976 (mouse) | Moderate | Moderate
Dunnick and Melnick 1993; NCI 1976 (rat) | Moderate | Moderate
Roe et al. 1979 (Experiment 1) | Low | Moderate
Outcome: Hepatic effects
Inhalation acute-duration exposure
Human studies
Aiking et al. 1994 | Moderate | Moderate
Animal studies
Baeder and Hofmann 1988 | Moderate | High
Constan et al. 1999 (Sv/129 mice) | High | High
Constan et al. 1999 (B6C3F1 mice) | High | High
Kasai et al. 2002 (rat) | High | High
Larson et al. 1994c; Mery et al. 1994 (mouse) | High | High
Larson et al. 1994c; Mery et al. 1994 (rat) | High | High
Larson et al. 1996 | High | High
Templin et al. 1996b (4 days) | High | High
Templin et al. 1996c (2 weeks) | Moderate | High
Templin et al. 1996c (4 days) | Moderate | High
Inhalation intermediate-duration exposure
Animal studies
Kasai et al. 2002 (mouse) | High | High
Kasai et al. 2002 (rat) | High | High
Larson et al. 1996 (13 weeks; 5 days/week) | High | High
Larson et al. 1996 (13 weeks; 7 days/week) | High | High
Larson et al. 1996 (3 weeks) | Moderate | High
Larson et al. 1996 (6 weeks) | Moderate | High
Templin et al. 1996b (13 weeks) | High | High
Templin et al. 1996b (13 weeks) | High | High
Templin et al. 1996b (3 weeks) | Moderate | High
Templin et al. 1996b (6 weeks) | Moderate | High
Templin et al. 1998 (13 weeks) | High | High
Templin et al. 1998 (3 weeks) | Moderate | High
Templin et al. 1998 (7 weeks) | Moderate | High
Torkelson et al. 1976 (rat 1–4 hours/day) | High | High
Torkelson et al. 1976 (rat 7 hours/day) | High | High
Inhalation chronic-duration exposure
Human studies
Bomski et al. 1967 | Moderate | Moderate
Challen et al. 1958 | Moderate | Moderate
Li et al. 1993 | Moderate | Moderate
Animal studies
Yamamoto et al. 2002 (mouse) | High | High
Yamamoto et al. 2002 (rat) | High | High
Oral acute-duration exposure
Animal studies
Chu et al. 1982b | Moderate | High
Ewaid et al. 2020 | Low | High
Jones et al. 1958 | Low | High
Keegan et al. 1998 | High | High
Larson et al. 1993 (mouse) | Moderate | High
Larson et al. 1993 (rat) | Moderate | High
Larson et al. 1994b (GO) | Moderate | High
Larson et al. 1994b (W) | Moderate | High
Larson et al. 1994d | Moderate | High
Larson et al. 1995a (DW) | Moderate | High
Larson et al. 1995a (G) | Moderate | High
Larson et al. 1995b | Moderate | High
Lilly et al. 1997 | High | High
Miyagawa et al. 1998 | Moderate | High
Moore et al. 1982 (G) | High | High
Moore et al. 1982 (GO) | High | High
Munson et al. 1982 | High | High
Templin et al. 1996a (Fischer 344) | High | High
Templin et al. 1996a (Osborne-Mendel) | High | High
Thompson et al. 1974 (Experiment 2, 6 F) | Moderate | High
Wada et al. 2015 | High | High
Wang et al. 1997 | High | High
Oral intermediate-duration exposure
Animal studies
Bull et al. 1986 (GO) | Moderate | High
Bull et al. 1986 (GW) | Moderate | High
Chu et al. 1982a | High | High
Chu et al. 1982b | High | High
Eschenbrenner and Miller 1945 | Moderate | High
NTP 1988a | High | High
Heywood et al. 1979 | Moderate | High
EPA 1980 (mouse) | High | High
EPA 1980 (rat) | High | High
Larson et al. 1994b (GO) | Moderate | High
Larson et al. 1994b (W) | Moderate | High
Larson et al. 1994d | High | High
Larson et al. 1995a (GO) | Moderate | High
Larson et al. 1995a (W) | Moderate | High
Larson et al. 1995b | Moderate | High
Melnick et al. 1998 | High | High
Mostafa et al. 2009 | Low | High
Munson et al. 1982 | Moderate | High
Sehata et al. 2002 (CB6F1) | High | High
Oral chronic-duration exposure
Animal studies
Heywood et al. 1979 | Moderate | Moderate
Dunnick and Melnick 1993; NCI 1976 (mouse) | Moderate | Moderate
Dunnick and Melnick 1993; NCI 1976 (rat) | Moderate | Moderate
Roe et al. 1979 (Experiment 1) | Moderate | Moderate
Outcome: Renal effects
Inhalation acute-duration exposure
Animal studies
Baeder and Hofmann 1988 | Moderate | High
Constan et al. 1999 (Sv/129 mice) | High | High
Constan et al. 1999 (B6C3F1 mice) | High | High
Kasai et al. 2002 (rat) | High | High
Larson et al. 1994c; Mery et al. 1994 (mouse) | High | High
Larson et al. 1994c; Mery et al. 1994 (rat) | High | High
Larson et al. 1996 | High | High
Templin et al. 1996b (4 days) | High | High
Templin et al. 1996c (2 weeks) | Moderate | High
Templin et al. 1996c (4 days) | Moderate | High
Inhalation intermediate-duration exposure
Animal studies | | High
Kasai et al. 2002 (mouse) | High | High
Kasai et al. 2002 (rat) | High | High
Larson et al. 1996 (13 weeks; 5 days/week) | High | High
Larson et al. 1996 (13 weeks; 7 days/week) | High | High
Larson et al. 1996 (3 weeks) | High | High
Larson et al. 1996 (6 weeks) | High | High
Templin et al. 1996b (13 weeks) | High | High
Templin et al. 1996b (13 weeks) | High | High
Templin et al. 1996b (3 weeks) | High | High
Templin et al. 1996b (6 weeks) | High | High
Templin et al. 1998 (13 weeks) | High | High
Templin et al. 1998 (3 weeks) | High | High
Templin et al. 1998 (7 weeks) | High | High
Torkelson et al. 1976 (rat 1–4 hours/day) | High | High
Torkelson et al. 1976 (rat 7 hours/day) | High | High
Inhalation chronic-duration exposure
Human studies
Aiking et al. 1994 | Moderate | Moderate
Li et al. 1993 | Moderate | Moderate
Animal studies
Yamamoto et al. 2002 (mouse) | High | High
Yamamoto et al. 2002 (rat) | High | High
Oral acute-duration exposure
Animal studies
Chu et al. 1982b | Moderate | High
Ewaid et al. 2020 | Low | High
Keegan et al. 1998 | Moderate | High
Larson et al. 1993 (rat) | Moderate | High
Larson et al. 1993 (mouse) | Moderate | High
Larson et al. 1994b (GO) | Moderate | High
Larson et al. 1994b (W) | Moderate | High
Larson et al. 1994d | High | High
Larson et al. 1995a (DW) | Moderate | High
Larson et al. 1995a (G) | Moderate | High
Larson et al. 1995b | Moderate | High
Lilly et al. 1997 | High | High
Liu et al. 2013 | High | High
Miyagawa et al. 1998 | Moderate | High
Moore et al. 1982 (G) | High | High
Moore et al. 1982 (GO) | High | High
Potter et al. 1996 | High | High
Templin et al. 1996a (Fischer 344) | High | High
Templin et al. 1996a (Osborne-Mendel) | High | High
Thompson et al. 1974 (Experiment 2, 6 F) | Moderate | High
Oral intermediate-duration exposure
Animal studies
Chu et al. 1982a | High | High
Chu et al. 1982b | High | High
NTP 1988a | High | High
Heywood et al. 1979 | Low | High
Hooth et al. 2002; McDorman et al. 2003a, 2003b | High | High
EPA 1980 (mouse) | High | High
EPA 1980 (rat) | High | High
Larson et al. 1994b (GO) | Moderate | High
Larson et al. 1994b (W) | Moderate | High
Larson et al. 1994d | High | High
Larson et al. 1995a (GO) | Moderate | High
Larson et al. 1995a (W) | Moderate | High
Larson et al. 1995b | Moderate | High
Lipsky et al. 1993 (GO) | Moderate | High
Lipsky et al. 1993 (GW) | Moderate | High
Sehata et al. 2002 (CB6F1) | High | High
Oral chronic-duration exposure
Animal studies
Heywood et al. 1979 | Moderate | Moderate
Hard et al. 2000; Jorgenson et al. 1985 (rat) | High | Moderate
Nagano et al. 2006 | High | Moderate
Dunnick and Melnick 1993; NCI 1976 (rat) | Moderate | Moderate
Dunnick and Melnick 1993; NCI 1976 (mouse) | Moderate | Moderate
Roe et al. 1979 (Experiment 1) | Moderate | Moderate
Roe et al. 1979 (Experiment 3) | High | Moderate
Outcome: Neurological effects
Inhalation acute-duration exposure
Animal studies
Constan et al. 1999 (Sv/129 mice) | Moderate | High
Constan et al. 1999 (B6C3F1 mice) | Moderate | High
DHA 2022 | High | High
EPA 1978 | Moderate | High
Gehring 1968 | Moderate | High
Larson et al. 1994c; Mery et al. 1994 (rat) | High | High
Lehmann and Flury 1943 (cat) | Very low | High
Lehmann and Flury 1943 (mouse) | Very low | High
Inhalation intermediate-duration exposure
Animal studies
Larson et al. 1996 (13 weeks; 7 days/week) | High | High
Larson et al. 1996 (3 weeks) | Moderate | High
Templin et al. 1996b (13 weeks) | High | High
Templin et al. 1996b (3 weeks) | Moderate | High
Inhalation chronic-duration exposure
Human studies
Challen et al. 1958 | Moderate | Moderate
Li et al. 1993 | Moderate | Moderate
Animal studies
Yamamoto et al. 2002 (mouse) | High | High
Yamamoto et al. 2002 (rat) | High | High
Oral acute-duration exposure
Animal studies
Balster and Borzelleca 1982 (14 days) | High | High
Balster and Borzelleca 1982 (once) | Moderate | High
Bowman et al. 1978 | Low | High
NTP 1988a | Moderate | High
Jones et al. 1958 | Low | High
Landauer et al. 1982 | High | High
Oral intermediate-duration exposure
Animal studies
Balster and Borzelleca 1982 (30 days) | High | High
Balster and Borzelleca 1982 (60 days) | High | High
Balster and Borzelleca 1982 (90 days) | High | High
Chu et al. 1982a | High | High
Chu et al. 1982b | High | High
Dorman et al. 1997 | High | High
Sehata et al. 2002 (CB6F1) | High | High
Wada et al. 2015 | High | High
Oral chronic-duration exposure
Animal studies
Heywood et al. 1979 | Moderate | Moderate
Dunnick and Melnick 1993; NCI 1976 (rat) | Moderate | Moderate
Dunnick and Melnick 1993; NCI 1976 (mouse) | Moderate | Moderate
Roe et al. 1979 (Experiment 1) | Moderate | Moderate
Outcome: Developmental effects
Inhalation acute-duration exposure
Animal studies
Baeder and Hofmann 1988 | High | High
EPA 1978 | Moderate | High
Murray et al. 1979 (GDs 1–7) | High | High
Murray et al. 1979 (GDs 6–15) | High | High
Murray et al. 1979 (GDs 8–15) | High | High
Schwetz et al. 1974 | Moderate | High
Inhalation chronic-duration exposure
Human studies
Swartz et al. 2015a, 2015b | Low | Low
Oral acute-duration exposure
Animal studies
Ruddick et al. 1983 | High | High
Thompson et al. 1974 (Experiment 1, 25 F) | High | High
Thompson et al. 1974 (Experiment 2, 6 F) | High | High
Thompson et al. 1974 (rabbit, 1 time/day) | High | High
Thompson et al. 1974 (rabbit, 2 times/day) | High | High
Oral chronic-duration exposure
Human studies
Bonou et al. 2017 | Moderate | Moderate
Botton et al. 2015 | Low | Moderate
Cao et al. 2016 | Low | Moderate
Costet et al. 2011 | Moderate | Moderate
Dodds and King 2001 | Moderate | Moderate
Grazuleviciene et al. 2011 | Moderate | Moderate
Grazuleviciene et al. 2013 | Moderate | Moderate
Hinckley et al. 2005 | Low | Moderate
Hoffman et al. 2008 | Moderate | Moderate
Kaufman et al. 2018 | Moderate | Moderate
Kaufman et al. 2020 | Moderate | Moderate
Kramer et al. 1992 | Moderate | Moderate
Levallois et al. 2012 | Moderate | Moderate
Liu et al. 2021 | Moderate | Moderate
Porter et al. 2005 | Moderate | Moderate
Rivera-Núñez and Wright 2013 | Low | Moderate
Summerhayes et al. 2012 | Moderate | Moderate
Sun et al. 2020 | Moderate | Moderate
Villanueva et al. 2011 | Moderate | Moderate
Villanueva et al. 2018 | Low | Moderate
Wright et al. 2004 | Moderate | Moderate
Zaganjor et al. 2020 | Moderate | Moderate
Zhu et al. 2022 | Moderate | Moderate
Animal studies
Burkhalter and Balster 1979 | Moderate | High
NTP 1988a | High | High
Lim et al. 2004 (5 weeks) | High | High
Lim et al. 2004 (8 weeks) | High | High

(DW) = drinking water; F = females; (G) = gavage; GD = gestation day; (G) = gavage in water; (GW) = gavage in water; (W) = water

Table C-16 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Respiratory effects
Human studies | Moderate | −1 Risk of bias | Low
Animal studies | High | | High
Outcome: Hepatic effects
Human studies | Moderate | −1 Risk of bias | Low
Animal studies | High | +1 Consistency in the body of evidence | High
Outcome: Renal effects
Human studies | Moderate | −1 Risk of bias | Low
Animal studies | High | +1 Consistency in the body of evidence | High
Outcome: Neurological effects
Human studies | Moderate | −1 Risk of bias | Low
Animal studies | High | −1 Risk of bias | High
| | +1 Large magnitude of effect
Outcome: Developmental effects
Human studies | Moderate | −1 Risk of bias | Very low
| | −1 Unexplained inconsistencies
Animal studies | High | −1 Unexplained inconsistencies | Moderate

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for respiratory, hepatic, renal, neurological, and developmental effects are presented in Table C-17. For epidemiological data, if the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. The initial confidence reflects the body of evidence for the health outcome across all exposure routes and durations. Adjustments to the initial confidence are based on the properties discussed below and shown in Table C-16. If a property is not shown in Table C-16, ATSDR concluded that the property neither increases nor decreases confidence in the corresponding health outcome.

Table C-17 Confidence in the Body of Evidence for Chloroform

| Confidence in body of evidence
Outcome | Human studies | Animal studies
Respiratory effects | Low | High
Hepatic effects | Low | High
Renal effects | Low | High
Neurological effects | Low | High
Developmental effects | Very low | Moderate

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-9 and C-10). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies— inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for chloroform, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for chloroform is presented in Table C-18.

Table C-18 Level of Evidence of Health Effects for Chloroform

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Respiratory effects | Low | No Effect | Inadequate evidence
Hepatic effects | Low | Effect | Low
Renal effects | Low | Effect | Low
Neurological effects | Low | Effect | Low
Developmental effects | Very low | Effect | Inadequate evidence
Animal studies
Respiratory effects | High | Effect | High
Hepatic effects | High | Effect | High
Renal effects | High | Effect | High
Neurological effects | High | Effect | High
Developmental effects | Moderate | Effect | Moderate

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for chloroform are listed below and summarized in Table C-19.

Known Health Effects

- Hepatic effects: There is a low level of evidence for hepatic effects from limited epidemiological data and a high level of evidence from a large number of animal studies with consistent findings. The Hazard Identification conclusion for hepatic effects was increased from “Presumed” to “Known” based on other relevant data consisting of the extensive database of case reports and case series documenting hepatic effects of chloroform in exposed humans.
  ○ [underlined: Evidence from epidemiological studies]: There is some evidence of adverse hepatic effects in humans with occupational exposure to chloroform (Bomski et al. 1967), while other studies of occupational exposure did not find any hepatic effects (Challen et al. 1958; Li et al. 1993).
  ○ [underlined: Evidence from animal studies]: Hepatic lesions have been observed in numerous animal studies, including acute-, intermediate-, and chronic-duration inhalation and oral studies in rodents; intermediate- and chronic-duration oral studies in dogs; and an acute-duration oral study in rabbits (Section 2.9). Typical lesion progression begins with mild histopathological damage after low and/or brief exposures (e.g., lipid accumulation, cellular swelling and vacuolation, scattered necrosis, hepatocellular proliferation) and progresses to widespread and severe necrosis and degeneration with high and/or long-term exposure.
  ○ [underlined: Other relevant data]: The hepatic findings are strengthened by a large number of case reports and case-series reports indicating that the liver is a primary target following high-level chloroform exposure. Acute liver failure and/or severe liver damage are common findings in fatal exposures via inhalation (Giusti and Chiarotti 1981; Lionte 2010; Royston 1924; Townsend 1939) or oral (Dettling et al. 2016; Piersol et al. 1933) exposure. Reversible clinical signs of hepatotoxicity are commonly observed in nonfatal case studies of chloroform toxicity following inhalation exposure (Dettling et al. 2016; Gosselink et al. 2012; Hutchens and Kung 1985; Kang et al. 2014; Lin et al. 2005; Lunt 1953; Minor et al. 2018; Phoon et al. 1983; Smith et al. 1973). Similarly, reversible hepatotoxicity is a common finding in nonfatal cases of attempted suicide via chloroform ingestion (Choi et al. 2006; Dell’Aglio et al. 2010; Jayaweera et al. 2017; Kim 2008; Rao et al. 1993; Schroeder 1965;) and other cases of accidental or unspecified oral poisoning (Hakim et al. 1992; Sridhar et al. 2011; Storms 1973). One nonfatal dermal case also reported reversible hepatotoxicity (Vlad et al. 2014). Experimental studies demonstrate that hepatic effects are attributable to reactive intermediates produced during metabolism of chloroform (Brown et al. 1974a; Constan et al. 1999; Fang et al. 2008; Gopinath and Ford 1975).
- Neurological effects: There is a low level of evidence for neurological effects from limited epidemiological data and a high level of evidence from a large number of animal studies with consistent findings. The Hazard Identification conclusion for neurological effects was increased from “Presumed” to “Known” based on: (a) the historical use of chloroform as a general anaesthetic; (b) case reports and case series documenting marked neurological effects of chloroform in exposed humans; and (c) a plausible mechanism of action.
  ○ [underlined: Evidence from epidemiological studies]: There is limited evidence of neurological impairments (e.g., impaired hand-eye coordination, slowed reaction time) and subjective neurological complaints (e.g., dizziness, fatigue, depression) following occupational exposure to chloroform (Challen et al. 1958; Li et al. 1993).
  ○ [underlined: Evidence from animal studies] Chloroform is a CNS depressant in animals exposed via inhalation (Constan et al. 1999; EPA 1978; Gehring 1968; Lehmann and Flury 1943) or oral routes (Bowman et al. 1978; NTP 1988a; Jones et al. 1958). At exposure levels below those associated with CNS depression, there is limited evidence for altered neurobehavior following oral exposure in animals, including altered motor activity, impaired coordination, and altered operant learning (Balster and Borzelleca 1982; DHA 2022; Landauer et al. 1982; Wada et al. 2015). The only histopathological change reported in the neurological system is olfactory nerve loss in rats following acute-duration inhalation exposure (Larson et al. 1994c; Mery et al. 1994); this finding is likely in response to degeneration of the nasal olfactory epithelial tissue observed at the same exposure levels.
  ○ [underlined: Other relevant data]: Chloroform was used as a general anesthetic beginning in the late 1800s and was widely used for more than 100 years (Davison 1959), providing clear evidence for its neurological effects after inhalation exposure. Case reports also show that chloroform induces CNS depression at high inhalation exposure levels in humans (Featherstone 1947; Smith et al. 1973; Whitaker and Jones 1965). CNS depression has also been reported in individuals who intentionally or accidentally ingested the chemical (Piersol et al. 1933; Schroeder 1965; Storms 1973). Chloroform may cause CNS depression via perturbation of the lipophilic cell membrane, which results in alterations in proteins that function as ion channels and/or neurotransmitter receptors (Harris and Groh 1985; Jenkins et al. 2001; Nakagawa et al. 2000).

Presumed Health Effects

- Respiratory effects: There is inadequate evidence for respiratory effects from a single epidemiological study and a high level of evidence from several animal studies with consistent findings. Other relevant data (case reports) were not sufficient to merit an increase in the hazard identification conclusion.
  ○ [underlined: Evidence from epidemiological studies]: A single epidemiological study reported no change in respiratory function in adults after a 40-minute swim in a chlorinated pool (Font-Ribera et al. 2010); no other epidemiology studies of this endpoint were located, and no studies evaluating nasal effects in humans following exposure to chloroform were identified.
  ○ [underlined: Evidence from animal studies]: In animals, the nasal epithelium is a sensitive target of toxicity following inhalation and oral exposure (Section 2.4). Damage to the lower respiratory tract in animals was generally only observed at lethal exposure levels (Bowman et al. 1978; Kasai et al. 2002; NCI 1976). There is limited evidence of inflammatory responses in the lung at low inhalation exposure levels in mice (de Oliveira et al. 2015).
  ○ [underlined: Other relevant data]: Lung damage has been reported in several fatal cases of inhalation or oral exposure (Ago et al. 2011; Featherstone 1947; Giusti and Chiarotti 1981; Harada et al. 1997; Piersol et al. 1933; Royston 1924; Schroeder 1965). Changes in respiratory rate and/or respiratory arrest have been reported in human case reports of high exposure (Cui et al. 2022; Jayaweera et al. 2017; Storms 1973; Whitaker and Jones 1965) but these effects are likely secondary to CNS depression.
- Renal effects: There is inadequate evidence for renal effects from limited epidemiological data and a high level of evidence from a large number of animal studies with consistent findings. Other relevant data (case reports) were not sufficient to merit an increase in the hazard identification conclusion.
  ○ [underlined: Evidence from epidemiological studies]: No changes in renal clinical chemistry values were observed in one occupational cohort (Li et al. 1993) or in a group of competitive swimmers exposed to chlorinated water during training (Aiking et al. 1994).
  ○ [underlined: Evidence from animal studies]: The kidney is a clear target of toxicity in animals. Renal lesions have been observed in numerous studies following acute-, intermediate-, and chronic-duration inhalation and oral studies in rodents; intermediate- and chronic-duration oral studies in dogs; and acute-duration oral and dermal studies in rabbits (Section 2.10). Typical lesion progression begins with mild histopathological damage after low and/or brief exposures (e.g., tubular dilation, single-cell necrosis, renal cell proliferation) and progresses to severe nephropathy characterized by widespread necrosis and degeneration with higher and/or long-term exposure.
  ○ [underlined: Other relevant data]: Case reports of fatal chloroform exposures have reported renal damage (Piersol et al. 1933; Royston 1924). Additionally, reversible changes in renal clinical chemistry and urinalysis have been reported in nonfatal cases (Dettling et al. 2016; Gosselink et al. 2012; Piersol et al. 1933; Schroeder 1965; Sridhar et al. 2011; Wallace 1950). Experimental studies demonstrate that renal effects are attributable to reactive intermediates produced during metabolism of chloroform (Constan et al. 1999; Culliford and Hewitt 1957; Liu et al. 2013; Weir et al. 2005).

Suspected Health Effects

- Developmental effects: There is inadequate evidence for developmental effects from epidemiological data and a moderate level of evidence from animal studies with some inconsistent findings. Other relevant data were limited and did influence the hazard conclusion.
  ○ [underlined: Evidence from epidemiological studies]: Impaired growth (e.g., low birth weight, small for gestational age, decreased postnatal weight gain) has been associated with chloroform exposure from tap water in some epidemiological studies (Botton et al. 2015; Grazuleviciene et al. 2011; Kramer et al. 1992; Summerhayes et al. 2012; Sun et al. 2020; Wright et al. 2004; Zaganjor et al. 2020). However, these findings were not observed in other studies (Bonou et al. 2017; Cao et al. 2016; Hinckley et al. 2005; Liu et al. 2021; Porter et al. 2005; Villanueva et al. 2011). No clear associations were observed between chloroform exposure and birth defects (Dodds and King 2001; Grazuleviciene et al. 2013; Hoffman et al. 2008; Kaufman et al. 2018, 2020; Levallois et al. 2012; Rivera-Núñez and Wright 2013) or neurodevelopmental outcomes (Villanueva et al. 2018). A meta-analysis identified a slight (5%) increase in risk of small for gestational age associated with increased chloroform levels in maternal drinking water; however, this increase in risk paralleled the increase (7%) observed for total trihalomethanes in drinking water (Summerhayes et al. 2021).
  ○ [underlined: Evidence from animal studies]: In animals, maternal inhalation during gestation was associated with birth defects in rats, such as missing ribs and acaudate fetuses with imperforate anus, and cleft palate in mice (Murray et al. 1979; Schwetz et al. 1974). These defects were not observed in additional developmental studies in rats exposed via inhalation (Baeder and Hofmann 1988; EPA 1978) or rats or rabbits exposed orally (Ruddick et al. 1983; Thompson et al. 1974). However, delayed ossification and decreased fetal growth were reported in many developmental studies after inhalation or oral exposure, generally at maternally toxic exposure levels (Baeder and Hofmann 1988; Murray et al. 1979; Ruddick et al. 1983; Schwetz et al. 1974; Thompson et al. 1974).
  ○ [underlined: Other relevant data]: Chloroform is known to cross the placenta (Danielsson et al. 1986).

Table C-19 Hazard Identification Conclusions for Chloroform

Outcome | Hazard identification
Respiratory effects | Presumed
Hepatic effects | Known
Renal effects | Presumed
Neurological effects | Known
Developmental effects | Suspected