# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR CHLOROFORM

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to chloroform.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for chloroform. ATSDR primarily focused on peer-reviewed articles without language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of chloroform have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of chloroform are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen^a^

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
In vitro (these studies will be considered su pporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

a Physical-chemical properties are not generally obtained from literature searches, but rather from curated governmental databases such as PubChem.

Prioritization of Human Data. Numerous epidemiological studies evaluate potential associations between exposure to chlorinated drinking water and adverse health outcomes, particularly developmental endpoints and cancer. Epidemiological studies evaluating associations with consumption of chlorinated water or total trihalomethane exposure only were not included in the profile due to availability of studies with chloroform-specific exposure estimates and analyses. Additionally, human epidemiological studies without monitoring data, such as ecological studies based on proximity to emission sources or cohort studies with only self-reported ever/never exposed classifications, were not included in the profile. These studies have limited usefulness due to high risk of exposure misclassification and no information on intensity of potential exposure.

Prioritization of Animal Data. The acute- and intermediate-duration databases for hepatic and renal endpoints in animals following inhalation or oral exposure are extensive. Therefore, animal studies evaluating hepatic and renal endpoints were prioritized for efficient review. Inclusion of hepatic and renal animal studies in Chapter 2 (and the systematic review) was based on the following criteria:

- Acute- and intermediate-duration, single-dose studies that focused only on hepatic and renal endpoints were excluded. All chronic-duration studies and studies evaluating multiple systems were retained regardless of number of dose groups. Lethality data were retained from all studies.
- Only acute- and intermediate-duration studies that evaluated at least one dose within the same order of magnitude (e.g., 0–9, 10–99, 100–999, etc.) of the lowest identified LOAEL for hepatic or renal effects in the 1997 toxicological profile were included. Route- and duration-specific lowest LOAELs are shown in Table B-2. Based on these LOAEL values, only acute-duration inhalation studies evaluating at least one concentration <10 or <100 ppm were included for hepatic and renal endpoints, respectively. For intermediate-duration inhalation studies, only studies evaluating at least one concentration <100 ppm were included for hepatic and renal endpoints. For acute- and intermediate-duration oral studies, only studies evaluating at least one concentration <100 mg/kg/day were included for hepatic and renal endpoints. All chronic-duration studies and studies that evaluated multiple systems were retained regardless of the lowest dose level. Lethality data were retained from all studies.

Table B-2 Lowest LOAELs for Hepatic and Renal Endpoints Reported in 1997 Toxicological Profile

System | Inhalation (ppm) | Oral (mg/kg/day)
Hepatic
Acute | 3 | 34
Intermediate | 25 | 30
Renal
Acute | 29 | 34
Intermediate | 10 | 17.4

### B.1.1 Literature Search

The literature search was conducted to update the Toxicological Profile for Chloroform released in 1997. All literature cited in the previous (1997) toxicological profile were considered for inclusion in the updated profile. The initial literature search, which was performed in September 2020, was restricted to studies added to databases since January 1995. An updated literature search was performed after the Toxicological Profile for Chloroform Draft for Public Comment was released in January 2024 to identify any additional studies added to databases between September 2020 and February 2024. The following main databases were searched in September 2020 and February 2024:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for chloroform. The query strings used for the literature search are presented in Table B-3.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-4. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to chloroform were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-3 Database Query Strings

Database search date | Query string
PubMed
02/2024 | ((“Chloroform”[mh] OR 67-66-3[rn]) AND (2020/09/01:3000[mhda])) OR (((“1,1,1-Trichloromethane”[tw] OR “chloroform”[tw] OR “methane trichloro”[tw] OR “Trichloromethane”[tw] OR “Formyl trichloride”[tw] OR “carbon trichloride”[tw] OR “Freon 20”[tw] OR “HCC 20”[tw] OR “Methane trichloride”[tw] OR “Methenyl chloride”[tw] OR “Methenyl trichloride”[tw] OR “Methyl trichloride”[tw] OR “Methylidyne trichloride”[tw] OR “Trichloroform”[tw] OR ((“F 20”[tw] OR “F20”[tw]) AND “freon*”) OR ((“R 20”[tw] OR “R20”[tw]) AND “refrigerant*”)) NOT medline[sb]) AND (2020/09/01:3000[dp] OR 2020/09/01:3000[crdt] OR 2020/09/01:3000[edat]))
09/2020 | ((((“Chloroform/toxicity”[mh] OR “Chloroform/adverse effects”[mh] OR “Chloroform/poisoning”[mh] OR “Chloroform/pharmacokinetics”[mh]) OR (“Chloroform”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Chloroform”[mh] AND toxicokinetics[mh:noexp]) OR (“Chloroform/blood”[mh] OR “Chloroform/cerebrospinal fluid”[mh] OR “Chloroform/urine”[mh]) OR (“Chloroform”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Chloroform”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Chloroform/antagonists and inhibitors”[mh]) OR (“Chloroform/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Chloroform”[mh] AND cancer[sb]) OR (“Chloroform/pharmacology”[majr])) OR ((“1,1,1-Trichloromethane”[tw] OR “CARBON TRICHLORIDE”[tw] OR “chloroform”[tw] OR “Formyl trichloride”[tw] OR “Freon 20”[tw] OR “HCC 20”[tw] OR “Methane trichloride”[tw] OR “Methane, trichloro-”[tw] OR “Methenyl chloride”[tw] OR “Methenyl trichloride”[tw] OR “Methyl trichloride”[tw] OR “Methylidyne trichloride”[tw] OR “Trichloroform”[tw] OR “Trichloromethane”[tw] OR ((“F 20”[tw] OR “F20”[tw]) AND freon*[tw]) OR ((“R 20”[tw] OR “R20”[tw]) AND refrigerant*[tw])) NOT medline[sb]))) AND (1995:3000[dp] OR 1995:3000[mhda] OR 1995:3000[crdt] OR 1995:3000[edat])
NTRL
02/2024 | Terms in Title or Keyword; limited to 2020-present
| “1,1,1-Trichloromethane” OR “chloroform” OR “methane trichloro” OR “Trichloromethane” OR “Formyl trichloride” OR “carbon trichloride” OR “Freon 20” OR “HCC 20” OR “Methane trichloride” OR “Methenyl chloride” OR “Methenyl trichloride” OR “Methyl trichloride” OR “Methylidyne trichloride” OR “Trichloroform”
09/2020 | Date Published 1995 to 2020
| Fields: Title or Keyword
| “1,1,1-Trichloromethane” OR “CARBON TRICHLORIDE” OR “chloroform” OR “Formyl trichloride” OR “Freon 20” OR “HCC 20” OR “Methane trichloride” OR “Methane, trichloro-” OR “Methenyl chloride” OR “Methenyl trichloride” OR “Methyl trichloride” OR “Methylidyne trichloride” OR “Trichloroform” OR “Trichloromethane”
Toxcenter
02/2024 | FILE ‘TOXCENTER’ ENTERED AT 13:04:32 ON 14 FEB 2024
| L1 38527 SEA FILE=TOXCENTER 67-66-3
| L2 27919 SEA FILE=TOXCENTER L1 NOT PATENT/DT
| L3 4855 SEA FILE=TOXCENTER L2 AND ED>=20200901 ACT TOXQUERY/Q ---------
| L4 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?)
| L5 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,IT)
| L6 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50)
| L7 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT
| L8 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?)
| L9 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?)
| L10 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?)
| L11 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE))
| L12 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?)
| L13 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?)
| L14 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?)
| L15 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?)
| L16 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?)
| L17 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?)
| L18 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?)
| L19 QUE (ENDOCRIN? AND DISRUPT?)
| L20 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?)
| L21 QUE (WEAN? OR OFFSPRING OR AGE(W) FACT OR?)
| L22 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?)
| L23 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?)
| L24 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?)
| L25 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?)
| L26 QUE (NEPHROTOX? OR HEPATOTOX?)
| L27 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?)
| L28 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?)
| L29 QUE L4 OR L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28
| L30 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?)
| L31 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE)
| L32 QUE L29 OR L30 OR L31
| L33 QUE (NONHUMAN MAMMALS)/ORG N
| L34 QUE L32 OR L33
| L35 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?)
| L36 QUE L34 OR L35 ---------
| L37 2780 SEA FILE=TOXCENTER L3 AND L36
| L38 104 SEA FILE=TOXCENTER L37 AND MEDLINE/FS
| L39 2676 SEA FILE=TOXCENTER L37 NOT MEDLINE/FS
| L40 2687 DUP REM L38 L39 (93 DUPLICATES REMOVED)
| L*** DEL 104 S L37 AND MEDLINE/FS
| L*** DEL 104 S L37 AND MEDLINE/FS
| L41 104 SEA FILE=TOXCENTER L40
| L*** DEL 2676 S L37 NOT MEDLINE/FS
| L*** DEL 2676 S L37 NOT MEDLINE/FS
| L42 2583 SEA FILE=TOXCENTER L40
| L43 2583 SEA FILE=TOXCENTER (L41 OR L42) NOT MEDLINE/FS
| D SET
| D SEL
| D CLUSTER
| D SCAN L43
09/2020 | FILE ‘TOXCENTER’ ENTERED AT 12:58:25 ON 25 SEP 2020
| CHARGED TO COST=EH038.05.01 .LB.03
| L1 31178 SEA FILE=TOXCENTER 67-66-3
| L2 30902 SEA FILE=TOXCENTER L1 NOT TSCATS/FS
| L3 21961 SEA FILE=TOXCENTER L2 NOT PATENT/DT
| L4 13834 SEA FILE=TOXCENTER L3 AND PY>1994 ACT TOXQUERY/Q ---------
| L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?)
| L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,IT)
| L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50)
| L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT
| L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?)
| L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?)
| L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?)
| L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE))
| L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?)
| L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?)
| L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?)
| L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?)
| L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?)
| L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?)
| L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?)
| L20 QUE (ENDOCRIN? AND DISRUPT?)
| L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?)
| L22 QUE (WEAN? OR OFFSPRING OR AGE(W) FACT OR?)
| L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?)
| L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?)
| L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?)
| L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?)
| L27 QUE (NEPHROTOX? OR HEPATOTOX?)
| L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?)
| L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?)
| L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29
| L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?)
| L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE)
| L33 QUE L30 OR L31 OR L32
| L34 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?)
| L35 QUE L33 OR L34 ---------
| L36 6707 SEA FILE=TOXCENTER L4 AND L35
| L37 732 SEA FILE=TOXCENTER L36 AND MEDLINE/FS
| L40 1002 SEA FILE=TOXCENTER L36 AND BIOSIS/FS
| L41 4927 SEA FILE=TOXCENTER L36 AND CAPLUS/FS
| L42 46 SEA FILE=TOXCENTER L36 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS)
| L43 5991 DUP REM L37 L40 L42 L41 (716 DUPLICATES REMOVED) ANSWERS ‘1-5991’ FROM FILE TOXCENTER
| L*** DEL 732 S L36 AND MEDLINE/FS
| L*** DEL 732 S L36 AND MEDLINE/FS
| L44 732 SEA FILE=TOXCENTER L43
| L*** DEL 1002 S L36 AND BIOSIS/FS
| L*** DEL 1002 S L36 AND BIOSIS/FS
| L45 794 SEA FILE=TOXCENTER L43
| L*** DEL 4927 S L36 AND CAPLUS/FS
| L*** DEL 4927 S L36 AND CAPLUS/FS
| L46 4428 SEA FILE=TOXCENTER L43
| L*** DEL 46 S L36 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS)
| L*** DEL 46 S L36 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS)
| L47 37 SEA FILE=TOXCENTER L43
| L48 5259 SEA FILE=TOXCENTER (L44 OR L45 OR L46 OR L47) NOT MEDLINE/FS
| L53 732 SEA FILE=TOXCENTER (L49 OR L50 OR L51 OR L52) AND MEDLINE/FS
| L54 769 SEA FILE=TOXCENTER L48 AND PY<=2000
| L56 740 SEA FILE=TOXCENTER L48 AND PY>2000 AND PY<=2005
| L58 1008 SEA FILE=TOXCENTER L48 AND PY>2005 AND PY<=2010
| L60 1449 SEA FILE=TOXCENTER L48 AND PY>2010 AND PY<=2015
| L61 1293 SEA FILE=TOXCENTER L48 AND PY>2015
| L62 5259 SEA FILE=TOXCENTER L54 OR L56 OR L58 OR L60 OR L61
| D SCAN L54
| D SCAN L56
| D SCAN L58
| D SCAN L60
| D SCAN L61

Table B-4 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
02/2024; 09/2020 | 67-66-3
NTP
02/2024 | Date limited: 2020–2024; not dated
| 67-66-3
| “chloroform” “Trichloromethane”
| “1,1,1-Trichloromethane” “methane trichloro” “Formyl trichloride” “carbon trichloride”
| “Freon 20” “HCC 20” “Methane trichloride” “Methenyl chloride”
| “Methenyl trichloride” “Methyl trichloride” “Methylidyne trichloride” “Trichloroform”
09/2020 | Limited to content types: Reports & Publications; Systematic Reviews; ROC Profiles, Reviews, or Candidates; and Testing Status
| 67-66-3
NPIRS
02/2024 | EPA Registration #: 020701
Regulations.gov
02/2024 | Dockets and Documents (limited to 01/01/2020–02/12/2024 and Notices)
| 67-66-3
| “chloroform”
| “Trichloromethane”
| “1,1,1-Trichloromethane”
| “methane trichloro”
| “Formyl trichloride”
| “carbon trichloride”
| “Freon 20”
| “HCC 20”
| “Methane trichloride”
| “Methenyl chloride”
| “Methenyl trichloride”
| “Methyl trichloride”
| “Methylidyne trichloride”
| “Trichloroform”
09/2020 | Limited to rules, proposed rules, notices, other
| 67-66-3
NIH RePORTER
05/2024 | “1,1,1-Trichloromethane” OR “chloroform” OR “methane trichloro” OR “Trichloromethane” OR “Formyl trichloride” OR “carbon trichloride” OR “Freon 20” OR “HCC 20” OR “Methane trichloride” OR “Methenyl chloride” OR “Methenyl trichloride” OR “Methyl trichloride” OR “Methylidyne trichloride” OR “Trichloroform”
02/2023 | Text Search: “1,1,1-Trichloromethane” OR “CARBON TRICHLORIDE” OR “chloroform” OR “Formyl trichloride” OR “Freon 20” OR “HCC 20” OR “Methane trichloride” OR “Methane, trichloro-” OR “Methenyl chloride” OR “Methenyl trichloride” OR “Methyl trichloride” OR “Methylidyne trichloride” OR “Trichloroform” OR “Trichloromethane” (advanced)
| Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process^a^

a References identified throughout the assessment process may include studies found by tree searching; recommended by intraagency, interagency, peer, or public reviewers; or published more recently than the date of the literature search (February 2024). Additional references include those for specific regulations or guidelines and publications found by targeted searches for specific information (e.g., searches for reviews of general [not chemical-specific] mechanisms of toxicity).

The 2020 pre-public comment search results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 10,710
- Number of records identified from other strategies: 133
- Total number of records to undergo literature screening: 10,843

The 2024 post-public comment search results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 4,578
- Number of records identified from other strategies: 166
- Total number of records to undergo literature screening: 4,744

## B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on chloroform during the pre- and post-public comment drafts:

- Title and abstract screen
- Full text screen

Pre-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 10,843
- Number of studies considered relevant and moved to the next step: 833

Pre-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 833
- Number of studies cited in the previous toxicological profile: 286
- Total number of studies cited in the profile: 625

A summary of the results of the pre-public literature search and screening is presented in Figure B-1.

Figure B-1 September 2020 Pre-Public Comment Literature Search Results and Screen for Chloroform

*The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.

Post-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 4,744
- Number of studies considered relevant and moved to the next step: 176

Post-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 176
- Number of studies cited in the pre-public draft of the toxicological profile: 625
- Total number of studies cited in the profile: 685

A summary of the results of the post-public comment literature search and screening is presented in Figure B-2

Figure B-2 May 2024 Post-Public Comment Literature Search Results and Screen for Chloroform*

*The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.