# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106–5, Atlanta, Georgia 30329–4027.

## Chloroform Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroform
CAS Numbers: | 67-66-3
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 0.001 ppm (0.005 mg/m^3^)
Critical Effect: | Nasal lesions
Reference: | Larson et al. 1996; Templin et al. 1996b
Point of Departure: | NOAEL of 2 ppm (NOAEL_HEC_ of 0.04 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 9, 24
Species: | Rat, Mouse

MRL Summary: An acute-duration inhalation MRL of 0.001 ppm was derived for chloroform based on nasal lesions in rats and mice exposed to concentrations ≥10 ppm for 4 days (6 hours/day); a NOAEL of 2 ppm was identified (Larson et al. 1996; Templin et al. 1996b). The MRL is based on the NOAEL of 2 ppm, which was adjusted to continuous duration exposure and converted to a NOAEL_HEC_ of 0.04 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans after dosimetric adjustment and 10 for human variability). The LOAEL_HEC_ value was 0.19 ppm.

Selection of the Critical Effect: No acute-duration human studies with reliable exposure estimates were identified. The most sensitive effects following acute-duration inhalation exposure were hepatic and respiratory effects (Table A-1). Changes to nasal bones and olfactory neuron loss were also observed at similar concentrations as nasal epithelial changes.

Table A-1 Selected NOAEL and LOAEL Values in Animals Following Acute-Duration Inhalation Exposure to Chloroform

Species | Duration | Effect level (ppm) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Hepatic effects
B6C3F1 mouse | 7 days; 6 hours/day | 1.2 | 3 | 18% increase in relative liver weight | Larson et al. 1994c
B6C3F1 mouse | 4 days; 6 hours/day | 2 | 10 | Diffuse lipid hepatocytic vacuolation, scattered hepatocyte necrosis | Larson et al. 1996
Respiratory effects
C57BL/6 mouse | 5 days; 1 hour/day (20 minutes 3 times/day) | ND | 7 | Increased white blood cells in BALF, increased alveolar area, and decreased density of alveolar septa; decreased relative lung weight in females | de Oliveira et al. 2015
Fischer 344 rat | 4 days; 6 hours/day | 2 | 10 | Loss of olfactory glands; periosteal hypercellularity and proliferation; mineralization of the basal lamina; new nasal bone growth | Templin et al. 1996b
B6C3F1 mouse | 4 days; 6 hours/day | 2 | 10 | Connective tissue proliferation in the nasal lamina propria; periosteal cell proliferation in nasal cavity | Larson et al. 1996
B6C3F1 mouse | 7 days; 6 hours/day | 3 | 10 | Nasal periosteal cell proliferation | Mery et al. 1994
Fischer 344 rat | 7 days; 6 hours/day | 3.1 | 10.4 | Goblet cell hyperplasia in nasal respiratory epithelium; olfactory gland degeneration in lamina propria; periosteal proliferation and new bone formation | Larson et al. 1994c; Mery et al. 1994
Nervous system effects
Fischer 344 rat | 7 days; 6 hours/day | 3.1 | 10.4 | Olfactory neuron loss | Larson et al. 1994c; Mery et al. 1994

BALF = bronchoalveolar lavage fluid; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

In order to identify the most sensitive POD, benchmark dose (BMD) modeling was attempted for endpoints in Table A-1 when data were amenable to modeling. The data were fit to all available continuous models in EPA’s Benchmark Dose Software (BMDS; version 3.3) using a benchmark response (BMR) of 1 SD for liver weight, nasal lesion severity score, periosteal labeling index (proliferation), and nasal turbinate width. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, a 95% lower confidence limit on the BMD (BMCL) that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest 95% lower confidence limit concentration (BMCL) was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest Akaike information criterion (AIC) was chosen.

The datasets used for BMD modeling are presented in Table A-2 for elevated liver weight in mice reported by Larson et al. (1994c), Table A-3 for nasal lesion severity score and periosteal proliferation in mice reported by Larson et al. (1996), Table A-4 for periosteal proliferation and width of central nasal turbinate in rats reported by Mery et al. (1994), Table A-5 for periosteal proliferation in mice reported by Mery et al. (1994), and Table A-6 for periosteal proliferation in rats reported by Templin et al. (1996b). Data for increased severity of hepatic lesions in mice were not suitable for modeling because mean severity scores were reported without a measure of variance (Larson et al. 1996). Data for pulmonary effects reported by de Oliveira et al. (2015) were not suitable for modeling because only one exposure group was included. Data for nasal epithelial lesions in rats were not suitable for modeling because incidence data were not provided and/or mean severity scores were reported without a measure of variance (Larson et al. 1994c; Mery et al. 1994; Templin et al. 1996b). ATSDR used the NOAEL/LOAEL approach for endpoints with data unsuitable for BMD modeling.

Table A-2 Relative Liver Weights in Female Mice Following Inhalation Exposure to Chloroform for 7 Days (6 Hours/Day)

Endpoint^a^ | Analytical concentration (ppm)
Endpoint^a^ | 0 | 1.2 | 3 | 10 | 29.5 | 101 | 288
Relative liver weight (% body weight) | 5.7±0.6 (5) | 6.3±0.5 (5) | 6.7±0.7^b^ (5) | 7.0±1.1^b^ (5) | 7.3±0.6^b^ (5) | 9.5±1.7^b^ (5) | 10.1±1.1^b^ (5)

a Mean±SD (number of animals).

b p<0.05.

BW = body weight; SD = standard deviation

Source: Larson et al. 1994c

Table A-3 Nasal Lesions and Periosteal Proliferation in Female Mice Following Inhalation Exposure to Chloroform for 4 Days (6 Hours/Day)

Endpoint^a^ | Analytical concentration (ppm)
Endpoint^a^ | 0 | 0.3 | 2 | 10 | 30 | 88
Severity score^b^ | 0±0 (5) | 0±0 (5) | 0.5±0.5 (5) | 1.6±0.5^c^ (5) | 1.8±1.0^c^ (5) | 2.4±0.5^c^ (5)
Nasal turbinate lamina propria labeling index | 15±8 (5) | 9±3 (5) | 16±5 (5) | 164±49^d^ (5) | 281±158^d^ (5) | 397±27^d^ (5)

a Mean±SD (number of animals).

b Nasal lesions were scored according to a 1–4 score: 0 = within normal limits; 1 = minimal; 2 = mild; 3 = moderate; 4 = severe.

c p<0.05, as calculated for this review.

d p<0.05, as reported by the study authors.

SD = standard deviation

Source: Larson et al. 1996

Table A-4 Periosteal Proliferation and Endoturbinate Width in Male Rats Following Inhalation Exposure to Chloroform for 7 Days (6 Hours/Day)

Endpoint^a^ | Analytical concentration (ppm)
Endpoint^a^
Endpoint^a^ | 0 | 1.5 | 3.1 | 10.4 | 29.3 | 100 | 271
Labelled cells in nasal turbinate
Proximal | 55±30 (5) | 52±41 (5) | 140±130 (5) | 270±54^b^ (5) | 330±100^b^ (5) | 250±95^b^ (5) | 450±110^b^ (5)
Central | 26±15 (5) | 19±13 (5) | 90±13 (5) | 220±80^b^ (5) | 200±60^b^ (5) | 230±110^b^ (5) | 340±140^b^ (5)
Distal | 36±19 (5) | 34±19 (5) | 96±19 (5) | 150±69^b^ (5) | 120±52^b^ (5) | 130±47^b^ (5) | 220±93^b^ (5)
Width of central turbinate (μm) | 41±12 (5) | 45±17 (5) | 40±9 (5) | 61±17^b^ (5) | 51±16^b^ (5) | 66±8^b^ (5) | 68±10^b^ (5)

a Mean±SD (number of animals).

b p<0.05, as reported by the study authors.

SD = standard deviation

Source: Mery et al. 1994

Table A-5 Periosteal Proliferation in Female Mice Following Inhalation Exposure to Chloroform for 7 Days (6 Hours/Day)

Endpoint^a^ | Analytical concentration (ppm)
Endpoint^a^
Endpoint^a^ | 0 | 1.2 | 3 | 10 | 29.5 | 101 | 288
Labelled cells in nasal turbinate
Proximal | 19±11 (5) | 31±32 (5) | 63±34 (5) | 360±94^b^ (5) | 190±130^b^ (5) | 190±100^b^ (5) | 330±70^b^ (5)
Distal | 14±11 (5) | 21±12 (5) | 15±10 (5) | 82±42^b^ (5) | 54±48^b^ (5) | 77±24^b^ (5) | 100±30^b^ (5)
Ventral | 31±23 (5) | 95±130 (5) | 110±140 (5) | 310±49^b^ (5) | 230±140^b^ (5) | 260±160^b^ (5) | 370±130^b^ (5)
Dorsal | 21±13 (5) | 36±69 (5) | 27±14 (5) | 200±11^b^ (5) | 120±74^b^ (5) | 110±140^b^ (5) | 220±140^b^ (5)

a Mean±SD (number of animals).

b p<0.05, as reported by the study authors.

SD = standard deviation

Source: Mery et al. 1994

Table A-6 Periosteal Proliferation in Male Rats Following Inhalation Exposure to Chloroform for 4 Days (6 Hours/Day)

Endpoint^a^ | Concentration (ppm)
Endpoint^a^ | 0 | 2 | 10 | 30 | 90 | 300
Proximal turbinate labeling index | 30±15 (5) | 24±11 (5) | 490±99^b^ (5) | 566±155^b^ (5) | 752±74^b^ (5) | 809±48^b^ (5)

a Mean±SD, estimated from graphically presented data using GrabIt! software (number of animals).

b p<0.05, as reported by the study authors.

SD = standard deviation

Source: Templin et al. 1996b

Details of the modeling results for the model predictions for relative liver weight in female mice reported by Larson et al. (1994c) are in Table A-7. The frequentist, restricted, Exponential 5 model was selected based on the selection criteria outlined above. No adequate models were identified for connective tissue or periosteal cell proliferation in mice following exposure for 4 days (Larson et al. 1996) or periosteal cell proliferation in rats following exposure for 4 days (Templin et al. 1996b) or 7 days (Mery et al. 1994) because they failed to meet conventional goodness-of-fit criteria using constant or nonconstant variance. While statistical model fits were identified for increased width of the central turbinate in rats exposed for 7 days and distal turbinate labeling index in mice exposed for 7 days, inspection of the recommended and alternate models showed poor visual fit, particularly in the low-exposure region of the curves.

Table A-7 Results from Benchmark Dose (BMD) Analysis (Constant Variance) of Relative Liver Weight in Female Mice Following Inhalation Exposure to Chloroform for 7 Days (6 Hours/Day) (Larson et al. 1994c)

Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC
Model | BMC_1SD_^a^ (ppm) | BMCL_1SD_^a^ (ppm) | p-Value^b^ | AIC | Dose below bmc | Dose above bmc
Exponential (model 3)^d^ | | | 0.001 | 116.36 | 3.07 | −0.84
Exponential (model 5)^d,e^ | 16.72 | 9.89 | 0.49 | 101.74 | 0.64 | −0.82
Hill^f^ | 13.97 | 6.94 | 0.43 | 102.16 | 0.46 | −1.03
Polynomial (3-degree)^f^ | | | 0.004 | 113.93 | 0.46 | 2.86
Polynomial (2-degree)^f^ | | | 0.004 | 113.93 | 0.46 | 2.86
Power | | | 0.004 | 113.93 | 0.46 | 2.86
Linear | | | 0.004 | 113.93 | 0.46 | 2.86

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Selected model. The constant variance model provided an adequate fit. Only the Exponential 5 and Hill models provided an adequate fit to the means. BMCLs were sufficiently close (differed by <3-fold). Therefore, the model with the lowest AIC was selected (Exponential 5).

f Coefficients restricted to be positive.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a change of 1 standard deviation from the control); NA = not applicable

In order to accurately compare candidate PODs across different species and target tissues, POD values were converted into human equivalent concentrations (HECs). For systemic (hepatic) effects, exposure was not adjusted for continuous exposure because data provided by the PBPK model by Corley et al. (1990) demonstrate that the arterial blood concentration (CA) of chloroform in the mouse exposed to chloroform for 6 hours reached “periodicity” (the pattern of repeated increases and decreases in arterial blood concentration that occurs when steady state is achieved during repeated intermittent exposures) within 15 minutes following exposure (Table A-8). Therefore, adjustment from 6 hours to 24 hours is not required.

Table A-8 Corley PBPK Model for Chloroform to Simulate 6-Hour Inhalation Exposure in Mice

Time (hours) | Blood concentration (CA) (mg/L)
0.00 | 0.014
0.25 | 0.040
0.50 | 0.041
0.75 | 0.041
1.25 | 0.042
1.50 | 0.042
1.75 | 0.042
2.00 | 0.042
2.25 | 0.042
2.50 | 0.042
3.375 | 0.042
4.5 | 0.042
5.625 | 0.042
6.75 (post-exposure) | 0.0006

Source: Corley et al. (1990) in the Scop version (courtesy of Dr. Nancy Chiu, EPA)

The NOAELs for hepatic effects in mice reported by Larson et al. (1994c, 1996) were converted into NOAEL_HEC_ values using guidance from EPA (1994) on dosimetric adjustments for systemic effects using the ratio of animal:human blood gas partition coefficients. In the case of chloroform, using reported blood:air partition coefficients of 21.3 for the mouse and 7.34 for the human (Corley et al. 1990) provides a ratio of mouse: human partition coefficients >1; therefore, a default value of 1 is used to derive the NOAEL_HEC._

Larson et al. (1994c), 7-day mouse study (increased relative liver weight):

B M C L_H E C_ = B M C L × (mouse partition coefficient)/(human partition coefficent) = 9.9 p p m × 1 = 9.9 p p m

Larson et al. (1996), 4-day mouse study (hepatic lesions):

N O A E L_H E C_ = N O A E L × (mouse partition coefficient)/(human partition coefficent) = 2 p p m × 1 = 2 p p m

The candidate POD values for nasal effects were adjusted to continuous exposure because kinetic data reported by Sarangapani et al. (2002) indicate that the periodicity reported by Corley et al. (1990) is not applicable to nasal tissue exposures. Using a PBPK model, Sarangapani et al. (2002) showed a steeper external exposure-internal dose relationship for the nasal compartment compared to the hepatic compartment. This steeper dose relationship is driven by the tissue:air partition coefficient and is relatively insensitive to the blood perfusion rate or other systemic parameters. Additionally, longer-duration studies indicate increased severity of nasal lesions with increased duration of exposure, which further supports duration-adjustment for nasal effects. Since the nasal bone effects and olfactory neuron loss are presumably due to portal-of-entry effects, extrathoracic HEC calculations were applied for these endpoints as well.

For each study evaluating nasal endpoints, POD_ADJ_ values were converted to POD_HEC_ values using guidance from EPA (1994) on dosimetric adjustments for respiratory effects using the regional gas dose ratio (RGDR) for extrathoracic effects (RGDR_ET_). This RGDR_ET_ is calculated using the following equation as defined by EPA (1994):

R G D R_E T_ = (V_E_a__)/(S A_a_) ÷ (V_E_h__)/(S A_h_)

- where:
- V_E_a__ = ventilation rate for animals: male F344 rats = 0.137 L/minute; female B6C3F1 mice = 0.028 L/minute
- S A_a_ = surface area of the extrathoracic region in rats = 15 cm^2^
- V_E_h__ = ventilation rate for humans = 13.8 L/minute
- S A_h_ = surface area of the extrathoracic region in humans = 200 cm^2^

Note, below, that rat and mouse have different extrathoracic RGDR values and these will be critical in calculating NOAEL_HEC_ values for each endpoint.

Rat: R G D R_E T_ = (V_E_a__)/(S A_a_) ÷ (V_E_h__)/(S A_h_) = (0.137)/(15) ÷ (13.8)/(200) = 0.132 Mouse: R G D R_E T_ = (V_E_a__)/(S A_a_) ÷ (V_E_h__)/(S A_h_) = (0.028)/(3) ÷ (13.8)/(200) = 0.136

Templin et al. (1996b); 4-day study in rats (nasal lesions and bone growth, periosteal proliferation):

N O A E L_A D j_ = N O A E L × (hours / day)/(24 hours) × (days / week)/(7 days) = 2 p p m × (6 hours)/(24 hours) × (4 days)/(7 days) = 0.3 p p m N O A E L_H E C_ = N O A E L_A D J_ × R G D R = 0.3 p p m × 0.132 = 0.04 p p m

Larson et al. (1996); 4-day study in mice (nasal lesions, periosteal proliferation):

N O A E L_A D j_ = N O A E L × (hours / day)/(24 hours) × (days / week)/(7 days) = 2 p p m × (6 hours)/(24 hours) × (4 days)/(7 days) = 0.3 p p m N O A E L_H E C_ = N O A E L_A D J_ × R G D R = 0.3 p p m × 0.136 = 0.04 p p m

Larson et al. (1994c) and Mery et al. (1994); 7-day study in rats (nasal lesions, bone growth, periosteal proliferation; olfactory neuron loss):

N O A E L_A D J_ = N O A E L × (hours / day)/(24 hours) × (days / week)/(7 days) = 3.1 p p m × (6 hours)/(24 hours) × (7 days)/(7 days) = 0.78 p p m N O A E L_H E C_ = N O A E L_A D J_ × R G D R = 0.78 p p m × 0.132 = 0.10 p p m

Mery et al. (1994); 7-day study in mice (nasal periosteal proliferation):

N O A E L_A D J_ = N O A E L × (hours / day)/(24 hours) × (days / week)/(7 days) = 3 p p m × (6 hours)/(24 hours) × (7 days)/(7 days) = 0.8 p p m N O A E L_H E C_ = N O A E L_A D J_ × R G D R = 0.8 p p m × 0.136 = 0.1 p p m

The LOAEL value for pulmonary effects in mice reported by de Oliveira et al. (2015) was adjusted to continuous exposure because it is unknown if the periodicity reported by Corley et al. (1990) for systemic effects is applicable to pulmonary effects. The LOAEL_ADJ_ was then converted to a LOAEL_HEC_ using guidance from EPA (1994) on dosimetric adjustments for respiratory effects using the RGDR for pulmonary effects (RGDR_PU_). The RGDR_PU_ is calculated using the following equation as defined by EPA (1994):

R G D R_P U_ = (Q_a l v_a__)/(S A_a_) ÷ (Q_a l v_h__)/(S A_h_) = (0.028)/(0.05) ÷ (13.8)/(54) = 2.19

- where:
- Q_a l v_a__ = alveolar ventilation rate for B6C3F1 mice = 0.028 L/minute
- S A_a_ = surface area of the pulmonary region in mice = 0.05 m^2^
- Q_a l v_h__ = alveolar ventilation rate for humans = 13.8 L/minute
- S A_h_ = surface area of the pulmonary region in humans = 54 m^2^

Applying this equation results in an RGDR of 2.191304 for pulmonary effects in mice, and the HEC is calculated as shown below.

de Oliveira et al. (2015); 5-day study in mice (pulmonary effects):

L O A E L_A D j_ = L O A E L × (hours / day)/(24 hours) × (days / week)/(7 days) = 7 ppm × (1 hours)/(24 hours) × (5 days)/(7 days) = 0.2 p p m L O A E L_H E C_ = L O A E L_A D J_ × R G D R = 0.2 p p m × 2.19 = 0.4 p p m

All candidate POD_HEC_ values are summarized in Table A-9. Based on POD_HEC_ values, the lowest POD identified was for nasal effects in rats and mice, with a NOAEL_HEC_ value of 0.04 ppm. Therefore, nasal effects were selected as the critical effect.

Table A-9 Summary of Candidate Effects and POD Values Considered for Derivation of an Acute-Duration Inhalation MRL for Chloroform

Species | Duration | Effect | Candidate POD (ppm) | POD type | Reference
Hepatic effects
B6C3F1 mouse | 7 days; 6 hours/day | Increased relative liver weight | 9.9 | BMCL_HEC_ | Larson et al. 1994c
B6C3F1 mouse | 4 days; 6 hours/day | Increased severity of hepatic lesions | 2 | NOAEL_HEC_ | Larson et al. 1996
Respiratory effects
C57BL/6 mouse | 5 days; 1 hour/day (20 minutes 3 times/day) | Increased white blood cells in BALF, increased alveolar area, and decreased density of alveolar septa; decreased relative lung weight in females | 0.4 | LOAEL_HEC_ | de Oliveira et al. 2015
Fischer 344 rat | 4 days; 6 hours/day | Nasal epithelial lesions, periosteal proliferation, new bone growth | 0.04 | NOAEL_HEC_ | Templin et al. 1996b
B6C3F1 mouse | 4 days; 6 hours/day | Nasal epithelial lesions, periosteal proliferation | 0.04 | NOAEL_HEC_ | Larson et al. 1996
B6C3F1 mouse | 7 days; 6 hours/day | Nasal periosteal proliferation | 0.1 | NOAEL_HEC_ | Mery et al. 1994
Fischer 344 rat | 7 days; 6 hours/day | Nasal epithelial lesions, periosteal proliferation, new bone growth | 0.10 | NOAEL_HEC_ | Larson et al. 1994c; Mery et al. 1994
Nervous system effects
Fischer 344 rat | 7 days; 6 hours/day | Olfactory neuron loss | 0.10 | NOAEL_HEC_ | Larson et al. 1994c; Mery et al. 1994

BALF = bronchoalveolar lavage fluid; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL = 95% lower confidence limit on the BMC; HEC = human equivalent concentration; LOAEL = lowest observed adverse effect level; MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level; POD = point of departure

Selection of the Principal Study: Templin et al. (1996b) and Larson et al. (1996) were selected as co-principal studies because they provided the lowest candidate POD (0.04 ppm) for the critical effect (nasal lesions).

Summary of the Principal Study:

Templin MV, Larson JL, Butterworth BE, . 1996b. A 90-day chloroform inhalation study in F-344 rats: profile of toxicity and relevance to cancer studies. Fundam Appl Toxicol 32(1):109–125.8812246

Larson JL, Templin MV, Wolf DC, . 1996. A 90-day chloroform inhalation study in female and male B6C3F1 mice: implications for cancer risk assessment. Fundam Appl Toxicol 30(1):118–137. 10.1006/faat.1996.0049.8812250

Templin et al. (1996b) exposed 9-week-old male F344 rats (5/sex/group) to target concentrations of 0, 2, 10, 30, 90, or 300 ppm chloroform for 4 days (6 hours/day). In all animals, bromodeoxyuridine (BrdU) was administered 3.5 days prior to sacrifice. Endpoints evaluated included clinical signs, body weight, gross necropsy, histopathology (liver, kidney, nasal cavity, non-nasal bones (sternum, rib, vertebrae, tibia, femur), and cellular proliferation (BrdU labeling index) in liver, kidney, and bone.

Average analytical exposure concentrations were always within 4.5% of the target (quantitative values not reported). No deaths were reported. Body weight gains were significantly decreased compared to control in all exposure groups. Controls gained approximately 3% during the exposure period, while rats exposed to 2, 10, 30, 90, or 300 ppm lost approximately 2, 3, 3, 5, and 14% of their initial body weight (estimated based on graphically presented data). No histopathological lesions were observed in the liver, but the BrdU labelling index showed significantly increased hepatocellular proliferation at 300 ppm. Minimal vacuolation of proximal convoluted tubules was observed in 5/5 mice at 300 ppm; no renal cell proliferation was noted. In the nasal cavity, lesions were noted in at ≥10 ppm. The lesions were primarily observed in the ethmoid portion lined with olfactory epithelium (ventral and lateral regions of turbinates), including lesions within the lamina propria characterized by edema, loss of deep Bowman's glands, periosteal hypercellularity, and new bone growth in the proximal portions of the ethmoturbinates. The severity and relative distribution of the lesions were concentration-dependent, ranging from minimal involvement in rats exposed to 10 ppm to moderate to severe effects in rats exposed to 300 ppm. Focal atrophy of the olfactory epithelium was noted in rats exposed to 90 or 300 ppm.

Larson et al. (1996) investigated the ability of chloroform vapors to produce toxicity and regenerative cell proliferation in the liver, kidneys, and nasal passages of female B6C3F1 mice. Groups of five animals were exposed to target concentrations of 0, 0.3, 2, 10, 30, or 90 ppm chloroform (via inhalation for 6 hours/day for 4 consecutive days). At necropsy, livers and kidneys were removed, weighed, examined macroscopically, and prepared for microscopic evaluation. The nasal cavities and non-nasal bones (sternum with rib, vertebrae, tibia, femur) were also removed and prepared for microscopic evaluation. Animals were administered BrdU via an implanted osmotic pump for the last 3.5 days. Cell proliferation was quantitated as the percentage of cells in S-phase (labeling index [LI]) measured by immuno-histochemical detection of BrdU-labeled nuclei.

Analytical concentrations were 0, 0.3, 1.99, 10.0, 29.6, and 88 ppm. No clinical signs of toxicity were noted in females exposed to chloroform for 4 days. Relative kidney weights were similar to controls at all chloroform exposure levels; however, exposure to 90 ppm chloroform resulted in increased relative liver weights. Female mice exposed to chloroform for 4 days experienced a dose-dependent mild response of uniform hepatocyte lipid vacuolization. Scattered hepatocyte necrosis also occurred in a dose-dependent manner. Hepatic LI was significantly elevated in female mice in the 90-ppm dose group after 4 days exposure (9-fold; p<0.05). Kidneys of female mice exposed to chloroform were not different from those of controls at any dose. Exposure to chloroform did not significantly affect the kidney cortex LI in females at any dose. Mild, transient changes occurred in the posterior ventral areas of nasal tissue in female mice exposed to 10, 30, and 90 ppm chloroform. The lesions were characterized by mild proliferative responses in the periosteum consisting of a thickening of this bone. The adjacent lamina also exhibited loss of acini of Bowman’s glands and vascular congestion. No microscopic changes were noted in non-nasal bones, nor were non-nasal bone LIs different from those of controls.

Selection of the Point of Departure for the MRL: The NOAEL of 2 ppm based on nasal lesions in rats and mice was selected as the POD as it provides the lowest POD for the critical effect. As mentioned above, data were either unavailable for BMD modeling (Templin et al. 1996b) or failed to produce any model fits (Larson et al. 1996).

Adjustment for Intermittent Exposure and Human Equivalent Concentration: As shown above in equations after Table A-8, the NOAEL of 2 ppm was adjusted for continuous exposure and converted into a NOAEL_HEC_ of 0.04 ppm. The associated LOAEL of 10 ppm was adjusted for continuous exposure and converted into a LOAEL_HEC_ of 0.19 ppm as shown below.

Templin et al. (1996b); rats:

L O A E L_A D j_ = L O A E L × (hours / day)/(24 hours) × (days / week)/(7 days) = 10 p p m × (6 hours)/(24 hours) × (4 days)/(7 days) = 1.4 p p m L O A E L_H E C_ = L O A E L_A D J_ × R G D R = 1.4 p p m × 0.132 = 0.19 p p m

Larson et al. (1996); mice:

L O A E L_A D j_ = L O A E L × (hours / day)/(24 hours) × (days / week)/(7 days) = 10 p p m × (6 hours)/(24 hours) × (4 days)/(7 days) = 1.4 p p m L O A E L_H E C_ = L O A E L_A D J_ × R G D R = 1.4 p p m × 0.136 = 0.19 p p m

Uncertainty Factors: The following uncertainty factors were applied to the NOAEL_HEC_ to derive the MRL:

- Uncertainty factor of 3 for extrapolation from animals to humans with dosimetric adjustments
- Uncertainty factor of 10 for human variability

Subsequently, the MRL for acute-duration exposure to chloroform via inhalation is:

M R L = (N O A E L_H E C_)/(( U F )) = (0.04 p p m)/(30) = 0.001 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that respiratory effects are a presumed health effect following exposure to chloroform based on inadequate evidence from human epidemiology studies and a high level of evidence from animal studies (Appendix C).

Lung damage has been reported in several fatal cases of inhalation exposure (Ago et al. 2011; Featherstone 1947; Giusti and Chiarotti 1981; Harada et al. 1997; Piersol et al. 1933; Royston 1924; Schroeder 1965). Case reports have also documented changes in respiratory rate and/or respiratory arrest at high exposure levels (Jayaweera et al. 2017; Storms 1973; Whitaker and Jones 1965), but these effects are likely secondary to CNS depression. No data pertaining to potential nasal effects in humans following exposure to chloroform were identified. In animals, the nasal epithelium is a consistent target of toxicity in rodents following acute-, intermediate-, and chronic-duration inhalation exposure (Constan et al. 1999; Kasai et al. 2002; Larson et al. 1994c, 1996; Mery et al. 1994; Templin et al. 1996b; Yamamoto et al. 2002) and acute- and intermediate-duration gavage exposure (Dorman et al. 1997; Larson et al. 1995b; Templin et al. 1996a). Findings show a dose- and duration-dependent increase in the incidence and severity of lesions. The MRL based on nasal lesions is expected to be protective of lower respiratory effects, as damage to the lower respiratory tract in animals was generally only observed at lethal exposure levels (Bowman et al. 1978; Kasai et al. 2002; NCI 1976). Only minimal evidence of inflammatory responses has been reported in the lung at low inhalation exposure levels in mice (de Oliveira et al. 2015).

Agency Contacts (Chemical Managers): Rae T. Benedict, Ph.D.

## Chloroform Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroform
CAS Numbers: | 67-66-3
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.0008 ppm (0.004 mg/m^3^)
Critical Effect: | Nasal lesions
Reference: | Templin et al. 1996b
Point of Departure: | LOAEL of 2 ppm (LOAEL_HEC_ of 0.07 ppm)
Uncertainty Factor: | 90
LSE Graph Key: | 37
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.0008 ppm was derived for chloroform based on nasal lesions in rats exposed to concentrations ≥2 ppm for 13 weeks (7 days/week; 6 hours/day); a NOAEL was not identified (Templin et al. 1996b). The MRL is based on the LOAEL of 2 ppm, which was adjusted to continuous duration exposure and converted to a LOAEL_HEC_ of 0.07 ppm and divided by a total uncertainty factor of 90 (3 for use of a minimal LOAEL, 3 for extrapolation from animals to humans after dosimetric adjustment, and 10 for human variability).

Selection of the Critical Effect: No intermediate-duration human studies with reliable exposure estimates were identified. The most sensitive effects following intermediate-duration inhalation exposure were respiratory effects, specifically damage to the nasal turbinates and overlying epithelial tissues (Table A-10).

Table A-10 Selected NOAEL and LOAEL Values in Animals Following Intermediate-Duration Inhalation Exposure to Chloroform

Species | Duration | Effect level (ppm) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Respiratory
Fischer 344 rats | 6 or 13 weeks; 7 days/week; 6 hours/day | ND | 2 | Loss of olfactory glands and edema in the nasal lamina propria; atrophy of ethmoid turbinate | Templin et al. 1996b
Fischer 344 rats | 3 weeks; 7 days/week; 6 hours/day | 2 | 10 | Loss of olfactory glands; edema, and cellular proliferation in the nasal lamina propria | Templin et al. 1996b
BDF1 mouse | 13 weeks; 5 days/week; 6 hours/day | ND | 12 | Eosinophilic change of olfactory and respiratory epithelia in females; thickening of nasal bones in both sexes | Kasai et al. 2002
Body weight
BDF1 mouse | 13 weeks 5 days/week; 6 hours/day | ND | 5 | 17% decrease in percent body weight gain | Templin et al. 1998
Renal
BDF1 mouse | 13 weeks; 5 days/week; 6 hours/day | ND | 12 | Necrosis and cytoplasmic basophilia in the proximal tubules and proteinuria in males | Kasai et al. 2002

LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: The 13-week study in rats by Templin et al. (1996b) was selected as the principal study because it provided the lowest candidate POD for the critical effect (nasal lesions).

Summary of the Principal Study:

Templin MV, Larson JL, Butterworth BE, . 1996b. A 90-day chloroform inhalation study in F-344 rats: profile of toxicity and relevance to cancer studies. Fundam Appl Toxicol 32(1):109–125.8812246

Templin et al. (1996b) exposed nine-week-old male and female F344 rats (10/sex/group) to target concentrations of 0, 2, 10, 30, 90, or 300 ppm chloroform for 13 weeks via whole-body inhalation (7 days/week; 6 hours/day). BrdU was administered 3.5 days prior to sacrifice in 8/group in control and 30-, 90-, and 300-ppm groups. Endpoints evaluated included clinical signs, body weight, organ weights (liver and kidney), gross necropsy, histopathology on a complete set of tissues, and cell proliferation in the liver, kidney, and nasal tissues.

Average analytical exposure concentrations were always within 4.5% of the target (quantitative data not reported). No deaths were reported. Rats receiving the higher concentrations of chloroform exhibited signs of mild dehydration in the second week and, at the later time points, slight hair loss, discharge from the eyes and anogenital staining (data not shown). Body weight gains were significantly decreased in males at 90 ppm (40%) and 300 ppm (9%), compared to control (54%); estimated based on graphically presented data. In females, body weight gain was significantly decreased at 10 ppm (29%), 30 ppm (30%), 90 ppm (20%), and 300 ppm (5%), compared to control (36%); estimated based on graphically presented data. Relative liver weights were increased in males at 300 ppm (~30%) and in females increased at 90 ppm (~10%) and 300 ppm (~50%). Relative kidney weights were increased at 90 ppm in males (~10%) and females (~25%) and at 300 ppm in males (~30%) and females (~50%). Organ weight findings may be secondary to body weight effects (absolute organ weights were not reported); however, the study authors noted that increased female liver weight was associated with periductal fibrosis. Hepatocellular vacuolation and hepatocyte degeneration and/or necrosis was observed in both sexes at ≥90 ppm. Foci of adenofibrosis (intestinal-crypt-like ducts with periductular fibrosis) were observed in both sexes at 300 ppm (more severe in females). Hepatocellular proliferation was observed in both sexes at 300 ppm. In the kidney, vacuolation in the proximal convoluted tubule and scattered focal necrosis were observed in males at ≥90 ppm. Females showed scattered regenerating proximal convoluted tubules with anisokaryosis and megalokaryosis. Renal cell proliferation was observed in both sexes at ≥30 ppm. Nasal lesions were observed in 100% of exposed male rats; no nasal lesions were observed in control males. The most prevalent effects were atrophy of the ethmoid turbinates, loss of Bowman’s glands, and mild-to-moderate edema in the lamina propria. Mineralization of the basal lamina was observed at 300 ppm and the olfactory epithelium showed focal edema and conversion to respiratory epithelium. Lesions were minimal at 2 ppm, mild at 10 and 30 ppm, mild-to-moderate at 90 ppm, and moderate-to-severe at 300 ppm. The study authors noted that nasal lesions in female rats were “similar to those found in the male;” however, quantitative data were not provided. Nasal cellular proliferation was noted at ≥10 ppm. No other tissue was affected by chloroform exposure.

Selection of the Point of Departure for the MRL: The LOAEL of 2 ppm based on nasal lesions in male rats was selected as the POD as it provides the lowest POD for the critical effect. The data are not amenable to BMD modeling because the response in male rats goes from 0% incidence in the control group to 100% incidence in all exposure groups.

Adjustment for Intermittent Exposure: The LOAEL of 2 ppm was adjusted for continuous exposure.

L O A E L_A D J_ = L O A E L × (hours / day)/(24 hours) × (days / week)/(7 days) = 2 p p m × (6 hours)/(24 hours) × (7 days)/(7 days) = 0.5 p p m

Human Equivalent Concentration: Sarangapani et al. (2002) is the only published chloroform model that simulates doses to the nasal cavity tissues. The model has been validated against observations made in rats, but not other laboratory animal models or humans. ATSDR typically requires that models used for dosimetry extrapolation in derivation of MRLs be validated in the species to which they are applied. As the principal study uses mice, the Sarangapani et al. (2002) model was not used for dosimetry extrapolation in deriving the intermediate-duration inhalation MRL. Instead, the LOAEL_ADJ_ was converted to a LOAEL_HEC_ using guidance from EPA (1994) on dosimetric adjustments for respiratory effects using the RGDR_ET_. This RGDR_ET_ is calculated using the following equation as defined by EPA (1994):

R G D R_E T_ = (V_E_a__)/(S A_a_) ÷ (V_E_h__)/(S A_h_) = (0.137)/(15) ÷ (13.8)/(200) = 0 . 1 3 2

- where:
- V_E_a__ = ventilation rate for male F344 rats = 0.137 L/minute
- S A_a_ = surface area of the extrathoracic region in rats = 15 cm^2^
- V_E_h__ = ventilation rate for humans = 13.8 L/minute
- S A_h_ = surface area of the extrathoracic region in humans = 200 cm^2^

Applying this equation results in an RGDR of 0.13 for extrathoracic effects in F344 rats, and the HEC is calculated as:

L O A E L_H E C_ = L O A E L_A D J_ × R G D R = 0.5 p p m × 0.132 = 0.07 p p m

Uncertainty Factors: The following uncertainty factors were applied to the LOAEL_HEC_ to derive the MRL:

- Uncertainty factor of 3 for use of a minimal LOAEL (nasal lesions of minimal severity)
- Uncertainty factor of 3 for animal to human extrapolation with applying dosimetric adjustment
- Uncertainty factor of 10 for human variability

Subsequently, the inhalation MRL for intermediate-duration exposure to chloroform is:

M R L = (L O A E L_H E C_)/((U F)) = (0.07 ppm)/(90) = 0.0008 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that respiratory effects are a presumed health effect following exposure to chloroform based on inadequate evidence from human epidemiology studies and a high level of evidence from animal studies (Appendix C).

Lung damage has been reported in several fatal cases of inhalation exposure (Ago et al. 2011; Featherstone 1947; Giusti and Chiarotti 1981; Harada et al. 1997; Piersol et al. 1933; Royston 1924; Schroeder 1965). Case reports have also documented changes in respiratory rate and/or respiratory arrest at high exposure levels (Jayaweera et al. 2017; Storms 1973; Whitaker and Jones 1965), but these effects are likely secondary to CNS depression. No data pertaining to potential nasal effects in humans following exposure to chloroform were identified. In animals, the nasal epithelium is a consistent target of toxicity in rodents following acute-, intermediate-, and chronic-duration inhalation exposure (Constan et al. 1999; Kasai et al. 2002; Larson et al. 1994c, 1996; Mery et al. 1994; Templin et al. 1996b; Yamamoto et al. 2002) and acute- and intermediate-duration gavage exposure (Dorman et al. 1997; Larson et al. 1995b; Templin et al. 1996a). Findings show a dose- and duration-dependent increase in the incidence and severity of lesions.

Agency Contact (Chemical Manager): Rae T. Benedict, Ph.D.

## Chloroform Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroform
CAS Numbers: | 67-66-3
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic
MRL: | 0.0004 ppm (0.002 mg/m^3^)
Critical Effect: | Nasal lesions
Reference: | Yamamoto et al. 2002
Point of Departure: | LOAEL of 5.0 ppm (LOAEL_HEC_ of 0.11 ppm)
Uncertainty Factor: | 300
LSE Graph Key: | 52
Species: | Mouse

MRL Summary: A chronic-duration inhalation MRL of 0.0004 ppm was derived for chloroform based on nasal lesions in female mice exposed to concentrations ≥5 ppm for 104 weeks (5 days/week; 6 hours/day); a NOAEL was not identified (Yamamoto et al. 2002). The MRL is based on the LOAEL of 5.0 ppm, which was adjusted to continuous duration exposure and converted to a LOAEL_HEC_ of 0.11 ppm and divided by a total uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans after dosimetric adjustment, and 10 for human variability).

Selection of the Critical Effect: Both human and animal data were considered while determining the critical effects (Table A-11). The only chronic-duration human study with dose-response data is an occupational study by Li et al. (1993). A LOAEL of 2.76 ppm was identified for workers occupationally exposed to chloroform for 1–15 years based on impaired performance on the pursuit aiming task, indicating impaired hand-eye coordination. In animal studies, the most sensitive target of toxicity was nasal effects in mice at ≥5 ppm.

Table A-11 Selected NOAEL and LOAEL Values in Humans and Animals Following Chronic-Duration Inhalation Exposure to Chloroform

Species | Duration | Effect level (ppm) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Neurological
Human | 1–15 years; 5 days/week^a^; 8 hours/day^a^ | ND | 2.76 | Impaired hand-eye coordination | Li et al. 1993
Respiratory
BDF1 mouse | 104 weeks; 5 days/week; 6 hours/day | ND | 5.0 | Atrophy and respiratory metaplasia of the olfactory epithelium; thickening of nasal bones | Yamamoto et al. 2002
Fischer 344 rat | 104 weeks; 5 days/week; 6 hours/day | ND | 10.1 | Atrophy and respiratory metaplasia of the olfactory epithelium; thickening of nasal bones | Yamamoto et al. 2002
Renal
Fischer 344 rat | 104 weeks; 5 days/week; 6 hours/day | 10.1 | 30.0 | Nuclear enlargement of the proximal tubules and dilation of the tubular lumen | Yamamoto et al. 2002

a Assuming a 40-day work week.

LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

In order to accurately compare PODs across study designs, species, and target tissues, candidate PODs were adjusted for continuous exposure in both studies, and a HEC value was calculated for the nasal effects in mice.

Li et al. (1993); human (neurological effects):

L O A E L_A D j_ = L O A E L × (hours / day)/(24 hours) × (days / week)/(7 days) = 2.76 p p m × (8 hours)/(24 hours) × (5 days)/(7 days) = 0.657 p p m

Yamamoto et al. (2002) ; mouse (nasal effects):

The nasal LOAEL was adjusted for continuous exposure.

L O A E L_A D j_ = L O A E L × (hours / day)/(24 hours) × (days / week)/(7 days) = 5.0 ppm × (6 hours)/(24 hours) × (5 days)/(7 days) = 0.89 p p m

The LOAEL_ADJ_ was converted to a LOAEL_HEC_ using guidance from EPA (1994) on dosimetric adjustments for respiratory effects using the RGDR_ET_. This RGDR_ET_ is calculated using the following equation as defined by EPA (1994):

R G D R_E T_ = (V_E_a__)/(S A_a_) ÷ (V_E_h__)/(S A_h_) = (0.0245)/(3) ÷ (13.8)/(200) = 0.118

- where:
- V_E_a__ = ventilation rate for female BDF1 mice = 0.0245 L/minute (Yamamoto et al. 2002)
- S A_a_ = surface area of the extrathoracic region in mice = 3 cm^2^ (EPA 1994)
- V_E_h__ = ventilation rate for humans = 13.8 L/minute (EPA 1994)
- S A_h_ = surface area of the extrathoracic region in humans = 200 cm^2^ (EPA 1994)

Applying this equation results in an RGDR of 0.118 for extrathoracic effects in female BDF1 mice, and the HEC is calculated as shown below.

L O A E L_H E C_ = L O A E L_A D J_ × R G D R = 0.89 ppm × 0.118 = 0.11 ppm

The candidate human and animal chronic-duration inhalation PODs are summarized in Table A-12.

Table A-12 Summary of Candidate Effects and POD Values Considered for Derivation of a Chronic-Duration Inhalation MRL for Chloroform

Species | Duration | Effect | Candidate POD (ppm) | POD type | Reference
Neurological effects
Human | 1–15 years; 5 days/week^a^; 8 hours/day^a^ | Impaired hand-eye coordination | 0.657 | LOAEL_ADJ_ | Li et al. 1993
Respiratory effects
BDF1 mouse | 104 weeks; 5 days/week; 6 hours/day | Atrophy and respiratory metaplasia of the olfactory epithelium; thickening of nasal bones | 0.11 | LOAEL_HEC_ | Yamamoto et al. 2002

a Assuming a 40-hour work week.

ADJ = adjusted; HEC = human equivalent concentration; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; POD = point of departure

Based on values in Table A-12, nasal lesions were selected as the critical effect because they provide the lowest candidate POD. Additionally, there is clear evidence of concentration- and duration-dependent increases in incidence and/or severity of nasal lesions in acute-, intermediate-, and chronic-duration animal studies. While selecting neurological effects from the human study would decrease uncertainty with regard to animal to human extrapolation, there are considerable uncertainties associated with the study by Li et al. (1993), including: 1) limited information regarding methods and timing of exposure assessment; 2) limited information regarding controls (identified only as individuals “without obvious exposure to occupational hazards”; 3) no information on potential concurrent exposures to other solvents or potentially neurotoxic compounds; and 4) relatively small group numbers, especially at the LOAEL (60 control, 14 low-exposure [2.76 ppm], 46 high-exposure [6.04 ppm]). Based on these limitations, systematic review determined that the Li et al. (1993) is a second-tier risk of bias study of low confidence (Appendix C).

Selection of the Principal Study: The 104-week study in mice by Yamamoto et al. (2002) was selected as the principal study because it provided the lowest candidate POD (0.11 ppm) for the critical effect (nasal lesions).

Summary of the Principal Study:

Yamamoto S, Kasai T, Matsumoto, . 2002. Carcinogenicity and chronic toxicity in rats and mice exposed to chloroform by inhalation. J Occup Health 44(5):283–293. 10.1539/joh.44.283.

Six-week-old male and female Crj:BDF1 mice (50/sex/group) were exposed to 0, 5, 30, or 90 ppm chloroform via whole-body inhalation for 6 hours/day, 5 days/week, for 104 weeks. Analytical concentrations were reported as 5.0, 10.1, 30.0, and 90.1 ppm. To avoid lethality, the 30- and 90-ppm exposure groups underwent stepwise exposure paradigms over the first 4–6 weeks. Time weighted averages (TWAs) were calculated from the analytical concentrations and exposure duration (2 weeks at 5.0 ppm, 2 weeks at 10.1 ppm, and 100 weeks at 30.0 ppm for the 30-ppm group; 2 weeks at 5.0 ppm, 2 weeks at 10.1 ppm, 2 weeks at 30.0 ppm, and 98 weeks at 90.1 ppm for the 90-ppm group), resulting in final TWA exposure concentrations of 0, 5.0, 29.1, and 85.8 ppm. Endpoints evaluated included lethality, clinical signs, body weight, food and water intake, hematology, blood chemistry, urinalysis, organ weights, gross necropsy, and histopathology. A complete set of tissues were examined.

Chloroform exposure did not affect survival rate (50–76%) or lead to any overt clinical signs of toxicity compared to control (using the stepwise protocol). Body weight was significantly decreased in males and females at all doses throughout the first year of the study, but subsequently recovered to control levels in the two lower dose female groups. The magnitude of decrease is unknown (data not reported). Food consumption was similar between exposed and control mice. No significant changes in hematological parameters were observed (data not shown). Serum chemistry changes included significant increases in serum AST, ALT, and BUN in males and females at 85.8 ppm. Serum ALP was also increased in males. No difference was seen in the urinalysis. Absolute, but not relative, kidney weight was significantly increased in males at 85.8 ppm (data not shown; attributed to tumors). No other organ weight data were reported. Gross examination showed increased incidences of renal nodules in males at 29.1 and 85.8 ppm, but not in the females (data not shown). Microscopic changes included significant increases in fatty change in the liver of males and females at 85.8 ppm and lesions in the renal proximal tubule (nuclear enlargement, cytoplasmic basophilia, hyperplasia) in males at ≥29.1 ppm. Kidney damage in females was markedly lower than in males, with the only change being a slight significant increase in cytoplasmic basophilia at 85.8 ppm. In the nasal cavity, thickening of bone was noted in both sexes at ≥5.0 ppm exposure with atrophy and respiratory metaplasia of the olfactory epithelium occurring in males at 85.8 ppm and in females at ≥5.0 ppm. In males, significant increases were seen in the incidence of renal adenoma or carcinoma (combined) at 29.1 ppm (7/50) and 85.8 ppm (12/48) and renal carcinoma at 85.8 ppm (11/48) compared to control (a significant positive trend for these tumors was noted). No renal tumors occurred in control males or female mice of any group. Incidence of liver tumors was not increased in any exposure group, although significant positive trends were found for hepatocellular adenoma or carcinoma (combined) and carcinoma in both males and females. No nonneoplastic or neoplastic lesions were increased in other organs.

Selection of the Point of Departure for the MRL: The LOAEL of 5.0 ppm for nasal lesions in mice was selected as it provided the lowest POD for the critical effect. The principal study only provided incidence data for neoplastic lesions; however, incidence data were available in unpublished Japanese-language reports with English tables (MHLW 1994b). Data for nasal lesions could not be BMD modeled because incidence went from 0% in controls to 100% at the lowest concentration.

Adjustment for Intermittent Exposure and Human Equivalent Concentration: Sarangapani et al. (2002) is the only published chloroform model that simulates doses to the nasal cavity tissues. The model has been validated against observations made in rats, but not other laboratory animal models or humans. ATSDR typically requires that models used for dosimetry extrapolation in derivation of MRLs be validated in the species to which they are applied. As the principal study uses mice, the Sarangapani et al. (2002) model was not used for dosimetry extrapolation in deriving the chronic-duration inhalation MRL. Therefore, the LOAEL was converted to a LOAEL_HEC_ using guidance from EPA (1994) on dosimetric adjustments for respiratory effects using the RGDR_ET_, as shown in the equations after Table A-11. The LOAEL of 5.0 ppm was adjusted for continuous exposure and converted into a LOAEL_HEC_ of 0.11 ppm.

Uncertainty Factors: The following uncertainty factors were then applied to the LOAEL_HEC_ to derive the MRL.

- 10 for use of a LOAEL
- 3 for extrapolation from animals to humans with dosimetric adjustments
- 10 for human variability

Subsequently, the inhalation MRL for chronic-duration exposure to chloroform is:

M R L = (L O A E L_H E C_)/(U F s) = (0.11 p p m)/(300) = 0.00037 p p m ≈ 0.0004 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that respiratory effects are a presumed health effect following exposure to chloroform based on inadequate evidence from human epidemiology studies and a high level of evidence from animal studies (Appendix C).

Lung damage has been reported in several fatal cases of inhalation exposure (Ago et al. 2011; Featherstone 1947; Giusti and Chiarotti 1981; Harada et al. 1997; Piersol et al. 1933; Royston 1924; Schroeder 1965). Case reports have also documented changes in respiratory rate and/or respiratory arrest at high exposure levels (Jayaweera et al. 2017; Storms 1973; Whitaker and Jones 1965), but these effects are likely secondary to CNS depression. In animals, the nasal epithelium is a consistent target of toxicity in rodents following acute-, intermediate-, and chronic-duration inhalation exposure (Constan et al. 1999; Kasai et al. 2002; Larson et al. 1994c, 1996; Mery et al. 1994; Templin et al. 1996b; Yamamoto et al. 2002) and acute- and intermediate-duration gavage exposure (Dorman et al. 1997; Larson et al. 1995b; Templin et al. 1996a). Findings show a dose- and duration-dependent increase in the incidence and severity of lesions.

Agency Contact (Chemical Manager): Rae T. Benedict, Ph.D.

## Chloroform Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroform
CAS Numbers: | 67-66-3
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.3 mg/kg/day
Critical Effect: | Hepatotoxicity (hepatic lesions)
Reference: | Larson et al. 1994b
Point of Departure: | NOAEL of 26 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 33
Species: | Mouse

MRL Summary: An acute-duration oral MRL of 0.3 mg/kg/day was derived for chloroform based on hepatic effects (centrilobular hepatocyte eosinophilic cytoplasm) in B6C3F1 mice following exposure to chloroform in drinking water for 4 days (Larson et al. 1994b). The MRL is based on a NOAEL of 26 mg/kg/day, which was divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: No adequate acute-duration human data were available. Experimental acute-duration oral data in animals clearly show that rodents are more susceptible to chloroform toxicity via gavage exposure than drinking water exposure. The lowest acute-duration LOAELs identified in rats and mice via gavage exposure range from 10 to 34 mg/kg/day for respiratory, hepatic, renal, neurological, and developmental effects (Table A-13). In contrast, the lowest acute-duration LOAELs identified in rats and mice exposed via drinking water range from 53 to 81 mg/kg/day for hepatic effects and decreased body weights (Table A-14).

Table A-13 Selected NOAEL and LOAEL Values in Animals Following Acute-Duration Gavage Exposure to Chloroform

Species | Duration | Effect level (mg/kg/day) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Renal
Osborne-Mendel rat | Once | ND | 10 | Regenerative cell proliferation in the epithelial cells of the proximal tubules of the renal cortex | Templin et al. 1996a
Fischer 344 rat | 4 days | 10 | 34 | Mild-to-moderate degeneration of renal proximal tubules and tubule epithelial cell proliferation | Larson et al. 1993
Fischer 344 rat | Once | ND | 34 | Scattered necrosis of the renal proximal tubule | Larson et al. 1993
B6C3F1 mouse | 4 days | ND | 34 | Extensive acute necrosis of the proximal convoluted tubule, regenerative cell proliferation in the renal cortex and medulla | Larson et al. 1994d
Developmental
Dutch belted rabbit | 13 days; GDs 6–18 | ND | 20 | 8% decrease in fetal body weight, delayed ossification | Thompson et al. 1974
Neurological
CD-1 mouse | 10 days | 10 | 30 | Conditioned taste aversion to saccharin | Landauer et al. 1982
Hepatic
Fischer 344 rat | 4 days | 10 | 34 | Increased relative liver weight | Larson et al. 1993
Respiratory
Fischer 344 rat | 4 days | ND | 34 | Degeneration of the olfactory epithelium and superficial Bowman’s glands; periosteal hypercellularity | Larson et al. 1995b

GD = gestation day; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Table A-14 Selected NOAEL and LOAEL Values in Animals Following Acute-Duration Drinking Water Exposure to Chloroform

Species | Duration | Effect level (mg/kg/day) | | Effect | Reference
Species | Duration | NOAEL | LOAEL | Effect | Reference
Renal
Fischer 344 rat | Drinking water | 68.1 | ND | | Larson et al. 1995a
B6C3F1 mouse | Drinking water | 105 | ND | | Larson et al. 1994b
Hepatic
B6C3F1 mouse | Drinking water | 26 | 53 | Centrilobular hepatocyte eosinophilic cytoplasm | Larson et al. 1994b
Fischer 344 rat | Drinking water | 68.1 | ND | | Larson et al. 1995a
Body weight
Fischer 344 rat | Drinking water | 33.2 | 57.5 | 17% decrease in body weight gain | Larson et al. 1995a
B6C3F1 mouse | Drinking water | 53 | 81 | 20% body weight loss | Larson et al. 1994b

LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Increased toxicity in rodents following acute-duration gavage exposure, compared to drinking water, is likely due to saturation of detoxification pathways following bolus gavage exposure, which exacerbates toxicity due to accumulation of toxic metabolites in hepatic and renal tissues. Specifically, it is proposed that the reaction of chloroform metabolites with GSH acts as a detoxifying mechanism. This is supported by observations that chloroform doses that caused liver GSH depletion produced liver necrosis (Docks and Krishna 1976). Additionally, exposure to chloroform via drinking water over the course of the day, rather than in a single bolus dose, may result in adaptive mechanisms. In support, hepatotoxicity in female mice associated with a 3-day gavage exposure to 263 mg/kg/day was attenuated if mice were exposed to chloroform at doses up to 520 mg/kg/day in drinking water for 3 weeks prior to gavage exposure (Pereira and Grothaus 1997). No literature was identified indicating similar adaptive changes regarding detoxification capacity following gavage exposure. Considering these chloroform-specific data regarding differential toxicity and toxicokinetics via gavage versus drinking water exposure, basing an oral MRL on the most sensitive endpoint following gavage exposure (renal toxicity) may be overly conservative and not applicable to lower, environmentally relevant exposure levels. Based on this rationale, findings from drinking water studies are considered more relevant to environmental exposure levels and scenarios. The most sensitive effects following drinking water exposure are hepatic effects in mice at 53 mg/kg/day (Table A-14). Therefore, hepatic effects are selected as the critical effect for derivation of the acute-duration oral MRL.

Selection of the Principal Study: The 4-day study in mice by Larson et al. (1994b) is selected as the principal study because it provides the highest NOAEL below the lowest LOAEL for the critical effect (hepatotoxicity).

Summary of the Principal Study:

Larson JL, Wolf DC, Butterworth BE. 1994b. Induced cytotoxicity and cell proliferation in the hepatocarcinogenicity of chloroform in female B6C3F1 mice: comparison of administration by gavage in corn oil vs ad libitum in drinking water. Fund Appl Toxicol 22:90–102.

Groups of female B6C3F1 mice (14/group) were exposed to chloroform at drinking water concentrations of 0, 60, 200, 400, 900, or 1,800 ppm for 4 days. Mice were housed individually so accurate dose calculations could be made based on individual water consumption data. Body weights were recorded. After the 4-day exposure period, mice were sacrificed, and all animals were examined for macroscopic changes in the liver and kidney prior to being divided into three groups for analysis. Group 1 (five animals per group) was evaluated for serum clinical chemistry (ALT, SDH), liver and kidney weight, and liver and kidney histology. Group 2 (four animals per group) was evaluated for kidney histology. Group 3 (five animals per group) was evaluated for cellular proliferation (via BrdU labelling) in the liver and kidney.

Based on measured water intake and body weights, the study authors calculated average chloroform intakes of 0, 16.0, 26.4, 53.5, 80.9, and 105 mg/kg/day at 0, 60, 200, 400, 900, and 1,800 ppm, respectively. Dose-related decreases in body weights and water intake were observed, with an approximate 20% body weight loss during the exposure period at ≥900 ppm (data presented graphically). At necropsy, no exposure-related changes in serum ALT or SDH, gross pathology, or liver or kidney weights were observed. The study authors reported tinctorial changes, characterized by pale cytoplasmic eosinophilic staining of centrilobular hepatocytes, in 2/5, 8/10, and 4/5 mice, respectively; it is noted that the methods section indicates that only five per group were evaluated for liver histology. Liver histology at ≤200 ppm was reportedly not different from control (incidence data not reported). No exposure-related histopathological changes were noted in the kidney. Chloroform exposure via drinking water did not induce cell proliferation in either the liver or kidney.

Selection of the Point of Departure for the MRL: The NOAEL of 26 mg/kg/day for hepatic effects in the study by Larson et al. (1994b) was selected as the POD. While the study authors reported incidence data at ≥400 ppm (53.5 mg/kg/day), incidence data for ≤200 ppm (≤26 mg/kg/day) were not provided; therefore, BMD modeling was not used to derive this MRL.

Calculations: None. Available PBPK models were evaluated for potential suitability for oral dose extrapolation. Corley et al. (1990) and Reitz et al. (1990) are the only published reports of validation of models for predicting chloroform dosimetry from the oral exposure route. Both studies relied on data from studies of a single gavage dose (or in the case of humans, gelatin capsule dosing) of chloroform in oil-based vehicles. The models have not been validated for simulating dosimetry of repeated continuous exposures, such as daily ingestion of chloroform in drinking water. Application of either model to dosimetry extrapolation in the derivation of the acute MRL would be highly uncertain. The major uncertainty would be in extrapolating the internal doses from delivery of a large bolus dose to the liver from an oil gavage dose to the internal dose expected for repeated ingestion of chloroform in water. This extrapolation has not been validated. Therefore, the models were not used for dosimetry extrapolation in deriving the acute-duration MRL.

Uncertainty Factors: The following uncertainty factors were applied to the NOAEL to derive the MRL:

- Uncertainty factor of 10 for extrapolation from animals to humans
- Uncertainty factor of 10 for human variability

Subsequently, the oral MRL for acute-duration exposure to chloroform is:

Provisional M R L = (N O A E L_◻_)/(( U F )) = (26 m g / k g / day)/(100) = 0.26 m g / k g / day ≈ 0.3 m g / k g / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that hepatic effects are a known health effect following exposure to chloroform based on a low level of evidence from human epidemiology studies, high level of evidence from animal studies, and other relevant data consisting of the extensive database of case reports and case series documenting hepatic effects of chloroform in exposed humans (Appendix C).

Numerous case series and case reports indicate that the liver is a clear target of toxicity in humans following oral and inhalation exposure to high levels of chloroform (Section 2.9). In fatal ingestion cases, acute liver failure and/or severe liver damage have been found at autopsy (Dettling et al. 2016; Piersol et al. 1933). In nonfatal cases of oral ingestion, clinical signs of hepatotoxicity manifested within 1–7 days of exposure (Choi et al. 2006; Dell’Aglio et al. 2010; Hakim et al. 1992; Jayaweera et al. 2017; Kim 2008; Rao et al. 1993; Schroeder 1965; Sridhar et al. 2011; Storms 1973). Impaired liver function was observed in a man who ingested 21 mg/kg/day chloroform in a cough medicine for 10 years (Wallace 1950).

In animal studies, the liver is also a clear target of toxicity following acute-, intermediate-, and chronic-duration inhalation and oral studies in rodents; intermediate- and chronic-duration oral studies in dogs; and an acute-duration oral study in rabbits (Section 2.9). Findings in rodents following gavage exposure range from changes in clinical chemistry and mild histopathological damage after lower, shorter exposures (e.g., lipid accumulation, cellular swelling and vacuolation, scattered necrosis, hepatocellular proliferation), with widespread and severe necrosis and degeneration with higher and/or longer durations. As discussed above, the rodent liver is less susceptible to toxicity following drinking water exposure, presumably due to saturation of metabolic detoxification pathways with bolus gavage exposure.

Agency Contact (Chemical Manager): Rae T. Benedict, Ph.D.

## Chloroform Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroform
CAS Numbers: | 67-66-3
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.1 mg/kg/day
Critical Effect: | Hepatotoxicity (increased serum ALT)
Reference: | Heywood et al. 1979
Point of Departure: | NOAEL of 15 mg/kg/day (NOAEL_ADJ_ of 13 mg/kg/day)
Uncertainty Factor: | 100
LSE Graph Key: | 74
Species: | Dog

MRL Summary: An intermediate-duration oral MRL of 0.1 mg/kg/day was derived for chloroform based on hepatic effects (~2-fold increase in serum ALT) in Beagle dogs following exposure to chloroform for 26–52 weeks (6 days/week) via toothpaste capsule (Heywood et al. 1979). The MRL is based on a NOAEL of 15 mg/kg/day, which was adjusted to a continuous duration dose (NOAEL_ADJ_) of 13 mg/kg/day and divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: No adequate intermediate-duration oral studies in humans were identified. As discussed in the acute-duration oral MRL worksheet above, rodents are more susceptible to chloroform toxicity via gavage exposure than drinking water exposure following intermediate-duration oral exposure. This pattern is clearly shown in a series of 21-day studies in rats and mice by Larson et al. (1994b, 1995a; Table A-15).

Table A-15 Comparison of Toxicity in Rodents Following a 21-Day Exposure to Chloroform via Gavage versus Drinking Water Exposure

Species | Route | Effect level (mg/kg/day) | | Effect | Reference
Species | Route | NOAEL | LOAEL | Effect | Reference
Hepatic
Fischer 344 rat | Gavage in oil | 34 | 100 | Increased hepatocellular proliferation | Larson et al. 1995a
Fischer 344 rat | Drinking water | 106 | ND | | Larson et al. 1995a
B6C3F1 mouse | Gavage in oil | 10 | 34 | Mild vacuolation of hepatocytes, increased serum ALT and SDH | Larson et al. 1994b
B6C3F1 mouse | Drinking water | 43 | 82 | Increased relative liver weight | Larson et al. 1994b
Renal
Fischer 344 rat | Gavage in oil | 34 | 100 | Increased proliferation of proximal tubule epithelial cells in renal cortex | Larson et al. 1995a
Fischer 344 rat | Drinking water | 106 | ND | | Larson et al. 1995a

ALT = alanine aminotransferase; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; SDH = sorbitol dehydrogenase

Based on the rationale discussed in the acute-duration oral MRL worksheet above, gavage studies in rodents were not considered for intermediate-duration oral MRL derivation. The most sensitive effects in drinking water studies in rodents and oral exposure studies in other species are hepatic effects in dogs at ≥30 mg/kg/day and renal and gastrointestinal effects in Eker rats at ≥27 mg/kg/day (Table A-16). Findings in Eker rats is not considered an appropriate basis for the MRL since it is an animal model of hereditary renal cancer (McDorman et al. 2003a). Additionally, no additional drinking water studies in rats or mice report adverse renal or gastrointestinal effects (Table A-16). Therefore, hepatic effects are selected as the critical effect for derivation of the intermediate-duration oral MRL.

Table A-16 Selected NOAEL and LOAEL Values in Animals Following Intermediate-Duration Oral Exposure to Chloroform

Species | Duration (route) | Effect level (mg/kg/day) | | Effect | Reference
Species | Duration (route) | NOAEL | LOAEL | Effect | Reference
Hepatic effects
Beagle dog | 26–52 weeks (C); 6 days/week | 15 | 30 | ~2-fold increase in serum ALT | Heywood et al. 1979
B6C3F1 mouse | 3 weeks (W) | 43 | 82 | Increased relative liver weight | Larson et al. 1994b
Fischer 344 rat | 3 weeks (W) | 106 | ND | | Larson et al. 1995a
B6C3F1 mouse | 90 days (W) | 145 | 290 | Increased fat content of the liver; centrilobular fatty changes | EPA 1980
Osborne-Mendel rat | 90 days (W) | 160 | ND | | EPA 1980
Fischer 344 rat | 28 or 90 days (W) | 200 | ND | | Chu et al. 1982a,1982b
Renal effects
Eker^a^ rat | 10 months (W) | ND | 27 | Increased incidence of atypical tubules and hyperplasia | McDorman et al. 2003a
Fischer 344 rat | 3 weeks (W) | 106 | ND | | Larson et al. 1995a
Osborne-Mendel rat | 90 days (W) | 160 | ND | | EPA 1980
Fischer 344 rat | 28 or 90 days (W) | 200 | ND | | Chu et al. 1982a, 1982b
B6C3F1 mouse | 3 weeks (W) | 329 | ND | | Larson et al. 1994b
B6C3F1 mouse | 90 days (W) | 435 | ND | | EPA 1980
Gastrointestinal effects
Eker^a^ rat | 10 months (W) | ND | 27 | Increased incidence of aberrant crypt foci in the colon | McDorman et al. 2003a
Fischer 344 rat | 13 weeks (W) | 34 | ND | | DeAngelo et al. 2002
Fischer 344 rat | 26 weeks (W) | 35 | ND | | Geter et al. 2004b

a Animal model of hereditary renal cancer.

ALT = alanine aminotransaminase; (C) = capsule; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; (W) = drinking water

Selection of the Principal Study: The 26–52-week study in dogs by Heywood et al. (1979) is selected as the principal study because it provides the highest NOAEL below the lowest LOAEL for the critical effect (hepatotoxicity). In the study by Heywood et al. (1979), dose delivery was via toothpaste-containing gelatin capsule. This route of exposure is not expected to mimic the bolus dose conditions of gavage administration. The capsule will disintegrate over time, resulting in a slower release of contents compared to bolus administration; thus, this mode of administration was considered to be relevant to human exposure conditions.

Summary of the Principal Study:

Heywood R, Sortwell RJ, Noel PRB, . 1979. Safety evaluation of toothpaste containing chloroform. III. Long-term study in beagle dogs. J Environ Pathol Toxicol 2:835–851.422938

In order to assess safety of toothpaste containing chloroform, groups of male and female Beagle dogs (8/sex/group) were exposed to chloroform in toothpaste-containing capsules at doses of 15 or 30 mg/kg/day for 6 days/week for up to 7.5 years. Control groups included untreated controls (8/sex), vehicle (capsule) controls (16/sex), and an alternative non-chloroform toothpaste control (8/sex). During the intermediate-phase of the study (<1 year), blood was collected to measure hematology and clinical chemistry parameters at 6 and 13 weeks of exposure and at intervals of 8–32 weeks thereafter. Body weight, food intake, water intake, and clinical signs were monitored throughout the exposure period.

No dogs died during the first year of the study. No clinical signs of toxicity or body weight effects were observed. Serum ALT was significantly increased in males and females exposed to 30 mg/kg/day beginning at 6 weeks and at every interval thereafter. The observed increase was approximately 2-fold starting on week 26. ALT activity was not increased in dogs exposed to 15 mg/kg/day group until week 130. Therefore, 15 mg/kg/day is considered a NOAEL for intermediate-duration exposure. No additional changes in serum clinical chemistry or hematology were noted.

Selection of the Point of Departure for the MRL: The NOAEL of 15 mg/kg/day for hepatic effects in the study by Heywood et al. (1979) was selected as the POD. While study authors reported mean ALT activity values and results of the statistical analysis, a measure of variance was not provided; therefore, BMD modeling could not be used to derive this MRL.

Calculations: The NOAEL of 15 mg/kg/day was adjusted for a daily exposure scenario:

N O A E L_A D J_ = N O A E L × (days exposed)/(7 days) = 15 m g / k g / day × (6 days)/(7 days) = 13 m g / k g / day

Available PBPK models were evaluated for potential suitability for oral dose extrapolation. Corley et al. (1990) and Reitz et al. (1990) are the only published reports of validation of models for predicting chloroform dosimetry from the oral exposure route. Neither of these studies evaluated dogs and are therefore not suitable for dose extrapolation.

Uncertainty Factors: The following uncertainty factors were applied to the NOAEL_ADJ_ to derive the MRL:

- Uncertainty factor of 10 for extrapolation from animals to humans
- Uncertainty factor of 10 for human variability

Subsequently, the oral MRL for intermediate-duration exposure to chloroform is:

M R L = (N O A E L_A D J_)/(( U F )) = (13 m g / k g / day)/(100) = 0.13 m g / k g / day ≈ 0.1 m g / k g / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that hepatic effects are a known health effect following exposure to chloroform based on a low level of evidence from human epidemiology studies, high level of evidence from animal studies, and other relevant data consisting of the extensive database of case reports and case series documenting hepatic effects of chloroform in exposed humans (Appendix C).

Numerous case series and case reports indicate that the liver is a clear target of toxicity in humans following oral and inhalation exposure to high levels of chloroform (Section 2.9). In fatal ingestion cases, acute liver failure and/or severe liver damage have been found at autopsy (Piersol et al. 1933; Dettling et al. 2016). In nonfatal cases of oral ingestion, clinical signs of hepatotoxicity manifest within 1–7 days of exposure (Choi et al. 2006; Dell’Aglio et al. 2010; Hakim et al. 1992; Jayaweera et al. 2017; Kim 2008; Rao et al. 1993; Schroeder 1965; Sridhar et al. 2011; Storms 1973). Impaired liver function was observed in a man who ingested 21 mg/kg/day chloroform in a cough medicine for 10 years (Wallace 1950).

In animal studies, the liver is also a clear target of toxicity following acute-, intermediate-, and chronic-duration inhalation and oral studies in rodents; intermediate- and chronic-duration oral studies in dogs; and an acute-duration oral study in rabbits (Section 2.9). Findings in rodents following oral gavage exposure range from changes in clinical chemistry and mild histopathological damage after lower, shorter exposures (e.g., lipid accumulation, cellular swelling and vacuolation, scattered necrosis, hepatocellular proliferation), with widespread and severe necrosis and degeneration with higher and/or longer exposure durations. As discussed above, the rodent liver is less susceptible to toxicity following drinking water exposure, presumably due to saturation of metabolic detoxification pathways with bolus gavage exposure.

Agency Contact (Chemical Manager): Rae T. Benedict, Ph.D.

## Chloroform Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroform
CAS Numbers: | 67-66-3
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.02 mg/kg/day
Critical Effect: | Hepatotoxicity (moderate-to-marked fatty cysts)
Reference: | Heywood et al. 1979
Point of Departure: | BMDL_10_ of 2.15 mg/kg/day (BMDL_ADJ_ of 1.84 mg/kg/day)
Uncertainty Factor: | 100
LSE Graph Key: | 84
Species: | Dog

MRL Summary: A chronic-duration oral MRL of 0.02 mg/kg/day was derived for chloroform based on hepatic effects (moderate-to-marked fatty cysts) in Beagle dogs following exposure to chloroform for up to 7.5 years (6 days/week) via toothpaste capsule (Heywood et al. 1979). The MRL is based on a BMDL_10_ of 2.15 mg/kg/day in male dogs, which was adjusted to a continuous duration dose (BMDL_ADJ_) of 1.84 mg/kg/day and divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: No adequate chronic-duration oral studies in humans were identified. The most sensitive chronic-duration oral LOAELs are shown in Table A-17. In contrast to findings in acute- and intermediate-duration studies, a clear increase in susceptibility was not observed in rodents exposed via gavage, compared to those exposed via drinking water (i.e., comparable lowest LOAEL values following chronic exposure). Several factors may contribute to this finding, including: (1) adaptive metabolic changes with chronic-duration exposure leading to blunting or attenuation of bolus effects; (2) lack of evaluation at low gavage doses in some studies (which may have potentially identified lower LOAELs); and/or (3) evaluation of different strains in chronic versus shorter-duration studies that may have differential susceptibility. However, dogs are more sensitive than rodents, regardless of oral exposure methodology. Therefore, the most sensitive endpoint in dogs (hepatotoxicity) is selected as the critical effect for derivation of the intermediate-duration oral MRL.

Table A-17 Selected NOAEL and LOAEL Values in Animals Following Chronic-Duration Oral Exposure to Chloroform

Species | Duration (route) | Effect level (mg/kg/day) | | Effect | Reference
Species | Duration (route) | NOAEL | LOAEL | Effect | Reference
Hepatic
Beagle dog | 7.5 years (C) | ND | 15 | Moderate-to-marked fatty cysts; ~2-fold increase in serum ALT | Heywood et al. 1979
ICI mouse | 80 weeks (GO) | 60 | ND | | Roe et al. 1979
Osborne-Mendel rat | 78 weeks (GO) | 100 | 200 | Necrosis of hepatic parenchyma | NCI 1976
B6C3F1 mouse | 78 weeks (GO) | ND | M: 138; F: 238 | Nodular hyperplasia | NCI 1976
Renal
Beagle dog | 7.5 years (C) | 15 | 30 | Fat deposition in glomeruli | Heywood et al. 1979
Fischer 344 rat | 104 weeks (W) | ND | 45 | Increased incidences of cytoplasmic basophilia and tubular lumen dilation in the proximal tubule | Nagano et al. 2006
ICI mouse | 80 weeks (GO) | F: 60 | M: 60 | Moderate-to-severe kidney disease | Roe et al. 1979
Osborne-Mendel rat | 104 weeks (W) | 38 | 81 | Renal tubule cell alterations | Hard et al. 2000; Jorgenson et al. 1985
Osborne-Mendel rat | 78 weeks (GO) | 200 | ND | | NCI 1976
B6C3F1 mouse | 78 weeks (GO) | M: 277; F: 477 | ND | | NCI 1976

ALT = alanine aminotransaminase; (C) = capsule; F = females; (GO) = gavage in oil; LOAEL = lowest-observed-adverse-effect level; M = males; ND = not determined; NOAEL = no-observed-adverse-effect level; (W) = drinking water

Selection of the Principal Study: The 7.5-year study in dogs by Heywood et al. (1979) is selected as the principal study because it provides the highest NOAEL below the lowest LOAEL for the critical effect (hepatotoxicity). In the study by Heywood et al. (1979), dose delivery was via toothpaste-containing gelatin capsule. This route of exposure is not expected to mimic the bolus dose conditions of gavage administration. The capsule will disintegrate over time, resulting in a slower release of contents compared to bolus administration; thus, this mode of administration was considered to be relevant to human exposure conditions.

Summary of the Principal Study:

Heywood R, Sortwell RJ, Noel PRB, . 1979. Safety evaluation of toothpaste containing chloroform. III. Long-term study in beagle dogs. J Environ Pathol Toxicol 2:835–851.422938

In order to assess safety of toothpaste containing chloroform, groups of male and female Beagle dogs (8/sex/group) were exposed to chloroform in toothpaste orally via gelatin capsules at doses of 15 or 30 mg/kg/day for 6 days/week for up to 7.5 years followed by a 20–24-week observation period. Control groups included untreated controls (8/sex), vehicle (capsule) controls (16/sex), and an alternative non-chloroform toothpaste control (8/sex). Survival, clinical signs, food intake, and water intake were monitored throughout the exposure period. Blood was collected to measure hematology and clinical chemistry parameters at 6 and 13 weeks of exposure and at intervals of 8–32 weeks thereafter.

Ophthalmoscopy was performed prior to exposure and at 3-month intervals thereafter. During the 6^th^ year of the study, bromosulfalein retention tests were conducted to assess liver function. At natural death or scheduled sacrifice, main organs (brain, pituitary, spinal cord, heart, lungs, liver, spleen, pancreas, thymus, prostate, uterus, kidneys, thyroids, adrenals, testes, ovaries) were removed and weighed, and a full microscopic examination was conducted on these tissues and all abnormalities. Electron microscopy was performed on liver and kidney sections from two untreated controls and three high-dose dogs (sex unspecified).

Several dogs died prior to scheduled sacrifice between week 87 and 328; however, mortalities were not exposure related. In male dogs, observed deaths included one from each of the following groups: untreated control, vehicle control, low-exposure, and high-exposure groups. In female dogs, three untreated controls and four vehicle controls died; all exposed animals survived until scheduled sacrifice. The study authors noted that about 20% of the dogs were hyperexcitable, mainly during the first 2–3 years. Some had convulsions, and 10 of the 11 reported fatalities occurred after such an attack. While study authors did not indicate which animal groups showed excitability, based on a lack of dose-related mortality it is assumed that neurological signs were not dose-related. No exposure-related changes were observed for body weight, food intake, or water intake. No exposure-related ophthalmological or hematological changes were noted. Serum ALT levels were significantly increased at 15 and 30 mg/kg/day starting on week 130 and 6, respectively. Elevations of ~2-fold were observed at week 260 and 26, respectively. Approximate 2-fold elevations in serum AST and serum ALP were also observed at the end of the exposure period (no statistical analysis provided). Serum enzyme levels recovered somewhat during the recovery period. The bromosulfalein retention test during the 6^th^ year did not reveal any liver impairment. No organ weight changes were found in the exposed groups. Exposure-related nonneoplastic histopathological changes were observed in the liver and kidney. Fatty cysts were observed in the liver in all groups; however, incidence and severity increased in a dose-related manner, with moderate-to-marked fatty cysts significantly elevated in treated groups, compared to control. In males, moderate-to-marked fatty cysts were observed in 1/15, 6/7, and 6/7 dogs at 0 (vehicle control), 15, and 30 mg/kg/day, respectively. In females, moderate-to-marked fatty cysts were observed in 0/12, 3/8, and 7/8 dogs at 0 (vehicle control), 15, and 30 mg/kg/day, respectively. No moderate-to-marked fatty cysts were observed in untreated or non-chloroform toothpaste controls. Fat deposition in renal glomeruli was reportedly higher in the 30 mg/kg/day chloroform group (incidence data were not provided). No remarkable nonneoplastic histopathological differences were observed in other evaluated tissues. No exposure-related tumors were observed.

Selection of the Point of Departure for the MRL: In order to identify the most sensitive POD, BMD modeling was attempted for the incidence data for fatty cysts in male and female dogs (Heywood et al. 1979). BMD modeling was not conducted for serum ALT data because the study authors did not report a measure of variance for the means. The incidence data were fit to all available dichotomous models in EPA’s BMDS (version 3.3) using a BMR of 10% extra risk. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, a 95% lower confidence limit on the BMD (BMDL) that is not 10 times lower than the lowest non-zero dose, and a scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMDL was selected as the POD when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest AIC was chosen.

The datasets used for BMD modeling are presented in Table A-18. Details of the modeling results for the model predictions for hepatic lesions in male and female dogs are in Tables A-19 and A-20, respectively. In accordance with the selection criteria mentioned above, the Logistic model, a frequentist, unrestricted model, was selected for males and the Probit model, a frequentist, unrestricted model, was selected for females.

Table A-18 Moderate-to-Marked Hepatic Fatty Cysts in Dogs Following Oral Exposure to Chloroform for up to 7.5 years

| Dose (mg/kg/day)
| 0 (vehicle) | 15 | 30
Males | 1/15 | 6/7^a^ | 6/7^a^
Incidence (percent incidence) | (7%) | (86%) | (86%)
Females | 0/12 | 3/8^a^ | 7/8^a^
Incidence (percent incidence) | (0%) | (38%) | (88%)

a p<0.05 (2-tailed Fisher’s Exact Probability Test, conducted for this review).

Source: Heywood et al. 1979

Table A-19 Model Predictions for Increased Incidence of Moderate-to-Marked Hepatic Fatty Cysts in Male Dogs Following Oral Exposure to Chloroform for up to 7.5 Years (Heywood et al. 1979)

| | | | | Scaled residuals^c^
Model | BMD_10_^a^ (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Dichotomous Hill | | | NA | 26.83 | −5.25×10^−9^ | 1.25×10^−8^
Gamma^d^ | | | 0.69 | 23.81 | −0.04 | 0.35
Log-Logistic^e^ | | | 0.87 | 23.03 | −0.002 | 0.12
Multistage Degree 2^f^ | | | 0.69 | 23.81 | −0.04 | 0.35
Multistage Degree 1^f^ | | | 0.69 | 23.81 | −0.04 | 0.35
Weibull^d^ | | | 0.69 | 23.81 | −0.04 | 0.35
Logistic ^g^ | 3.83 | 2.15 | 0.35 | 26.09 | −0.56 | 0.69
Log-Probit | | | NA | NA | NA | NA
Probit | 3.83 | 2.36 | 0.27 | 26.50 | −0.58 | 0.89
Quantal Linear | | | 0.69 | 23.81 | −0.04 | 0.35

a BMD and BMDLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Selected model. Only Logistic and Probit modes provided an adequate fit to the data. BMDLs were sufficiently close (differed by <3-fold). Therefore, the model with the lowest AIC was selected (Logistic).

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL_10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk; NA = computation failed

Table A-20 Model Predictions for Increased Incidence of Moderate-to-Marked Hepatic Fatty Cysts in Female Dogs Following Oral Exposure to Chloroform for up to 7.5 Years (Heywood et al. 1979)

| | | | | Scaled residuals^c^
Model | BMD_10_^a^ (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Dichotomous Hill | | | NA | 22.61 | −4.28×10^−4^ | 3.05×10^−9^
Gamma^d^ | | | 1.00 | 20.61 | −4.28×10^−4^ | 5.54×10^−10^
Log-Logistic^e^ | | | 1.00 | 20.61 | −4.28×10^−4^ | 3.49×10^−9^
Multistage Degree 2^f^ | | | 1.00 | 18.63 | −4.28×10^−4^ | −0.08
Multistage Degree 1^f^ | | | 0.80 | 19.87 | −4.28×10^−4^ | −0.56
Weibull^d^ | | | 1.00 | 20.61 | −4.28×10^−4^ | −4.68×10^−9^
Logistic | 9.04 | 4.86 | 0.55 | 21.35 | −0.50 | 0.32
Log-Probit | | | 1.00 | 20.61 | −4.28×10^−4^ | 3.20×10^−10^
Probit ^g^ | 8.70 | 4.63 | 0.62 | 21.09 | −0.39 | 0.30
Quantal Linear | | | 0.80 | 19.87 | −4.28×10^−4^ | −0.56

a BMD and BMDLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Selected model. Only Logistic and Probit modes provided an adequate fit to the data. BMDLs were sufficiently close (differed by <3-fold). Therefore, the model with the lowest AIC was selected (Probit).

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL_10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk; NA = computation failed

The candidate PODs for hepatic effects in dogs are summarized in Table A-21. Confidence is higher in the PODs based on BMD modeling; from these, the lowest POD identified was 2.15 mg/kg/day. Therefore, the BMDL_10_ of 2.15 mg/kg/day for increased incidence of moderate-to-marked fatty cysts in the liver of male dogs was selected as the POD for the chronic-duration oral MRL. Model fit for the hepatic lesions in male dogs is shown in Figure A-1 (Logistic model).

Table A-21 Summary of Candidate POD Values Considered for Derivation of a Chronic-Duration Oral MRL for Chloroform

Species (sex) | Duration | Effect | Candidate POD (mg/kg/day) | POD type | Reference
Dog (male and female) | 7.5 years (6 days/week) | >2-fold increase in serum ALT | 15 | LOAEL | Heywood et al. 1979
Dog (male) | 7.5 years (6 days/week) | Increased incidence of moderate-to-marked hepatic fatty cysts | 2.15 | BMDL | Heywood et al. 1979
Dog (female) | 7.5 years (6 days/week) | Increased incidence of moderate-to-marked hepatic fatty cysts | 4.63 | BMDL | Heywood et al. 1979

ALT = alanine aminotransferase; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD; LOAEL = lowest observed adverse effect level; MRL = Minimal Risk Level; POD = point of departure

Figure A-1 Fit of Logistic Model to Incidence Data for Moderate-to-Marked Hepatic Fatty Cysts in Male Dogs Following Oral Exposure to Chloroform for up to 7.5 Years (Heywood et al. 1979)

Calculations: The BMDL_10_ of 2.15 mg/kg/day was adjusted for a daily exposure scenario:

B M D L_A D J_ = B M D L_10_ × (days exposed)/(7 days) = 2.15 m g / k g / day × (6 days)/(7 days) = 1.84 m g / k g / day

Available PBPK models were evaluated for potential suitability for oral dose extrapolation. Corley et al. (1990) and Reitz et al. (1990) are the only published reports of validation of models for predicting chloroform dosimetry from the oral exposure route. Neither of these studies evaluated dogs and are therefore not suitable for dose extrapolation.

Uncertainty Factors: The following uncertainty factors were applied to the BMDL_ADJ_ to derive the MRL:

- Uncertainty factor of 10 for extrapolation from animals to humans
- Uncertainty factor of 10 for human variability

Subsequently, the oral MRL for chronic-duration exposure to chloroform is:

M R L = (B M D L_A D J_)/(( U F )) = (1.84 m g / k g / day)/(100) = 0.0184 m g / k g / day ≈ 0.02 m g / k g / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Systematic review concluded that hepatic effects are a known health effect following exposure to chloroform based on a low level of evidence from human epidemiology studies, high level of evidence from animal studies, and other relevant data consisting of the extensive database of case reports and case series documenting hepatic effects of chloroform in exposed humans (Appendix C).

Numerous case series and case reports indicate that the liver is a clear target of toxicity in humans following oral and inhalation exposure to high levels of chloroform (Section 2.9). In fatal ingestions cases, acute liver failure and/or severe liver damage have been found at autopsy (Dettling et al. 2016; Piersol et al. 1933). In nonfatal cases of oral ingestion, clinical signs of hepatotoxicity manifest within 1–7 days of exposure (Choi et al. 2006; Dell’Aglio et al. 2010; Hakim et al. 1992; Jayaweera et al. 2017; Kim 2008; Rao et al. 1993; Schroeder 1965; Sridhar et al. 2011; Storms 1973). Impaired liver function was observed in a man who ingested 21 mg/kg/day chloroform in a cough medicine for 10 years (Wallace 1950).

In animal studies, the liver is also a clear target of toxicity following acute-, intermediate-, and chronic-duration inhalation and oral studies in rodents; intermediate- and chronic-duration oral studies in dogs; and an acute-duration oral study in rabbits (Section 2.9). Findings in rodents following gavage exposure range from changes in clinical chemistry and mild histopathological damage after lower, shorter exposures (e.g., lipid accumulation, cellular swelling and vacuolation, scattered necrosis, hepatocellular proliferation), with widespread and severe necrosis and degeneration with higher and/or longer durations. As discussed above, the rodent liver is less susceptible to toxicity following drinking water exposure, presumably due to saturation of metabolic detoxification pathways with bolus gavage exposure.

Agency Contact (Chemical Manager): Rae T. Benedict, Ph.D.