# CHAPTER 8 REFERENCES

Ahlert RC, Enzminger JD. 1992. Anaerobic processes for the dechlorination of 1,1,1-trichloroethane. J Environ Sci Health A 27(7):1675–1699. 10.1080/10934529209375820.
Alabdulhadi A, Ramadan A, Devey P, 2019. Inhalation exposure to volatile organic compounds in the printing industry. J Air Waste Manag Assoc 69(10):1142–1169. 10.1080/10962247.2019.1629355.31184550
Al-Ajmi AM, Morad MA, Cooper PE, 2018. Reversible ethyl chloride neurotoxicity: A case report. Can J Neurol Sci 45(1):119–120. 10.1017/cjn.2017.262.29157319
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3(6):272–290. 10.1002/jat.2550030603.6376602
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 86(1):69–201. 10.1021/cr00071a004.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Federal Register 54(174):37618–37634. https://www.govinfo.gov/content/pkg/FR-1989-09-08/pdf/FR-1989-09-08.pdf. September 19, 2024.
ATSDR. 1991. Health assessment for Beacon Heights Landfill Site, Beacon Falls, Connecticut, Region 1. Cerclis No. CTD072122062. Addendum. Agency for Toxic Substances and Disease Registry. PB91205666. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB91205666.xhtml. April 12, 2023.
ATSDR. 2005a. Health consultation: State of Arizona, Silver Creek Subdivision, Tucson, Pima County, Arizona. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/hac/pha/stateofarizona-silvercreeksudv/silvercreekhcfinal060305.pdf. September 10, 2024.
ATSDR. 2005b. Health consultation: The former Miro Golf Course: Additional environmental contamination data Village of Douglas, Allegan County, Michigan. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.michigan.gov/-/media/Project/Websites/mdhhs/Folder1/Folder33/Miro_RI_HC.pdf?rev=7cc370f0ac534729adebe316b6c5e6aa. September 10, 2024.
ATSDR. 2005c. Health consultation: Evaluation of potential soil gas migration in residences adjacent to the Pemaco Superfund Sitemaywood, Los Angeles County, California. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/PemacoSuperfundSite042905/PemacoHC042505.pdf. September 10, 2024.
ATSDR. 2005d. Health consultation: Wright Groundwater Contamination Site, Wright, Kansas. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/WrightGroundwaterContamination/WrightGroundwaterFinalHC082605.pdf. September 10, 2024.
ATSDR. 2007. Health consultation: 8 – 10 Railroad Avenue, Derry, Rockingham County, New Hampshire. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/8-10RailroadAvenue/8-10RailroadAveHC061807.pdf. September 10, 2024.
ATSDR. 2008a. Health consultation: South Dayton Dump & Landfill, Moraine, Montgomery County, Ohio. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/SouthDaytonDumpLandfill/South_Dayton_Dump_&%20Landfill%20PHA%209-30-2008.pdf. September 10, 2024.
ATSDR. 2008b. Health consultation: Evaluation of environmental concerns and cancer incidence, 2000–2003, related to the Woburn Landfill in Woburn, Middlesex County, Massachusetts, Woburn Sanitary Landfill. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.mass.gov/doc/evaluation-of-environmental-concerns-and-cancer-incidence-2000-2003-related-to-the-woburn-0/download. September 10, 2024.
ATSDR. 2016. Evaluating vapor intrusion pathways guidance for ATSDR’s division of community health investigations. Agency for Toxic Substances and Disease Registry. https://stacks.cdc.gov/view/cdc/79266. March 28, 2024.
ATSDR. 2022a. Chloroethane. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/SPL/resources/index.html. June 8, 2023.
ATSDR. 2022b. Sanders2015 HLCs used in SHOWER Model v3 and PHAST. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Baek NH, Jaffe PR, Shingal N. 1990. Simulating the degradation of TCE under methanogenesis. J Environ Sci Health A 25(8):987–1005. 10.1080/10934529009375612.
Barletta B, Meinardi S, Simpson IJ, 2009. Characterization of volatile organic compounds (VOCs) in Asian and north American pollution plumes during INTEX-B: identification of specific Chinese air mass tracers. Atmos Chem Phys 9(14):5371–5388. 10.5194/acp-9-5371-2009.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Barrio-Lage G, Parsons FZ, Nassar RS, 1986. Sequential dehalogenation of chlorinated ethenes. Environ Sci Technol 20(1):96–99. 10.1021/es00143a013.22300158
Bircher AJ, Hampl K, Hirsbrunner P, 1994. Allergic contact dermatitis from ethyl chloride and sensitization to dichlorodifluoromethane (CFC 12). Contact Dermatitis 31(1):41–44. 10.1111/j.1600-0536.1994.tb01904.x.7924293
Breslin WJ, Berdasco NM, Phillips JE, 1988. Ethyl chloride effects on estrous cycling in B6C3F1 mice (final report) with cover letter dated 112188. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517350. 86–890000040. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0517350.xhtml. January 10, 2023.
Broussard LA, Broussard AK, Pittman TS, 2000. Death due to inhalation of ethyl chloride. J Forensic Sci 45(1):223–225. 10.1520/JFS14666J.10641945
Bucher JR, Morgan DL, Adkins B, 1995. Early changes in sex hormones are not evident in mice exposed to the uterine carcinogens chloroethane or bromoethane. Toxicol Appl Pharmacol 130(1):169–173. 10.1006/taap.1995.1022.7839365
Budavari S, O’Neil MJ, Smith A, 1989. Ethyl chloride. In: The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 11th ed. Rahway, NJ: Merck & Co., 597.
Budavari S, O’Neil MJ, Smith A, 1996. Ethyl chloride. In: The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 12th ed. Rahway, NJ: CRC Press, 645.
Bush OF, Bittenbender G, Adriani J. 1952. Electrocardiographic changes during ethyl chloride and vinyl ether anesthesia in the dog and man. Anesthesiology 13(2):197–202. 10.1097/00000542-195203000-00013.14915135
Bysshe SE. 1982. Bioconcentration factors in aquatic organisms. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book Co., 5–1 to 5–30.
CDC. 2017. Volatile organic compounds and trihalomethanes/MTBE - Blood (VOCWB_H). National health and nutrition examination survey: 2013–2014 Data documentation, codebook, and frequencies. https://wwwn.cdc.gov/Nchs/Nhanes/2013-2014/VOCWB_H.htm. August 1, 2023.
CDC. 2018. Volatile organic compounds and trihalomethanes/MTBE - Blood - Special sample (VOCWBS_I). National health and nutrition examination survey: 2015–2016 Data documentation, codebook, and frequencies. https://wwwn.cdc.gov/Nchs/Nhanes/2015-2016/VOCWB_I.htm. August 1, 2023.
CDC. 2020. Volatile organic compounds and trihalomethanes/MTBE - Blood (VOCWB_J). National health and nutrition examination survey: 2017–2018 Data documentation, codebook, and frequencies. https://wwwn.cdc.gov/Nchs/Nhanes/2017-2018/VOCWB_J.htm. August 1, 2023.
CDC. 2024. Blood chloroethane (2013 – 2018). National health and nutrition examination survey. https://www.cdc.gov/exposurereport/data_tables.html. August 1, 2023.
Chang HL, Alvarez-Cohen L. 1996. Biodegradation of individual and multiple chlorinated aliphatic hydrocarbons by methane-oxidizing cultures. Appl Environ Microbial 62(9):3371–3377. 10.1128/aem.62.9.3371-3377.1996.
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Cline PV, Viste DR. 1985. Migration and degradation patterns of volatile organic compounds. Waste Manag Res 3(4):351–360. 10.1016/0734-242X(85)90128-4.
CMR. 1982. Ethyl chloride production cuts tied to EPA lead phasedown; exports, future seen doubtful. Vol. 7. Chemical Marketing Reporter, 13–14.
Cole WH. 1956. Ethyl chloride as a gaseous anesthetic. Anesthesia 11:156–159. 10.1111/j.1365-2044.1956.tb07959.x.
Cole WH. 1967. A re-evaluation of the pharmacology of ethyl chloride. Med J Aust 1(17):853–855. 10.5694/j.1326-5377.1967.tb21831.x.6024693
Daubert TE, Danner RP. 1985. Chloroethane. In: Data compilation tables of properties of pure compounds. New York, NY: American Institute of Chemical Engineers.
Davidson BM. 1925. Studies of intoxication: V. The action of ethyl chloride. J Pharmacol Exp Ther 26:137–142.
Dawkins CJM. 1964. Safety of vinyl ether. Br Med J 2(5382):538. 10.1136/bmj.1.5382.563.
Demarest C, Torgovnick J, Sethi NK, 2011. Acute reversible neurotoxicity associated with inhalation of ethyl chloride: a case report. Clin Neurol Neurosurg 113(10):909–910. 10.1016/j.clineuro.2011.05.004.21676535
Dobkin AB, Byles PH. 1971. The pharmacodynamics of divinyl ether, ethylchloride, fluroxene, nitrous oxide and trichloroethylene. In: Soma LR, ed. Textbook of veterinary anesthesia. Baltimore, MD: Williams & Wilkins, 94–104.
DOE. 2024a. Protective action criteria (PAC) based on AEGLs, ERPGs, or TEELs. U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDocs. September 13, 2024.
DOE. 2024b. Definition of PACs (AEGLs, ERPGs or TEELs). U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDef. September 13, 2024.
Dow. 1941. Toxicity of ethyl chloride. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0517041. 86–870002251. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0517041.xhtml. January 10, 2023.
Dow. 1985. Initial submission: Ethyl chloride: Inhalation teratology probe study in CF-1 mice (final report) with cover letter dated 102591 (sanitized). Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0534634. 88–9200000184S. 8EHQ-1091–1538S. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0534634.xhtml. January 10, 2023.
Dow. 1992. Ethyl chloride: Disposition and metabolism in female Fischer 344 rats and B6C3F1 mice following inhalation exposure with cover letter dated 012893. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0543464. 86930000120. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0543464.xhtml. August 15, 2022.
Dow. 1995. Ethyl chloride: Palatability and 14-day drinking water toxicity study in Fischer 344 rats, with cover letter dated 12/22/1998. (sanitized). Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0573872. 86990000022S. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0573872.xhtml. January 12, 2023.
Duddleston KN, Arp DJ, Bottomley PJ. 2002. Biodegradation of monohalogenated alkanes by soil NH(3)-oxidizing bacteria. Appl Microbiol Biotechnol 59(4–5):535–539. 10.1007/s00253-002-1031-7.12172622
Ebert R, Fedtke N, Certa H, 1994. Genotoxicity studies with chloroethane. Mutat Res 322(1):33–44. 10.1016/0165-1218(94)90030-2.7517502
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
EMMI. 1997. Method 211.1: Organochlorine residues for fatty foods: Used by FDA. Environmental monitoring methods index. U.S. Environmental Protection Agency.
EPA. 1977. Industrial process profiles for environmental use: Chapter 6. The industrial organic chemical industry. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB281478. EPA600277023F. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB281478.xhtml. April 12, 2023.
EPA. 1979. Water-related environmental fate of 129 priority pollutants. Vol. II: Halogenated aliphatic hydrocarbons, halogenated ethers, monocyclic aromatics, phthalate esters, polycyclic aromatic hydrocarbons, nitrosamines, and miscellaneous compounds. Washington, DC: U.S. Environmental Protection Agency. PB80204381. EPA440479029b. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB80204381.xhtml. April 12, 2023.
EPA. 1981. Atmospheric measurements of selected hazardous organic chemicals. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB81200628. EPA600381032. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB81200628.xhtml# (https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB81200628.xhtml). April 12, 2023.
EPA. 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. PB87169090. EPA400481014. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB87169090.xhtml (https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB87169090.xhtml#). June 15, 2023.
EPA. 1985. Regulations of fuel and fuel additives, gasoline lead content. U.S. Environmental Protection Agency. Federal Register 50(45):9386–9399. https://www.govinfo.gov/content/pkg/FR-1985-03-07/pdf/FR-1985-03-07.pdf. September 19, 2024.
EPA. 1986a. Methods for the determination of organic compounds in finished drinking water and raw source water. Cincinnati, OH: U.S. Environmental Protection Agency. EPA601B860001. F0115–08. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=940034LY.txt. April 12, 2023.
EPA. 1986b. Superfund record of decisions (EPA Region 3): Tybouts Corner Landfill, New Castle County, Delaware, March 1986. Washington, DC: U.S. Environmental Protection Agency. EPARODR0386019. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91003AMA.txt. April 12, 2023.
EPA. 1986c. Superfund record of decision: Blosenski Landfill, PA. Washington, DC: U.S. Environmental Protection Agency. EPARODR0386029. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91002Z6I.txt. April 12, 2023.
EPA. 1998. Toxic chemical release reporting: Community right-to-know. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372. https://www.ecfr.gov/current/title-40/chapter-I/subchapter-J/part-372?toc=1. April 12, 2023.
EPA. 2001. Occurrence data from the unregulated contaminant monitoring rule. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2015-09/r1r2.zip. March 3, 2023.
EPA. 2007. Provisional peer-reviewed toxicity values for chloroethane (CASRN 75–00-3). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R07007F. https://cfpub.epa.gov/ncea/pprtv/documents/Chloroethane.pdf. March 14, 2023.
EPA. 2016. Vapor intrusion screening level calculator. U.S. Environmental Protection Agency. https://www.epa.gov/vaporintrusion. March 28, 2024.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2022a. 2020 Chemical data reporting results: Chloroethane. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data#2020. October 26, 2022.
EPA. 2022b. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2023a. 2017 NEI data: Chloroethane. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. October 24, 2022.
EPA. 2023b. Air Quality System (AQS) data. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. December 5, 2022.
EPA. 2023c. Chloroethane. Sampling methods for HAPS (Core HAPS and VOCs). U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/documents/codetables/methods_haps.html. August 1, 2023.
EPA. 2024. National primary drinking water regulations. U.S. Environmental Protection Agency. https://www.epa.gov/ground-water-and-drinking-water/national-primary-drinking-water-regulations. September 14, 2024.
FDA. 2023. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. March 14, 2023.
Fedtke N, Certa H, Ebert R, 1994a. Species differences in the biotransformation of ethyl chloride: I. Cytochrome P450-dependent metabolism. Arch Toxicol 68:158–166. 10.1007/s002040050049.8024462
Fedtke N, Certa H, Ebert R, 1994b. Species differences in the biotransformation of ethyl chloride: II. GSH-dependent metabolism. Arch Toxicol 68(4):217–223. 10.1007/s002040050060.8067893
Ferrario JB, Lawler GC, Deleon IR, 1985. Volatile organic pollutants in biota and sediments of Lake Pontchartrain. Bull Environ Contam Toxicol 34(2):246–255. 10.1007/BF01609730.3978262
Fidler AT, Baker EL, Letz RE. 1987. Estimation of long term exposure to mixed solvents from questionnaire data: a tool for epidemiological investigations. Br J Ind Med 44(2):133–141. 10.1136/oem.44.2.133.3814546
Finch CK, Lobo BL. 2005. Acute inhalant-induced neurotoxicity with delayed recovery. Ann Pharmacother 39(1):169–172. 10.1345/aph.1E159.15590879
Finer B. 1966. Divinyl ether and ethyl chloride for outpatients. Acta Anaesthesiol Scand Suppl 25:410–412.
Firdaus R, Sukmono B, Melati AC, 2018. Comparison between vapocoolant spray and eutectic mixture of local anesthetics cream in reducing pain during spinal injections. Anesthesiol Res Pract 2018:5050273. 10.1155/2018/5050273.30271434
Fiserova-Bergerova V, Pierce JT, Droz PO. 1990. Dermal absorption potential of industrial chemicals: Criteria for skin notation. Am J Ind Med 17(5):617–635. 10.1002/ajim.4700170507.2337085
Fisher EM, Koshland CP. 1990. Numerical simulation of the thermal destruction of some chlorinated C1 and C2 hydrocarbons. J Air Waste Manage Assoc 40(10):1384–1390. 10.1080/10473289.1990.10466790.2257126
Florentine BD, Frankel K, Raza A, 1997. Local anesthesia for fine-needle aspiration biopsy of palpable breast masses: the effectiveness of a jet injection system. Diagn Cytopathol 17(6):472–476. 10.1002/(sici)1097-0339(199712)17:6<472::aid-dc18>3.0.co;2-j.9407211
Fossum K, Love SL, April MD. 2016. Topical ethyl chloride to reduce pain associated with venous catheterization: a randomized crossover trial. Am J Emerg Med 34(5):845–850. 10.1016/j.ajem.2016.01.039.26971823
Gal-Oz A, Rogowski O, Swartzon M, 2010. Ethyl chloride as an antipruritic agent: a double-blind placebo-controlled prospective study. Dermatology 221(4):373–377. 10.1159/000321720.21099198
Gal-Oz A, Kivity S, Shacham Y, 2015. Prevention of pruritus with ethyl-chloride in skin prick test: a double-blind placebo-controlled prospective study. Allergy Asthma Clin Immunol 11(1):25. 10.1186/s13223-015-0091-z.26339253
Gargas ML, Burgess RJ, Voisard DE, 1989. Partition coefficients of low-molecular weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98(1):87–99. 10.1016/0041-008X(89)90137-3.2929023
Gargas ML, Clewell HJ, Andersen ME. 1990. Gas uptake inhalation techniques and the rates of metabolism of chloromethanes, chloroethanes, and chloroethylenes in the rat. Inhal Toxicol 2(3):295–319. 10.3109/08958379009145260.
Gargas ML, Sweeney LM, Himmelstein MW, 2008. Physiologically based pharmacokinetic modeling of chloroethane disposition in mice, rats, and women. Toxicol Sci 104(1):54–66. 10.1093/toxsci/kfn064.18385209
Gohlke R, Schmidt P. 1972. [Subacute action of low concentrations of chlorinated ethanes on rats with and without additional ethanol-treatment. II. Histological, histochemical and morphometrical studies]. Int Arch Arbeitsmed 30:298–312. (German)
Gossett JM. 1987. Measurement of Henry’s Law constants for C1 and C2 chlorinated hydrocarbons. Environ Sci Technol 21(2):202–208. 10.1021/ES00156A012.
Gould JP, Ramsey RE, Giabbai M, 1983. Formation of volatile haloorganic compounds in the chlorination of municipal landfill leachates. In: Jolley RA, ed. Water chlorination environment impact and health effects. Vol. 4. Michigan: Ann Arbor Science, 525–539.
Graedel TE, Hawkins DT, Claxton LD. 1986. Chlorinated hydrocarbons. In: Atmospheric chemical compounds sources, occurrence and bioassay. New York, NY: Academic Press, 461.
Grimsrud EP, Rasmussen RA. 1975. Survey and analysis of halocarbons in the atmosphere by gas chromatography-mass spectrometry. Atmos Environ 9(11):1014–1017. 10.1016/0004-6981(75)90022-0.
Hager L, Kamp F, Proebstl L, 2021. Inhalant abuse of ethyl chloride spray: A case report. Fortschr Neurol Psychiatr 89(07/08):382–384. 10.1055/a-1483-9865.34237782
Haid B, White JM, Morris LE. 1954. Observations of cardiac rhythm during ethyl chloride anesthesia in the dog. Curr Res Anesth Analg 33(5):315–325.
Haider K. 1980. Degradation of chlorinated aliphatic and aromatic compounds by aerobic and anaerobic soil microorganisms. In: Second environmental research programme 1976–80: Reports on research sponsored under the first phase: 1976–80. Luxembourg: Commission of the European Communities, 200–204.
Hes JP, Cohn DF, Streifler M. 1979. Ethyl chloride sniffing and cerebellar dysfunction (case report). Isr Ann Psychiatr Relat Discip 17(2):122–125.291586
Holliger C, Schraa G, Stupperich E, 1992. Evidence for the involvement of corrinoids and factor F430 in the reductive dechlorination of 1,2-dichloroethane by Methanosarcina barkeri. J Bacterial 174(13):4427–4434. 10.1128/jb.174.13.4427-4434.1992.
Hommes NG, Russell SA, Bottomley PJ, 1998. Effects of soil on ammonia, ethylene, chloroethane, and 1,1,1-trichloroethane oxidation by Nitrosomonas europaea. Appl Environ Microbiol 64(4):1372–1378. 10.1128/aem.64.4.1372-1378.1998.16349541
Hong IZ, Ponampalam R. 2022. Death related to ethyl chloride inhalation abuse: a case report. World J Emerg Med 13(5):422–424. 10.5847/wjem.j.1920-8642.2022.083.36119769
Horvath AL. 1982. Chloroethane. In: Halogenated hydrocarbons solubility-miscibility with water. New York, NY: Marcel Dekker, Inc., 494–495.
Howard CJ, Evenson KM. 1976. Rate constants for the reactions of OH with ethane and some halogen substituted ethanes at 296K. J Chem Phys 64(11):4303–4306. 10.1063/1.432115.
Hubrich C, Stuhl F. 1980. The ultraviolet absorption of some halogenated methanes and ethanes of atmospheric interest. J Photochem 12(2):93–107. 10.1016/0047-2670(80)85031-3.
IARC. 1991. Volume 52: Chlorinated drinking-water; chlorination by-products; some other halogenated compounds; cobalt and cobalt compounds. IARC Monographs on the evaluation of carcinogenic risks to humans. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.who.int/wp-content/uploads/2018/06/mono52.pdf. April 12, 2023.
IARC. 1999. Volume 71: Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. IARC Monographs on the evaluation of carcinogenic risks to humans. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.who.int/wp-content/uploads/2018/06/mono71.pdf. April 12, 2023.
Im YG, Park HJ, Chae HY, 2012. Comparison of changes in facial skin temperature caused by ethyl chloride spraying, ice block rubbing and cold gel packing in healthy subjects. J Oral Rehabil 39(12):931–940. 10.1111/joor.12007.22994138
IRIS. 1991. Chemical assessment summary: Ethyl chloride; CASRN 75–00-3. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0523_summary.pdf. March 14, 2023.
Irkoren S, Ozkan HS, Karaca H. 2015. A clinical comparison of EMLA cream and ethyl chloride spray application for pain relief of forehead botulinum toxin injection. Ann Plast Surg 75(3):272–274. 10.1097/sap.0000000000000121.25536197
Jaffe HH, Orchin M. 1962. Chloroethane. In: Theory and application of ultraviolet spectroscopy. New York, NY: John Wiley and Sons, Inc., 173–174.
Jeffers PM, Wolfe NL. 1996. Homogeneous hydrolysis rate constants-Part II: Additions, corrections, and halogen effects. Environ Toxicol Chem 15(7):1066–1070. 10.1002/etc.5620150708.
Juliá-Romero C, Valls-Gil N, Amaya-Paladino L. 2021. Acute poisoning due to inhaled ethyl chloride. Med Clin 157(11):550–551. 10.1016/j.medcli.2020.12.027.
Kenig EE. 1956. [Changes in the peripheral nervous system through the effects of ethyl chloride] (abstract). Biol Abstr 35:18811.
Kobayashi H, Rittmann BE. 1982. Microbial removal of hazardous organic compounds. Environ Sci Technol 16(3):170a-183a. 10.1021/es00097a002.
Konietzko H. 1984. Chlorinated ethanes: Sources, distribution, environmental impact and health effects. In: Hazard Assessment of Chemicals: Current Developments. Vol. 3. Academic Press, Inc., 401–448.
Kriechbaumer N, Hemmer W, Focke M, 1998. Sensitization to ethyl chloride in a handball player. Contact Dermatitis 38(4):227–228. 10.1111/j.1600-0536.1998.tb05724.x.9565308
Kuschinsky G. 1970. [Death caused by general anesthesia with ethyl chloride]. Dtsch Med Wochenschr 95(49):2499. (German)
Kuthiah N, Er C. 2019. "High" on muscle spray - ethyl chloride abuse. Ann Acad Med Singap 48(2):67–68.30926979
Lamartiniere CA. 1981. The hypothalamic-hypophyseal-gonadal regulation of hepatic glutathione Stransferases in the rat. Biochem J 198(1):211–217. 10.1042/bj1980211.7325995
Lamartiniere CA, Lucier GW. 1983. Endocrine regulation of xenobiotic conjugation enzymes. Basic Life Sci 24:295–312. 10.1007/978-1-4684-4400-1_16.6305330
Landry TD, Ayres JA, Johnson KA, 1982. Ethyl chloride: a two-week inhalation toxicity study and effects on liver non-protein sulfhydryl concentrations. Fundam Appl Toxicol 2(5):230–234. 10.1016/s0272-0590(82)80032-8.7185620
Landry TD, Johnson KA, Momany-Pfruender JJ, 1987. Ethyl chloride: 11-day continuous exposure inhalation toxicity study in B6C3F1 mice. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8. OTS0517040. 86–870002250. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0517040.xhtml. April 12, 2023.
Landry TD, Johnson KA, Phillips JE, 1989. Ethyl chloride: 11-day continuous exposure inhalation toxicity study in B6C3F1 mice. Fundam Appl Toxicol 13(3):516–522. 10.1016/0272-0590(89)90288-1.2612784
Laughton PM, Robertson RE. 1959. Solvolysis in hydrogen and deuterium oxide. Can J Chem 37(9):1491–1497. 10.1139/v59-219.
Lawson JIM. 1965. Ethyl chloride. Brit J Anaesth 37(9):667–670. 10.1093/bja/37.9.667.5320088
Lazarew NW. 1929. [Concerning the strength of the narcotic effects of the vapors of the chlorine derivatives of the methanes, ethanes and ethylenes]. Arch Exp Pathol Pharmakol 141:19–24. (German)
Lehmann KB, Flury F. 1943. Chloroethane. In: Toxicology and hygiene of industrial solvents. Baltimore, MD: William and Wilkins Co., 154–157.
Lide DR. 2005. Chloroethane. In: CRC Handbook of chemistry and physics. Boca Raton, FL: CRC Press, 3–110 to 113–111.
Lyman WJ. 1982. Adsorption coefficient for soils and sediments. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book Co., 4–1 to 5–29.
Mabey W, Mill T. 1978. Critical review of hydrolysis of organic compounds in water under environmental conditions. J Phys Chem Ref Data 7(2):383–415. 10.1063/1.555572.
Marbach JJ. 1996. Temporomandibular pain and dysfunction syndrome. History, physical examination, and treatment. Rheum Dis Clin North Am 22(3):477–498. 10.1016/s0889-857x(05)70283-0.8844909
Marshall KA, Pottenger LH. 2016. Chlorocarbons and chlorohydrocarbons. In: Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley and Sons, Inc., online. 10.1002/0471238961.1921182218050504.a01.pub3.
Matsunaga H, Tsuji K, Saito T. 1976. Foamed plastics of resin compositions comprising pullulan type resins and thermoplastic resins and process for producing the same. United States Patent. US3976605A. https://patents.google.com/patent/US3976605. November 27, 2023.
McLean S, Robinson J, Starmer GA, 1967. The influence of anaesthetic agents on the formation of methaemoglobin induced by aniline in cats. J Pharm Pharmac 19(12):803–809. 10.1111/j.2042-7158.1967.tb09547.x.
Milman AH, Story DL, Riccio ES, 1988. Rat liver foci and in vitro assays to detect initiating and promoting effects of chlorinated ethanes and ethylenes. Ann NY Acad Sci 534:521–530. 10.1111/j.1749-6632.1988.tb30143.x.3389679
Moon YE, Kim SH. 2014. Effects of ethyl chloride spray on pain and parameters of needle electromyography in the upper extremity. Am J Phys Med Rehabil 93(10):869–875. 10.1097/phm.0000000000000106.24879550
Moon YE, Lee MY, Kim DH. 2017. Preventive effect of a vapocoolant spray on propofol-induced pain: a prospective, double-blind, randomized study. J Anesth 31(5):703–708. 10.1007/s00540-017-2386-3.28780595
Moon YE, Kim SH, Seok H, 2020. Comparison of the effects of vapocoolant spray and topical anesthetic cream on pain during intraarticular injection of the shoulder: A randomized double-blind controlled trial. Arch Phys Med Rehabil 101(10):1689–1695. 10.1016/j.apmr.2020.04.021.32445850
Morgan A, Black A, Belcher DR. 1970. The excretion in breath of some aliphatic halogenated hydrocarbons following administration by inhalation. Ann Occup Hyg 13(4):219–233. 10.1093/annhyg/13.4.219.5509094
Morris TE, Tasto WD. 1979. Ethyl chloride. In: Grayson M, Eckroth D, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. V. 3rd ed. New York, NY: John Wiley and Sons, Inc., 714–722.
Morris LE, Noltensmeyer MH, White JM. 1953. Epinephrine induced cardiac irregularities in the dog during anesthesia with trichloroethylene, cyclopropane, ethyl chloride and chloroform. Anesthesiology 14(2):153–158. 10.1097/00000542-195303000-00006.13031151
Morselli PL, France-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants. Clin Pharmacokin 5(6):485–527. 10.2165/00003088-198005060-00001.
Mumtaz MM, Ray M, Crowell SR, 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Myers V. 1983. Remedial activity at the Miami Drum Site, Florida. In: National conference management of uncontrolled hazardous waste sites, October 31-November 2, 1983. Silver Spring, MD: Hazardous Materials Control Research Institute, 354–357.
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
Naylor LM, Loehr RC. 1982. Priority pollutants in municipal sewage sludge. Biocycle 23(6):18–22.
Nibhanipudi KV. 2015. Effect of chloroethane spray in the treatment of spastic torticollis in children and adolescents. Glob Pediatr Health 2(Jun):2333794x15591567. 10.1177/2333794x15591567.
NIOSH. 1994. Ethyl chloride. Immediately dangerous to life or health concentrations (IDLH). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/75003.html. March 14, 2023.
NIOSH. 2018. Appendix C. Supplementary exposure limits. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/nengapdxc.html. March 14, 2023.
NIOSH. 2019. Ethyl chloride. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0267.html. March 14, 2023.
NLM. 2023. PubChem compound summary: Chloroethane (CASRN: 75–00-3). https://pubchem.ncbi.nlm.nih.gov/compound/6337. April 13, 2023.
Noble DA. 1979. Another hazard of pierced ears [letter]. Br Med J 1:125. 10.1136/bmj.1.6156.125-c.
Nordin C, Rosenqvist M, Hollstedt C. 1988. Sniffing of ethyl chloride - An uncommon form of abuse with serious mental and neurological symptoms. Int J Addict 23(6):623–627. 10.3109/10826088809039224.3170051
NTP. 1989. Toxicology and carcinogenesis studies of chloroethane (ethyl chloride) (CAS No. 75–00-3) in F344/N rats and B6C3F1 mice (inhalation studies). Research Triangle Park, NC: National Toxicology Program. PB90225053. NTP TR 346. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr346.pdf. April 12, 2023.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. March 14, 2023.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2021. CASRN index. In: Report on carcinogens. 15th ed. National Toxicology Program, https://ntp.niehs.nih.gov/whatwestudy/assessments/cancer/roc/index.html. January 10, 2022.
OSHA. 2023a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-2. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol6/pdf/CFR-2023-title29-vol6-sec1910-1000.pdf. September 13, 2024.
OSHA. 2023b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol7/pdf/CFR-2023-title29-vol7-sec1915-1000.pdf. September 13, 2024.
OSHA. 2023c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol8/pdf/CFR-2023-title29-vol8-sec1926-55.pdf. September 13, 2024.
Otson R. 1987. Purgeable organics in Great Lakes raw and treated water. Int J Environ Anal Chem 31(1):41–53. 10.1080/03067318708077128.
Oura E, Raiha NC, Suomalaimen H. 1966. Influence of some alcohols and narcotics on the adenosine phosphates in the liver of the mouse. Ann Med Exp Biol Fenn 45(1):57–62.
Parker JC, Casey GE, Bahlman LJ, 1979. NIOSH current intelligence bulletin No. 27. Chloroethanes: review of toxicity. Am Ind Hyg Assoc J 40(3):A46–60.495456
Pellizzari ED, Hartwell TD, Harris BSH, 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28(3):322–328. 10.1007/BF01608515.7082873
Picut CA, Aoyama H, Holder JW, 2003. Bromoethane, chloroethane and ethylene oxide induced uterine neoplasms in B6C3F1 mice from 2-year NTP inhalation bioassays: pathology and incidence data revisited. Exp Toxicol Pathol 55(1):1–9. 10.1078/0940-2993-00303.12940622
Pothiawala S, Yong CK, Charles R. 2021. Inhaling muscle spray: A rising trend of abuse. World J Crit Care Med 10(3):43–46. 10.5492/wjccm.v10.i3.43.34046309
Ramsook C, Kozinetz CA, Moro-Sutherland D. 2001. Efficacy of ethyl chloride as a local anesthetic for venipuncture and intravenous cannula insertion in a pediatric emergency department. Pediatr Emerg Care 17(5):341–343. 10.1097/00006565-200110000-00005.11673710
Rao PB, Mohanty CR, Singh N, 2019. Effectiveness of different techniques of ethyl chloride spray for venepuncture-induced pain: A randomised controlled trial. Anesth Essays Res 13(3):568–571. 10.4103/aer.AER_103_19.31602079
Rasche ME, Hicks RE, Ilyman MR, 1990. Oxidation of monohalogenated ethanes and n-chlorinated alkanes by whole cells of Nitrosomonas europaea. J Bacterial 172(9):5368–5373. 10.1128/jb.172.9.5368-5373.1990.
RePORTER. 2024. Chloroethane. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. September 18, 2024.
Richards RN. 2009. Ethyl chloride spray for sensory relief for botulinum toxin injections of the hands and feet. J Cutan Med Surg 13(5):253–256. 10.2310/7750.2009.08072.19769833
Rodriguez NA, Ascaso FJ. 2012. Ocular surface frostbite secondary to ethyl chloride spray. Cutan Ocul Toxicol 31(1):77–80. 10.3109/15569527.2011.607201.21888495
Rooney AA, Boyles AL, Wolfe MS, 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rui W, Long G, Li G, 2017. Effects of ethyl chloride spray on early recovery after total knee arthroplasty: A prospective study. J Orthop Sci 22(1):89–93. 10.1016/j.jos.2016.10.005.27986370
Ruiz P, Ray M, Fisher J, 2011. Development of a human Physiologically Based Pharmacokinetic (PBPK) Toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Rüsch D, Koch T, Seel F, 2017. Vapocoolant spray versus lidocaine infiltration for radial artery cannulation: A prospective, randomized, controlled clinical trial. J Cardiothorac Vasc Anesth 31(1):77–83. 10.1053/j.jvca.2016.06.008.27590462
Sabel GV, Clark TP. 1984. Volatile organic compounds as indicators of municipal solid waste leachate contamination. Waste Manag Res 2(2):119–130. 10.1016/0734-242X(84)90135-6.
Schlieve T, Miloro M. 2015. Topical refrigerant spray for pediatric venipuncture for outpatient surgery. Oral Maxillofac Surg Cases 1(2):29–32. 10.1016/j.omsc.2015.05.004.
Schmidt P, Binnewies S, Gohlike R, 1972. [Subacute action of low concentrations of chlorinatedethanes on rats with and without additional ethanol treatment. I. Subacute and chronic toxicity studies with 1,1,2,2-tetrachloroethane]. Int Arch Arbeitsmed 38:283–298. (German)
Schwark T, Schaul M, Schneider S, 2022. Two cases of fatal inhalation of easily available "recreational" substances. Am J Forensic Med Pathol 43(2):186–190. 10.1097/paf.0000000000000740.34939944
Scortichini BH, Johnson KA, Momany-Pfruenderd JJ, 1986. Ethyl chloride: Inhalation teratology study in CF-1 mice. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section FYI. OTS0001135. FYI-OTS-0794–1135. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0001135.xhtml. April 12, 2023.
Selby IR, Bowles BJM. 1995. Analgesia for venous cannulation: A comparison of EMLA (5 minute application), lignocaine, ethyl chloride, and nothing. J R Soc Med 88(5):264–267.7636819
Senussi MH, Chalise S. 2015. Acute reversible neurologic deficits due to ethyl chloride sniffing: a case report and review of literature. Am J Ther 22(2):e40–e42. 10.1097/MJT.0b013e3182a32dba.24247102
Shah A, Vidoni A, McGarry S, 2018. Ethyl chloride spray for musculoskeletal ultrasound-guided injections: An alternative to subcutaneous injection of local anesthetic solution. J Clin Ultrasound 46(2):129–131. 10.1002/jcu.22561.29205374
Shepson PB, Kleindiemst TE, Mcelhoe HB. 1987. A cryogenic trap/porous polymer sampling technique for the quantitative determination of ambient volatile organic compound concentrations. Atmos Environ 21(3):579–587. 10.1016/0004-6981(87)90040-0.
Singh HB, Salas LJ, Stiles RE. 1983. Selected man-made halogenated chemicals in the air and oceanic environment. J Geophys Res 88(C6):3675–3683. 10.1029/JC088iC06p03675.
Sipes IG, Gandolfi AJ. 1991. General principles of toxicology. In: Amdur MO, Doull J, Klaassen CD, eds. Casarett and Doull’s toxicology: The basic science of poisons. 4th ed. New York, NY: Pergamon Press, 108.
Soueid A, Richard B. 2007. Ethyl chloride as a cryoanalgesic in pediatrics for venipuncture. Pediatr Emerg Care 23(6):380–383. 10.1097/01.pec.0000278396.25129.3f.17572521
Swann RL, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio and water solubility. Res Rev 85:17–28. 10.1007/978-1-4612-5462-1_3.
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press: 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Swenberg JA, Fedtke N, Fishbein L. 1992. Age-related differences in DNA adduct formation and carcinogenesis of vinyl chloride in rats. In: Guzelian PS, Henry CJ, Olin SS, eds. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press, 163–171.
Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Tan YM, Chan M, Chukwudebe A, 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Tank JC, Georgiadis GM, Bair JM, 2021. Does the use of ethyl chloride improve patient-reported pain scores with negative pressure wound therapy dressing changes? A prospective, randomized controlled trial. J Trauma Acute Care Surg 90(6):1061–1066. 10.1097/ta.0000000000003157.33755640
Thomas R. 1982. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw Hill Book Co., Chapter 15.
Torkelson TR, Rowe VK. 1981. Ethyl chloride. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Vol. 2B. 3rd ed. New York, NY: John Wiley and Sons, Inc., 3480–3483.
TRI23. 2024. Chloroethane. TRI search. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/enviro/tri-search. November 9, 2024.
Tu AS, Murray TA, Hatch KM, 1985. In vitro transformation of BALB/c-3T3 cells by chlorinated ethanes and ethylenes. Cancer Lett 28(1):85–92. 10.1016/0304-3835(85)90096-5.4027960
USBM. 1929. Physiological response attending exposure to vapors of methyl bromide, methyl chloride, ethyl bromide and ethyl chloride. U.S. Bureau of Mines. US Public Health Bull 185:1–56.
USGS. 2006. Description, properties, and degradation of selected volatile organic compounds detected in ground water - a review of selected literature. Reston, VA: U.S. Geological Survey. Open-File Report 2006–1338. https://pubs.usgs.gov/of/2006/1338/. June 15, 2023.
van Eekert MHA, Stams AJM, Field JA, 1999. Gratuitous dechlorination of chloroethanes by methanogenic granular sludge. Appl Microbiol Biotechnol 51(1):46–52. 10.1007/s002530051361.
van Ketel WG. 1976. Allergic contact dermatitis from propellants in deodorant sprays in combination with allergy to ethyl chloride. Contact Dermatitis 2(2):115–119. 10.1111/j.1600-0536.1976.tb02996.x.1017178
van Liere EJ, Mazzocco TR, Northup DW. 1966. The effect of cyclopropane, trichloroethylene and ethyl chloride on the uterus of the dog. Am J Obstet Gynecol 994(6):861–867.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483. 10.1111/j.1432-1033.1996.0476z.x.8681961
Vogel TM, McCarty PL. 1987. Abiotic and biotic transformations of 1,1,1-trichloroethane under methanogenic conditions. Environ Sci Technol 21(12):1208–1213. 10.1021/es00165a008.
Vogt WG, Walsh JJ. 1985. Volatile organic compounds in gases from landfill simulators. Proc Air Pollut Control Assoc Annu Meet 78:2–17.
Waibel KH, Katial RK. 2005. Effect of topical vapocoolant spray on skin test wheal, flare, and pain responses. Ann Allergy Asthma Immunol 95(2):149–153. 10.1016/s1081-1206(10)61204-5.16136764
Walsh P, Columb M, Russell R. 2010. A comparison of a Neuropen monofilament and ethyl chloride for assessing loss of touch sensation during combined spinal-epidural anaesthesia for caesarean section. Int J Obstet Anesth 19(4):365–372. 10.1016/j.ijoa.2010.06.010.20832279
Washington JW. 1996. Gas partitioning of dissolved volatile organic compounds in the vadose zone: Principles, temperature effects and literature review. Ground Water 34(4):709–718. 10.1111/j.1745-6584.1996.tb02059.x.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Williams GM. 1983. DNA repair tests of 11 chlorinated hydrocarbon analogs final report EPA contract. Naylor Dana Institute. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0509403. 40–8324292. 47007 B3C43. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0509403.xhtml. January 10, 2023.
Winkler GA, Dilbarova R, Clark RF, 2023. Reversible neurotoxicity due to excessive use of ethyl chloride. J Emerg Med 64(2):255–258. 10.1016/j.jemermed.2022.12.002.36806431
Worrall S, De Jersey J, Wilce PA, 1994. Studies on the usefulness of acetaldehyde-modified proteins and associated antibodies as markers of alcohol abuse. Alcohol Alcoholism Suppl 2:503–507.
WQP. 2023. Water Quality Portal data: Chloroethane. U.S. Geological Survey (USGS), Environmental Protection Agency (EPA), National Water Quality Monitoring Council (NWQMC). https://www.epa.gov/waterdata/water-quality-data. April 12, 2023.
Wu X, Qu Y, Chemg G, 2013. [Molecular identification and conditions for preliminary application of a Bacillus sp]. CIESC Journal 64(4):1459–1465. 10.3969/j.issn.0438-1157.2013.04.046. (Chinese)
Yacoub I, Robinson CA, Simmons GT. 1993. Death attributed to ethyl chloride. J Anal Toxicol 17(6):384–385. 10.1093/jat/17.6.384.8271788
Young P, Parker A. 1984. Vapors, odors and toxic gases from landfills. In: Jackson LP, Rohlik AR, Conway RA, eds. Hazardous and industrial waste management and testing: Third symposium. STP851-EB. Philadelphia, PA: ASTM Technical Publication, 24–41.
Young R, Carter C, Cardinali S, 2023. Recognizing ethyl chloride neurotoxicity: Inhalant abuse hidden in plain sight. Cureus 15(4):e37795. 10.7759/cureus.37795.37214062