# VERSION HISTORY

Date | Description
January 2025 | Final toxicological profile released
January 2024 | Draft for public comment toxicological profile released
April 2016 | Addendum to the toxicological profile released
December 1998 | Final toxicological profile released