# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding chloroethane in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for chloroethane.

Table 7-1 Regulations and Guidelines Applicable to Chloroethane

Agency | Description | Information | Reference
Air
EPA | RfC | 10 mg/m^3^ (4 ppm) | IRIS 1991
| Provisional peer reviewed toxicity values | | EPA 2007
| Provisional subchronic RfC | 4 mg/m^3^ (1.5 ppm)
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018a
| National primary drinking water regulations | Not listed | EPA 2024
| RfD | Not evaluated | IRIS 1991
| Provisional peer reviewed toxicity values
| Provisional subchronic RfD | 0.1 mg/kg/day | EPA 2007
WHO | Drinking water quality guidelines | Not listed | WHO 2022
FDA | Substances added to food (formerly EAFUS) | Not listed | FDA 2023
Cancer
HHS | Carcinogenicity classification | Not evaluated | NTP 2021
EPA | Carcinogenicity classification | Not evaluated | IRIS 1991
| Provisional peer reviewed toxicity values | | EPA 2007
| Provisional carcinogenicity assessment | Likely to be carcinogenic to humans
IARC | Carcinogenicity classification | Group 3^a^ | IARC 1999
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | 1,000 ppm | OSHA 2023a, 2023b, 2023c
NIOSH | REL (up to 10-hour TWA) | Handle with caution in the workplace^b^ | NIOSH 2018, 2019
| IDLH | 3,800 ppm^c^ | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018b
DOE | PACs-air | | DOE 2024a
| PAC-1^d^ | 300 ppm
| PAC-2^d^ | 5,100 ppm^e^
| PAC-3^d^ | 20,000 ppm^f^

a Group 3: not classifiable as to carcinogenicity to humans.

b Due to structural similarity to other chloroethanes shown to be carcinogenic in animals.

c 10% of the LEL for chloroethane.

d Definitions of PAC terminology are available from DOE (2024b).

e Between 10 and 50% of the LEL.

f Between 50 and 100% of the LEL.

AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; LEL = lower explosive limit; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization