# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Chloroethane (also known as ethyl chloride) is a colorless gas at room temperature and pressure. When stored in pressurized containers, it is a liquid. It has a characteristically sharp pungent smell (NLM 2023). Information regarding the chemical identity of chloroethane is presented in Table 4-1.

Table 4-1 Chemical Identity of Chloroethane

Characteristic | Information | Reference
Chemical name | Ethyl chloride; chloroethane | Lide 2005
Synonym(s) and registered trade name(s) | Aethylis; chloridum; chlorethyl; ether chloratus; ether hydrochloric; ether muriatic; ethyl chloride; monochloroethane; Anodynon; Chelen; chloryl anesthetic; Kelene; Narcotile | NLM 2023
Chemical formula | C_2_H_5_Cl | NLM 2023
SMILES | CCCl | NLM 2023
Chemical structure | CH_3_–CH_2_–Cl | NLM 2023
CAS Registry Number | 75-00-3 | NLM 2023

CAS = Chemical Abstracts Service; SMILES = simplified molecular-input line-entry system

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Chloroethane is a colorless gas under standard atmospheric and temperature conditions. It is considered a flammable gas and should not be used in areas where ignition may occur (NLM 2023). In the environment, it is highly volatile and tends to partition to the atmosphere. Information regarding the physical and chemical properties of chloroethane is presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of Chloroethane

Property | Information | Reference
Molecular weight | 64.51 g/mol | NLM 2023
Color | Colorless | NLM 2023
Physical state | Gas | NLM 2023
Melting point | −138.7°C | Budavari et al. 1989
Boiling point | 32.5°C at 2 atm; 12.3°C at 760 torr | Budavari et al. 1989, 1996
Specific gravity at 0°C | 0.9214 | Budavari et al. 1996
Density at 20°C | 0.8970 | Morris and Tasto 1979
Odor | Ethereal, pungent | NLM 2023
Odor threshold:
Water | 0.019 ppm (w/v) | Amoore and Hautala 1983
Air | 4.2 ppm (v/v) (11.3 g/L) | Amoore and Hautala 1983
Solubility:
Water at 20°C | 0.574 g/100 mL | Budavari et al. 1989
Organic solvents | Alcohol: 48.3 g/100 mL | Budavari et al. 1989
Partition coefficients:
Log K_ow_ | 1.43 | NLM 2023
Log K_oc_ | 1.52 (estimated using equation 4–7) | Lyman 1982
K_oc_ | 143; 33 (using log K_oc_ of 1.52) | Lyman 1982
Vapor pressure at 20°C | 1,008 mmHg | Daubert and Danner 1985
Henry’s law constant at 25°C | 1.11×10^−2^ atm•m^3^/mole (24.8 C) | Gossett 1987
Autoignition temperature | 519°C | Morris and Tasto 1979
Flashpoint
Open cup | −43°C | Budavari et al. 1989
Closed cup | −50°C | Budavari et al. 1989
Conversion factors:
ppm (v/v) to mg/m^3^ in air (20°C) | ppm (v/v) × 2.68 = mg/m^3^ | Budavari et al. 1989
mg/m^3^ to ppm in air (20°C) | mg/m^3^ × 0.373 = ppm (v/v) | Budavari et al. 1989
Explosive limits in air | 3.8–15.4 volume % | NLM 2023