# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR CHLOROETHANE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to chloroethane.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for chloroethane. ATSDR primarily focused on peer-reviewed articles without language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of chloroethane have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of chloroethane are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

### B.1.1 Literature Search

The literature search was conducted to update the Toxicological Profile for Chloroethane released in 1998. All literature cited in the previous (1998) toxicological profile were considered for inclusion in the updated profile. The initial literature search, which was performed in May 2022, was restricted to studies added to databases since January 1996. An updated literature search was performed after the Toxicological Profile for Chloroethane Draft for Public Comment was released in January 2024 to identify any additional studies added to databases between May 2022 and April 2024.

The following main databases were searched in May 2022 and April 2024:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for chloroethane. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to chloroethane were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
04/2024 | ((“Ethyl Chloride”[mh] OR 75-00-3[rn]) AND (2022/05/01:3000[mhda] OR 2021:3000[dp])) OR ((“Chloroethane”[tw] OR “Ethane, chloro-”[tw] OR “Ethyl chloride”[tw] OR “ethylchloride”[tw] OR “Freon 160”[tw] OR “Monochlorethane”[tw] OR “Monochloroethane”[tw] OR “chlorethane”[tw] OR “Aethylis”[tw] OR “Anodynon”[tw] OR “Chlorethan”[tw] OR “Chloryl anesthetic”[tw] OR “Chloryle anesthetic”[tw] OR “Cloretilo”[tw] OR “Dublofix”[tw] OR “Ether chloratus”[tw] OR “Ether chloridum”[tw] OR “Ether hydrochloric”[tw] OR “Ether muriatic”[tw] OR “Hydrochloric ether”[tw] OR “Kelene”[tw] OR “Muriatic ether”[tw] OR “Narcotile”[tw] OR “Chelen”[tw] OR “Chlorene”[tw] OR “Chloridum”[tw] OR “Chloryl”[tw] OR “Chlorethyl”[tw]) AND (2022/05/01:3000[edat] OR 2022/05/01:3000[crdt] OR 2021:3000[dp]))
05/2022 | (“Ethyl Chloride”[mh] OR 75-00-3[rn] OR “Chloroethane”[tw] OR “Ethane, chloro-”[tw] OR “Ethyl chloride”[tw] OR “ethylchloride”[tw] OR “Freon 160”[tw] OR “Monochlorethane”[tw] OR “Monochloroethane”[tw] OR “chlorethane”[tw] OR “Aethylis”[tw] OR “Anodynon”[tw] OR “Chlorethan”[tw] OR “Chloryl anesthetic”[tw] OR “Chloryle anesthetic”[tw] OR “Cloretilo”[tw] OR “Dublofix”[tw] OR “Ether chloratus”[tw] OR “Ether chloridum”[tw] OR “Ether hydrochloric”[tw] OR “Ether muriatic”[tw] OR “Hydrochloric ether”[tw] OR “Kelene”[tw] OR “Muriatic ether”[tw] OR “Narcotile”[tw] OR “Chelen”[tw] OR “Chlorene”[tw] OR “Chloridum”[tw] OR “Chloryl”[tw] OR “Chlorethyl”[tw]) AND 1996:3000[dp]
NTRL
04/2024 | “Chloroethane” OR “Ethane, chloro-” OR “Ethyl chloride” OR “ethylchloride” OR “Freon 160” OR “Monochlorethane” OR “Monochloroethane” OR “chlorethane” OR “Aethylis” OR “Anodynon” OR “Chlorethan” OR “Chloryl anesthetic” OR “Chloryle anesthetic” OR “Cloretilo” OR “Dublofix” OR “Ether chloratus” OR “Ether chloridum” OR “Ether hydrochloric” OR “Ether muriatic” OR “Hydrochloric ether” OR “Kelene” OR “Muriatic ether” OR “Narcotile” OR “Chelen” OR “Chlorene” OR “Chloridum” OR “Chloryl” OR “Chlorethyl”; Limited to 2021-2024
05/2022 | “Chloroethane” OR “Ethane, chloro-” OR “Ethyl chloride” OR “ethylchloride” OR “Freon 160” OR “Monochlorethane” OR “Monochloroethane” OR “chlorethane” OR “Aethylis” OR “Anodynon” OR “Chlorethan” OR “Chloryl anesthetic” OR “Chloryle anesthetic” OR “Cloretilo” OR “Dublofix” OR “Ether chloratus” OR “Ether chloridum” OR “Ether hydrochloric” OR “Ether muriatic” OR “Hydrochloric ether” OR “Kelene” OR “Muriatic ether” OR “Narcotile” OR “Chelen” OR “Chlorene” OR “Chloridum” OR “Chloryl” OR “Chlorethyl”; Limited to 1996-2022
Toxcenter
04/2024 | FILE ‘TOXCENTER’ ENTERED AT 15:38:29 ON 25 APR 2024
| CHARGED TO COST=ET027.02.04.LB.02
| L1 2397 SEA FILE=TOXCENTER 75-00-3
| L2 2037 SEA FILE=TOXCENTER L1 NOT PATENT/DT
| L3 128 SEA FILE=TOXCENTER L2 AND ED>=20220501 ACT TOXQUERY/Q ---------
| L4 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?)
| L5 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,IT)
| L6 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50)
| L7 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT
| L8 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?)
| L9 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?)
| L10 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?)
| L11 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE))
| L12 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?)
| L13 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?)
| L14 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?)
| L15 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?)
| L16 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?)
| L17 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?)
| L18 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?)
| L19 QUE (ENDOCRIN? AND DISRUPT?)
| L20 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?)
| L21 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?)
| L22 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?)
| L23 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?)
| L24 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?)
| L25 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?)
| L26 QUE (NEPHROTOX? OR HEPATOTOX?)
| L27 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?)
| L28 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?)
| L29 QUE L4 OR L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28
| L30 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?)
| L31 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE)
| L32 QUE L29 OR L30 OR L31
| L33 QUE (NONHUMAN MAMMALS)/ORGN
| L34 QUE L32 OR L33
| L35 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?)
| L36 QUE L34 OR L35 ---------
| L37 57 SEA FILE=TOXCENTER L3 AND L36
| L38 1 SEA FILE=TOXCENTER L37 AND MEDLINE/FS
| L39 56 SEA FILE=TOXCENTER L37 NOT MEDLINE/FS
| L40 57 DUP REM L38 L39 (0 DUPLICATES REMOVED)
| L41 71 SEA FILE=TOXCENTER L3 NOT L37
| L42 1 SEA FILE=TOXCENTER L3 AND MEDLINE/FS D SCAN L3
05/2022 | FILE ‘TOXCENTER’ ENTERED AT 16:55:39 ON 16 MAY 2022
| CHARGED TO COST=EH038.15.03.LB.04
| L1 2227 SEA FILE=TOXCENTER 75-00-3
| L2 2132 SEA FILE=TOXCENTER L1 NOT TSCATS/FS
| L3 1807 SEA FILE=TOXCENTER L2 NOT PATENT/DT
| L4 1040 SEA FILE=TOXCENTER L3 AND PY>1995 ACTIVATE TOXQUERY/Q ---------
| L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?)
| L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,IT)
| L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50)
| L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT
| L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?)
| L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?)
| L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?)
| L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE))
| L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?)
| L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?)
| L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?)
| L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?)
| L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?)
| L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?)
| L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?)
| L20 QUE (ENDOCRIN? AND DISRUPT?)
| L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?)
| L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?)
| L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?)
| L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?)
| L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?)
| L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?)
| L27 QUE (NEPHROTOX? OR HEPATOTOX?)
| L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?)
| L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?)
| L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29
| L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?)
| L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE)
| L33 QUE L30 OR L31 OR L32
| L34 QUE (NONHUMAN MAMMALS)/ORGN
| L35 QUE L33 OR L34
| L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?)
| L37 QUE L35 OR L36 ---------
| L38 414 SEA FILE=TOXCENTER L4 AND L37
| L39 52 SEA FILE=TOXCENTER L38 AND MEDLINE/FS
| L41 362 SEA FILE=TOXCENTER L38 NOT MEDLINE/FS
| L42 393 DUP REM L39 L41 (21 DUPLICATES REMOVED)
| L*** DEL 52 S L38 AND MEDLINE/FS
| L*** DEL 52 S L38 AND MEDLINE/FS
| L43 52 SEA FILE=TOXCENTER L42
| L*** DEL 362 S L38 NOT MEDLINE/FS
| L*** DEL 362 S L38 NOT MEDLINE/FS
| L44 341 SEA FILE=TOXCENTER L42
| L45 341 SEA FILE=TOXCENTER (L43 OR L44) NOT MEDLINE/FS D SCAN L45

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
04/2024; 05/2022 | Compounds searched: 75-00-3
NTP
04/2024 | 75-00-3
| chloroethane
| “ethyl chloride”
| chlorethane
| chloryl
| “Ethane, chloro-”
| ethylchloride
| “Freon 160”
| monochloroethane
05/2022 | 75-00-3
| chloroethane
| “ethyl chloride”
Regulations.gov
04/2024 | Limited to 2021 to present
| chloroethane
| 75-00-3
| “ethyl chloride”
05/2022 | chloroethane
| 75-00-3
| “ethyl chloride”
| Limited to EPA docket or notices
NIH RePORTER
08/2024 | Search Criteria-- Fiscal Year: Active Projects; Text Search: “Chloroethane” OR “Ethane, chloro-” OR “Ethyl chloride” OR “ethylchloride” OR “Freon 160” OR “Monochlorethane” OR “Monochloroethane” OR “chlorethane” OR “Aethylis” OR “Anodynon” OR “Chlorethan” OR “Chloryl anesthetic” OR “Chloryle anesthetic” OR “Cloretilo” OR “Dublofix” OR “Ether chloratus” OR “Ether chloridum” OR “Ether hydrochloric” OR “Ether muriatic” OR “Hydrochloric ether” OR “Kelene” OR “Muriatic ether” OR “Narcotile” OR “Chelen” OR “Chlorene” OR “Chloridum” OR “Chloryl” OR “Chlorethyl” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
03/2023 | Search Criteria; Fiscal Year: Active Projects Text Search: “Chloroethane” OR “Ethane, chloro-” OR “Ethyl chloride” OR “ethylchloride” OR “Freon 160” OR “Monochlorethane” OR “Monochloroethane” OR “chlorethane” OR “Aethylis” OR “Anodynon” OR “Chlorethan” OR “Chloryl anesthetic” OR “Chloryle anesthetic” OR “Cloretilo” OR “Dublofix” OR “Ether chloratus” OR “Ether chloridum” OR “Ether hydrochloric” OR “Ether muriatic” OR “Hydrochloric ether” OR “Kelene” OR “Muriatic ether” OR “Narcotile” OR “Chelen” OR “Chlorene” OR “Chloryl” OR “Chlorethyl” (advanced)Limit to: Project Title, Project Terms, Project Abstracts; Search Criteria; Fiscal Year: Active Projects Text Search: “Chloridum” (advanced)Limit to: Project Title, Project Terms, Project Abstracts
Other | Includes additional reference identified throughout the assessment process, which may include studies found by tree searching; recommended by intraagency, interagency, peer, or public reviewers; or published more recently than the date of literature search(es). Additional references include those for specific regulations or guidelines and publications found by targeted searches for specific information (e.g., searches for reviews of general [not chemical-specific] mechanisms of toxicity).

The 2022 pre-public comment search results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 688
- Number of records identified from other strategies: 74
- Total number of records to undergo literature screening: 762

The 2024 post-public comment search results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 184
- Number of records identified from other strategies: 17
- Total number of records to undergo literature screening: 201

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on chloroethane during the pre- and post-public comment drafts:

- Title and abstract screen
- Full text screen

Pre-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 762
- Number of studies considered relevant and moved to the next step: 141

Pre-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 141
- Number of studies cited in the previous toxicological profile: 133
- Total number of studies cited in the profile: 213

A summary of the results of the pre-public literature search and screening is presented in Figure B-1.

Figure B-1 May 2022 Pre-Public Comment Literature Search Results and Screen for Chloroethane^*^ * The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.

Post-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 201
- Number of studies considered relevant and moved to the next step: 22

Post-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 22
- Number of studies cited in the pre-public draft of the toxicological profile: 213
- Total number of studies cited in the profile: 223

A summary of the results of the post-public comment literature search and screening is presented in Figure B-2.

Figure B-2 April 2024 Post-Public Comment Literature Search Results and Screen for Chloroethane^*^ * The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.