# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106–5, Atlanta, Georgia 30329–4027.

## Chloroethane Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroethane
CAS Numbers: | 75-00-3
Date: | January 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 13 ppm (34 mg/m^3^)
Critical Effect: | Increased incidence of DFFC of skull bones
Reference: | Scortichini et al. 1986
Point of Departure: | NOAEL of 1,504 ppm (NOAEL_HEC_ of 376 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 13
Species: | Mouse

MRL Summary: An acute-duration MRL of 13 ppm was derived for chloroethane based on a NOAEL of 1,504 ppm for developmental effects (increased incidence of DFFC of skull bones) in mouse fetuses exposed for 6 hours/day on GDs 6–15 (Scortichini et al. 1986). The NOAEL was adjusted for continuous exposure and converted to a human equivalent concentration (NOAEL_HEC_) of 376.0 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans after dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: Developmental and neurological effects were observed at approximately 5,000 ppm following acute-duration inhalation exposure of chloroethane in animals (Table A-1). Two studies looked at developmental effects of chloroethane. In pregnant mice exposed to chloroethane for 6 hours/day on GDs 6–15, an increase in incidence of DFFC of the skull bones (a developmental delay of ossification of small centers of unossified bone of the skull) was seen in the fetuses at 4,946 ppm (Scortichini et al. 1986). Incidence based on number of fetuses affected was significant for dose-response trend, but not in a pairwise comparison to the control group. Incidence data for number of litters affected were not statistically different from controls (by pairwise or trend tests); however, this effect was considered biologically relevant. The second developmental study reported that mouse fetuses exposed to 15,000 ppm for 6 hours/day on GDs 6–15 appeared normal; however, fetuses were not examined for skeletal or visceral alterations (Dow 1985). This study was not included in Table A-1 because no developmental effects occurred in the only treatment group.

Neurological effects have been reported in humans and several animal species. These effects consisted of a feeling of dizziness and intoxication in humans, hyperactivity in mice and dogs, lethargy in rats, and unsteadiness in guinea pigs; however, the study with the lowest LOAEL for neurological effects (Dow 1985) did not report a NOAEL value. Developmental toxicity (increased incidence of DFFC of the skull in fetuses) was selected as the critical effect because Scortichini et al. (1986) provided the lowest LOAEL with an accompanying NOAEL value.

Table A-1 Selected NOAEL and LOAEL Values in Animals Following Acute-Duration Inhalation Exposure to Chloroethane

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Developmental effects
Mouse (CF-1) | 10 days; 6 hours/day; GDs 6–15 | 1,504 | 4,946 | Increased incidence of delayed fetal foramina closure (DFFC) of the skull bones (developmental delay of ossification of bones of the skull of fetuses) | Scortichini et al. 1986
Neurological effects
Human | Up to 22 minutes | ND | 13,000 | LOAEL: subjective feeling of intoxication, increased reaction times | Davidson 1925
Fisher-344; rat | 2 weeks; 5 days/week; 6 hours/day | 3,980 | 9,980 | Slight lethargy | Landry et al. 1982
CD-1; mouse | 10 days; 6 hours/day; GDs 6–15 | ND | 5,000 | Increased activity and stereotypic behavior (highly repetitive running patterns) in dams | Dow 1985
Beagle; dog | 2 weeks; 5 days/week; 6 hours/day | 3,980 | 9,980 | Hyperactivity during exposure in 1/2 dogs | Landry et al. 1982

Selected study/endpoint for derivation of acute-duration inhalation MRL.

LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; SLOAEL = serious LOAEL

Selection of the Principal Study: Of the two developmental studies, Scortichini et al. (1986) was selected as the principal study because visceral and skeletal examinations were performed. In addition, this study provided a LOAEL with an accompanying NOAEL value.

Summary of the Principal Study:

Scortichini BH, Johnson KA, Momany-Pfruenderd JJ, 1986. Ethyl chloride: Inhalation teratology study in CF-1 mice. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section FYI. OTS0001135. FYI-OTS-0794–1135. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0001135.xhtml. April 12, 2023 .

Pregnant CF-1 mice (23–26/group) were exposed to 99.9% pure chloroethane at 0, 491, 1,504, or 4,946 ppm 6 hours/day on GDs 6–15. Body weights were recorded on GDs 6, 9, 12, 15, and 18, and food and water intakes were measured. The animals were sacrificed on GD 18 and the following data were recorded: maternal liver weight; number and position of fetuses in utero; number of live and dead fetuses; number and position of resorption sites; weight and sex of each fetus; and gross external alterations. Half of each litter was examined for visceral alterations, and the other half was examined for skeletal alterations.

No maternal toxicity (body weight, food and water intake, liver weight) was observed. There were no effects on pregnancy rate, resorption rate, litter size, sex ratio, or fetal body weight. No changes in gross external or visceral alterations were seen in the exposed fetuses compared to controls. An increase in supernumerary ribs was found, although the effect was not indicated as statistically significant. The incidences of fetuses with supernumerary ribs were 2/257, l/299, 6/311, and 2/242 at 0, 491, 1,504, and 4,946 ppm, respectively. The incidences in litters were 2/22, l/25, 5/26, and 4/22 at 0, 491, 1,504, and 4,946 ppm, respectively.

A small increase in the incidence of DFFC of the skull bones (developmental delay of ossification of small centers of unossified bone of the skull) was observed at the high dose. The incidence data based on number of fetuses affected were 1/126, 1/142, 1/147, and 5/116 at 0, 491, 1,504, and 4,946 ppm, respectively. The study authors indicated that the foramina data were statistically significant. ATSDR’s analysis of the data determined that there was a significant trend (p=0.0488) for the fetal data, but no significance in a pairwise comparison to the control group for the fetal data. Incidence data for number of litters affected were 1/22, 1/24, 1/25, and 5/22 at 0, 491, 1,504, and 4,946 ppm, respectively. The study authors indicated that the litter data were not significantly different from control. ATSDR’s analysis determined that there were no significant differences in the pairwise comparison to control or trend test for the litter data.

Selection of the Point of Departure for the MRL: The NOAEL of 1,504 ppm for developmental effects (increased incidence of DFFC of the skull) in fetuses exposed 6 hours/day on GDs 6–15 (Scortichini et al. 1986) was selected as the point of departure (POD). Benchmark dose (BMD) modeling was not done on litter data due to lack of statistical significance by both pairwise comparison and for trend.

Adjustment for Intermittent Exposure: The intermittent NOAEL of 1,504 ppm was adjusted to a 24-hour continuous exposure using the following equation:

N O A E L_A D J_ = N O A E L × (6 hours)/(24 hours) = 1,504 p p m × (6 hours)/(24 hours) = 376.0 p p m

Human Equivalent Concentration: The HEC was calculated by multiplying the NOAEL_ADJ_ by the ratio of the chloroethane air:blood partition coefficient for humans and mice. The reported blood:gas (air) partition coefficient (H_b/g_) values for chloroethane are 5.1 for mice and 1.9 or 2.69 for humans (Gargas et al. 1989, 2008; Morgan et al. 1970). Since the ratio of mouse to human blood:gas (air) partition coefficient is >1, a default value of 1 was used. The duration-adjusted LOAEL _HEC_ was 1,237 ppm.

N O A E L_H E C_ = N O A E L_A D J_ × ((H_b / g_)_A_)/((H_b / g_)_H_) = 376.0 p p m × 1 = 376.0 p p m

Uncertainty Factor: The NOAEL_HEC_ was divided by a total uncertainty factor of 30:

- 3 for extrapolation from animals to humans after dosimetric adjustment
- 10 for human variability

M R L = N O A E L_H E C_ ÷ U F s 376.0 p p m ÷ 30 = 12.53 p p m ≈ 13 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: No supporting studies or pertinent information were available.

Agency Contacts (Chemical Managers): Carolyn Harper

## Chloroethane Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroethane
CAS Numbers: | 75-00-3
Date: | January 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 13 ppm (34 mg/m^3^)
Critical Effect: | Increased estrous cycle length in mice
Reference: | Bucher et al. 1995
Point of Departure: | LOAEL of 15,000 ppm (LOAEL_HEC_ of 3,750 ppm)
Uncertainty Factor: | 300
LSE Graph Key: | 18
Species: | Mouse

MRL Summary: An intermediate-duration inhalation MRL of 13 ppm was derived for chloroethane based on a LOAEL of 15,000 ppm for reproductive effects (increased estrous cycle length) in mice exposed 6 hours/day for 21 days (Bucher et al. 1995). The LOAEL was adjusted to continuous-duration exposure and converted to a human equivalent concentration (LOAEL_HEC_) of 3,750 ppm and divided by a total uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans after dosimetric adjustment, and 10 for human variability).

Selection of the Critical Effect: The only adverse effect identified in intermediate-duration inhalation studies is related to the estrous cycle. The average duration of the estrous cycle increased significantly by 7% from 5.15 to 5.52 days in mice exposed to 15,000 ppm (only concentration tested) for 21 days, although no consistent effects on estradiol or progesterone were noted (Bucher et al. 1995). Breslin et al. (1988) also studied the length of the estrous cycle in mice after 14 days of exposure to 14,955 ppm for 6 hours/day. No significant increase in the estrous cycle length was seen during exposure compared to pre-exposure (5.0±0.7 days pre-exposure versus 5.6±0.8 days during exposure). The discrepancy between the two studies regarding increased estrous cycle length may be due to duration of exposure (14 versus 21 days) or number of animals studied. Bucher et al. (1995) studied 30 females/group, whereas Breslin et al. (1988) studied 10 females/group. The larger sample size would lend itself to greater statistical power to distinguish differences. In 13-week inhalation studies, no adverse effects (including histopathology on a complete panel of tissues) were observed in rats or mice exposed up to 19,000 ppm (NTP 1989). No adverse effects were observed in rats or rabbits exposed to 10,000 ppm (only concentration tested) for 6.5 months (Dow 1941).

Selection of the Principal Study: The intermediate-duration inhalation study investigating estrous cycle length was selected as the principal study (Bucher et al. 1995). No other intermediate-duration study reported a toxicologically relevant adverse effect.

Summary of the Principal Study:

Bucher JR, Morgan DL, Adkins B, 1995. Early changes in sex hormones are not evident in mice exposed to the uterine carcinogens chloroethane or bromoethane. Toxicol Appl Pharmacol 130:169–173. 10.1006/taap.1995.1022.7839365

Female B6C3F1 mice (30/group) were exposed to chloroethane at 0 or 15,000 ppm 6 hours/day for 21 days. Before the exposures, all the mice were sham-exposed for 21 days, and vaginal cytology studies were completed daily during the sham exposures and during the 21-day exposure period. Body weights were measured at least weekly. At necropsy, blood was drawn for measurement of serum estradiol and progesterone. The liver and uterus were weighed. The liver, uterus, pituitary gland, adrenal glands, and ovaries were examined microscopically.

No clinical signs of toxicity were observed. Body weights were not different from control (data not shown). In the exposed group, mean estrous cycle length significantly increased from 5.15±0.15 days prior to exposure to 5.52±0.19 days during exposure (a 7% increase). In the control group, mean estrous cycle length was not different between the pre-exposure period and exposure period (5.02±0.2 versus 5.0±0.2, pre-exposure and exposure, respectively). The proportion of time spent in the stages of the cycle during exposure was significantly different compared to pre-exposure in both the exposed and control group. Mice spent shorter time in metestrus and longer time in the other stages. No significant difference in serum estradiol or progesterone were seen at the end of the exposure. No significant differences in weights of liver, uterus, or ovary were seen compared to control (data not shown). No histological changes were observed in the ovaries, pituitary, uterus, or adrenal glands.

Selection of the Point of Departure for the MRL: The LOAEL of 15,000 ppm for reproductive effects (increased duration of estrous cycle) in mice exposed 6 hours/day for 21 days (Bucher et al. 1995) was selected as the POD.

Adjustment for Intermittent Exposure: The intermittent 6 hours/day LOAEL of 15,000 ppm was adjusted to a 24-hour continuous exposure using the following equation:

Human Equivalent Concentration: The HEC was calculated by multiplying the LOAEL_ADJ_ by the ratio of the chloroethane air:blood partition coefficient for humans and mice. The reported blood:gas (air) partition coefficient (H_b/g_) values for chloroethane are 5.1 for mouse and 1.9 or 2.69 for humans (Gargas et al. 1989, 2008; Morgan et al. 1970). Since the ratio of mouse to human blood:gas (air) partition coefficient is >1, a default value of 1 was used.

L O A E L_A D J_ = L O A E L × (6 hours)/(24 hours) = 15,000 p p m × (6 hours)/(24 hours) = 3,750 p p m

Uncertainty Factor: The LOAEL_HEC_ was divided by a total uncertainty factor of 300:

L O A E L_H E C_ = L O A E L_A D J_ × ((H_b / g_)_A_)/((H_b / g_)_H_) = 3,750 p p m × 1 = 3,750 p p m

- 10 for use of a LOAEL
- 3 for extrapolation from animals to humans after dosimetric adjustment
- 10 for human variability

M R L = L O A E L_H E C_ ÷ U F s 3,750 p p m ÷ 300 = 12.5 p p m ≈ 13 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: No supporting studies or pertinent information were available.

Agency Contacts (Chemical Managers): Carolyn Harper

## Chloroethane Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroethane
CAS Numbers: | 75-00-3
Date: | January 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for chloroethane.

Rationale for Not Deriving an MRL: Renal and neurological effects were observed in female mice exposed to 15,000 ppm chloroethane for 100 weeks (only concentration tested) (NTP 1989). However, this study also reported decreased survival in these exposed mice, attributed to carcinomas of the uterus. An MRL for renal and/or neurological effects was not derived because serious health effects were seen at the concentration level studied.

Agency Contacts (Chemical Managers): Carolyn Harper

## Chloroethane Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroethane
CAS Numbers: | 75-00-3
Date: | January 2025
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: The database was not considered adequate for derivation of an acute-duration oral MRL for chloroethane.

Rationale for Not Deriving an MRL: No acute-duration oral MRL was derived due to lack of adequate data regarding the potential effects of chloroethane. No toxicologically relevant effects were seen in rats exposed to chloroethane in drinking water at doses ranging from 297 to 662 mg/kg/day for 7 or 14 days (Dow 1995).

Agency Contacts (Chemical Managers): Carolyn Harper

## Chloroethane Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroethane
CAS Numbers: | 75-00-3
Date: | January 2025
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: The database was not considered adequate for derivation of an intermediate-duration oral MRL for chloroethane.

Rationale for Not Deriving an MRL: No intermediate-duration oral studies were located that met ATSDR quality inclusion criteria; therefore, no MRL could be derived.

Agency Contacts (Chemical Managers): Carolyn Harper

## Chloroethane Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chloroethane
CAS Numbers: | 75-00-3
Date: | January 2025
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: The database was not considered adequate for derivation of a chronic-duration oral MRL for chloroethane.

Rationale for Not Deriving an MRL: No studies were located that describe the effects of chronic-duration oral exposure to chloroethane in humans or animals.

Agency Contacts (Chemical Managers): Carolyn Harper