# CHAPTER 8 REFERENCES

Abad E, Abalos M, Fiedler H. 2022. Air monitoring with passive samplers for dioxin-like persistent organic pollutants in developing countries (2017–2019). Chemosphere 287(Pt 1):131931. 10.1016/j.chemosphere.2021.131931.34454223
Abbott BD, Birnbaum LS, Pratt RM. 1987. TCDD-induced hyperplasia of the ureteral epithelium produces hydronephrosis in murine fetuses. Teratology 35(3):329–334. 10.1002/tera.1420350307.3629513
Abraham K, Hille A, Ende M, 1994. Intake and fecal excretion of PCDDs, PCDFs, HCB and PCBs (138, 153, 180) in a breast-fed and a formula-fed infant. Chemosphere 29(9–11):2279–2286. 10.1016/0045-6535(94)90395-6.7850375
Abraham K, Knoll A, Ende M, 1996. Intake, fecal excretion, and body burden of polychlorinated dibenzo-p-dioxins and dibenzofurans in breast-fed and formula-fed infants. Pediatr Res 40(5):671–679. 10.1203/00006450-199611000-00005.8910931
Abraham K, Paepke O, Gross A, 1998. Time course of PCDD/PCB concentrations in breastfeeding mothers and their infants. Chemosphere 37(9–12):1731–1741.9828301
Ahlborg UG, Wærn F, Manzoor E, 1989. Effects of combinations of PCDDs/PCDFs given to Sprague-Dawley rats. Chemosphere 18(1–6):283–289. 10.1016/0045-6535(89)90132-x.
Akahane M, Matsumoto S, Kanagawa Y, 2018. Long-term health effects of PCBs and related compounds: A comparative analysis of patients suffering from Yusho and the general population. Arch Environ Contam Toxicol 74(2):203–217. 10.1007/s00244-017-0486-6.29256109
Almemark M, Frostell B, Finnveden G. 1991. Treatment technologies for organochlorine-containing sludges and concentrates from external treatment of pulp and paper wastewaters. Water Sci Technol 24(3–4):319–329. 10.2166/wst.1991.0488.
Amendola G, Barna D, Blosser R, 1989. The occurrence and fate of PCDDs and PCDFs in five bleached kraft pulp and paper mills. Chemosphere 18(1–6):1181–1188. 10.1016/0045-6535(89)90253-1.
Amutova F, Delannoy M, Baubekova A, 2021. Transfer of persistent organic pollutants in food of animal origin - Meta-analysis of published data. Chemosphere 262:128351. 10.1016/j.chemosphere.2020.128351.33182113
Ankley GT, Niemi GJ, Lodge KB, 1993. Uptake of planar polychlorinated biphenyls and 2,3,7,8-substituted polychlorinated dibenzofurans and dibenzo-p-dioxins by birds nesting in the lower Fox River and Green Bay, Wisconsin, USA. Arch Environ Contam Toxicol 24(3):332–344. 10.1007/bf01128731.
Aozasa O, Ohta S, Mase Y, 1995. Comparative studies on bioaccumulation of PCDDs and PCDFs in C57BL/6 and DBA/2 mice treated with a mixture by oral administration. Chemosphere 30(9):1819–1828. 10.1016/0045-6535(95)00050-i.7757429
Aries E, Anderson DR, Fisher R. 2008. Exposure assessment of workers to airborne PCDD/Fs, PCBs and PAHs at an electric arc furnace steelmaking plant in the UK. Ann Occup Hyg 52(4):213–225. 10.1093/annhyg/men011.18400768
Arnot JA, Meylan W, Tunkel J, 2009. A quantitative structure-activity relationship for predicting metabolic biotransformation rates for organic chemicals in fish. Environ Toxicol Chem 28(6):1168–1177. 10.1897/08-289.1.19152232
Atkinson R. 1991. Atmospheric lifetimes of dibenzo-p-dioxins and dibenzofurans. Sci Total Environ 104(1–2):17–33. 10.1016/0048-9697(91)90005-y.1871588
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 1998. Toxicological profile for chlorinated dibenzo-p-dioxins (CDDs). Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/ToxProfiles/tp104.pdf. April 23, 2020.
ATSDR. 2000. Toxicological profile for polychlorinated biphenyls (PCBs). Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/toxprofiles/tp17.pdf. April 23, 2020.
ATSDR. 2012. Addendum to the toxicological profile for chlorinated dibenzo-p-dioxins (CDDs). Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/toxprofiles/cdds_addendum.pdf. April 23, 2020.
ATSDR. 2017. Chlorodibenzofurans. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/spl/resources/ATSDR_2017_SPL_Toxicity_Values.xlsx. July 30, 2020.
ATSDR. 2019. Chlorodibenzofurans. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Bajanowski T, Furst P, Wilmers K, 2002. Dioxin in infants - an environmental hazard? Int J Legal Med 116(1):27–32. 10.1007/s004140100257.11924704
Ballschmiter K, Buchert H, Niemczyk R, 1986. Automobile exhausts versus municipal-waste incineration as sources of the polychloro-dibenzodioxins (PCDD) and -furans (PCDF) found in the environment. Chemosphere 15(7):901–915. 10.1016/0045-6535(86)90055-x.
Bandiera S, Farrell K, Mason G, 1984a. Comparative toxicities of the polychlorinated dibenzofuran (PCDF) and biphenyl (PCB) mixtures which persist in Yusho victims. Chemosphere 13(4):507–512. 10.1016/0045-6535(84)90145-0.
Bandiera S, Sawyer T, Romkes M, 1984b. Polychlorinated dibenzofurans (PCDFs): effects of structure on binding to the 2,3,7,8-TCDD cytosolic receptor protein, AHH induction and toxicity. Toxicology 32(2):131–144. 10.1016/0300-483x(84)90132-x.6464025
Banks YB, Brewster DW, Birnbaum LS. 1990. Age-related changes in dermal absorption of 2,3,7, 8-tetrachlorodibenzo-p-dioxin and 2,3,4,7,8-pentachlorodibenzofuran. Fundam Appl Toxicol 15(1):163–173. 10.1016/0272-0590(90)90173-h.2373296
Bannister R, Safe S. 1987. The effects of receptor antagonists on the AHH induction activity of 2,3,7,8-TCDD in C57BL/6 and DBA/2 mice: 1,3,6,8-tetrachlorodibenzofuran. Chemosphere 16(8–9):1739–1742. 10.1016/0045-6535(87)90160-3.
Barnes DG, Dourson M. 1988. Reference dose (RfD): description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Bartalini A, Munoz-Arnanz J, Marsili L, 2019. Evaluation of PCDD/Fs, dioxin-like PCBs and PBDEs in sperm whales from the Mediterranean Sea. Sci Total Environ 653:1417–1425. 10.1016/j.scitotenv.2018.10.436.30759580
Barton DA, McKeown JJ, Brunck R. 1990. A screening study of the treatability of dioxins and furans in bleach plant filtrates and mill wastewaters. Chemosphere 20(10–12):1747–1754. 10.1016/0045-6535(90)90338-t.
Beck H, Droß A, Mathar W. 1992. Dependence of PCDD and PCDF levels in human milk on various parameters in Germany II. Chemosphere 25(7–10):1015–1020. 10.1016/0045-6535(92)90101-v.
Beck H, Dross A, Mathar W. 1994. PCDD and PCDF exposure and levels in humans in Germany. Environ Health Perspect 102(Suppl 1):173–185. 10.1289/ehp.94102s1173.
Beck H, Eckart K, Mathar W, 1989. Levels of PCDDs and PCDFs in adipose tissue of occupationally exposed workers. Chemosphere 18(1–6):507–516. 10.1016/0045-6535(89)90161-6.
Beck H, Droß A, Kleemann WJ, 1990a. PCDD and PCDF concentrations in different organs from infants. Chemosphere 20(7–9):903–910. 10.1016/0045-6535(90)90199-4.
Beck H, Droß A, Mathar W, 1990b. Influence of different regional emissions and cardboard containers on levels of PCDD, PCDF and related compounds in cow milk. Chemosphere 21(6):789–798. 10.1016/0045-6535(90)90266-V.
Birmingham B, Thorpe B, Frank R, 1989a. Dietary intake of PCDD and PCDF from food in Ontario, Canada. Chemosphere 19(1–6):507–512. 10.1016/0045-6535(89)90360-3.
Birmingham B, Gilman A, Grant D, 1989b. PCDD/PCDF multimedia exposure analysis for the Canadian population: Detailed exposure estimation. Chemosphere 19(1–6):637–642. 10.1016/0045-6535(89)90383-4.
Birnbaum LS. 1985. The role of structure in the disposition of halogenated aromatic xenobiotics. Environ Health Perspect 61:11–20. 10.1289/ehp.856111.2998745
Birnbaum LS, Decad GM, Matthews HB. 1980. Disposition and excretion of 2,3,7,8-tetrachlorodibenzofuran in the rat. Toxicol Appl Pharmacol 55(2):342–352. 10.1016/0041-008x(80)90096-4.7423523
Birnbaum LS, Decad GM, Matthews HB, 1981. Fate of 2,3,7,8-tetrachlorodibenzofuran in the monkey. Toxicol Appl Pharmacol 57(2):189–196. 10.1016/0041-008x(81)90279-9.7222035
Birnbaum LS, Harris MW, Barnhart ER, 1987a. Teratogenicity of three polychlorinated dibenzofurans in C57BL/6N mice. Toxicol Appl Pharmacol 90(2):206–216. 10.1016/0041-008x(87)90328-0.3629596
Birnbaum LS, Harris MW, Crawford DD, 1987b. Teratogenic effects of polychlorinated dibenzofurans in combination in C57BL/6N mice. Toxicol Appl Pharmacol 91(2):246–255. 10.1016/0041-008x(87)90105-0.3672524
Bloom M, Vena J, Olson J, 2006. Chronic exposure to dioxin-like compounds and thyroid function among New York anglers. Environ Toxicol Pharmacol 21(3):260–267. 10.1016/j.etap.2005.09.001.21783667
Bobet E, Berard MF, Dann T. 1990. The measurement of PCDD and PCDF in ambient air in southwestern Ontario. Chemosphere 20(10–12):1439–1445. 10.1016/0045-6535(90)90295-5.
Boda H, Nghi TN, Nishijo M, 2018. Prenatal dioxin exposure estimated from dioxins in breast milk and sex hormone levels in umbilical cord blood in Vietnamese newborn infants. Sci Total Environ 615:1312–1318. 10.1016/j.scitotenv.2017.09.214.29751436
Boenke A, Ballschmiter K. 1989. Formation of polychlorinated dibenzofurans in the pyrolysis of chlorinated fluorenones and 9,10-anthraquinones at 400°C. Fresenius Z Anal Chem 333(7):723–724. 10.1007/BF00476581.
Bonfanti L, Cioni M, Rossi C, 1990. Evaluation of PCDD/PCDF emission from the combined combustion of RDF with coal. Chemosphere 20(10–12):1891–1897. 10.1016/0045-6535(90)90357-y.
Bopp RF, Gross ML, Tong H, 1991. A major incident of dioxin contamination: sediments of New Jersey estuaries. Environ Sci Technol 25(5):951–956. 10.1021/es00017a019.
Borwitzky H, Schramm KW. 1991. Reduction of dioxin concentrations on contaminated surfaces. Chemosphere 22(5–6):485–493. 10.1016/0045-6535(91)90060-q.
Boutros PC, Bielefeld KA, Pohjanvirta R, 2009. Dioxin-dependent and dioxin-independent gene batteries: comparison of liver and kidney in AHR-null mice. Toxicol Sci 112(1):245–256. 10.1093/toxsci/kfp191.19759094
Boverhof DR, Burgoon LD, Tashiro C, 2006. Comparative toxicogenomic analysis of the hepatotoxic effects of TCDD in Sprague Dawley rats and C57BL/6 mice. Toxicol Sci 94(2):398–416. 10.1093/toxsci/kfl100.16960034
Bowes CW, Mulvihill MJ, Simoneit BR, 1975a. Identification of chlorinated dibenzofurans in American polychlorinated biphenyls. Nature 256(5515):305–307. 10.1038/256305b0.806811
Bowes GW, Mulvihill MJ, DeCamp MR, 1975b. Gas chromatographic characteristics of authentic chlorinated dibenzofurans; identification of two isomers in American and Japanese polychlorinated biphenyls. J Agric Food Chem 23(6):1222–1223. 10.1021/jf60202a045.811702
Brewster DW, Birnbaum LS. 1987. Disposition and excretion of 2,3,4,7,8-pentachlorodibenzofuran in the rat. Toxicol Appl Pharmacol 90(2):243–252. 10.1016/0041-008x(87)90332-2.3629600
Brewster DW, Uraih LC, Birnbaum LS. 1988. The acute toxicity of 2,3,4,7,8-pentachlorodibenzofuran (4PeCDF) in the male Fischer rat. Fundam Appl Toxicol 11(2):236–249. 10.1016/0272-0590(88)90148-0.3220203
Brewster DW, Banks YB, Clark AM, 1989. Comparative dermal absorption of 2,3,7,8-tetrachlorodibenzo-p-dioxin and three polychlorinated dibenzofurans. Toxicol Appl Pharmacol 97(1):156–166. 10.1016/0041-008x(89)90064-1.2916232
Brna TG, Kilgroe JD. 1990. Control of PCDD/PCDF emissions from municipal waste combustion systems. Chemosphere 20(10–12):1875–1882. 10.1016/0045-6535(90)90355-w.
Broman D, Naf C, Rolff C, 1992. Using ratios of stable nitrogen isotopes to estimate bioaccumulation and flux of polychlorinated dibenzo-p-dioxins (PCDDs) and dibenzofurans (PCDFs) in two food chains from the northern Baltic. Environ Toxicol Chem 11(3):331–345. 10.1002/etc.5620110307.
Brown JF, Lawton RW. 1984. Polychlorinated biphenyl (PCB) partitioning between adipose tissue and serum. Bull Environ Contam Toxicol 33(3):277–280. 10.1007/bf01625543.6434008
Budinsky RA, Rowlands JC, Casteel S, 2008. A pilot study of oral bioavailability of dioxins and furans from contaminated soils: Impact of differential hepatic enzyme activity and species differences. Chemosphere 70(10):1774–1786. 10.1016/j.chemosphere.2007.08.035.17945330
Bumb RR, Crummett WB, Cutie SS, 1980. Trace chemistries of fire: A source of chlorinated dioxins. Science 210(4468):385–390. 10.1126/science.6159682.6159682
Burka LT, McGown SR, Tomer KB. 1990. Identification of the biliary metabolites of 2,3,7,8-tetrachlorodibenzofuran in the rat. Chemosphere 21(10-11):1231–1242. 10.1016/0045-6535(90)90143-h.
Burkhard LP, Kuehl DW. 1986. N-octanol/water partition coefficients by reverse phase liquid chromatography/mass spectrometry for eight tetrachlorinated planar molecules. Chemosphere 15(2):163–167. 10.1016/0045-6535(86)90568-0.
Buser HR. 1976. Preparation of qualitative standard mixtures of polychlorinated dibenzo-p-dioxins and dibenzofurans by ultraviolet and γ-irradiation of the octachloro compounds. J Chromatogr 129:303–307. 10.1016/s0021-9673(00)87788-2.826542
Buser HR. 1979. Formation of polychlorinated dibenzofurans (PCDFs) from the pyrolysis of individual PCB isomers. Chemosphere 8(3):157–174. 10.1016/0045-6535(79)90065-1.
Cai LY, Izumi S, Suzuki T, 2011. Dioxins in ascites and serum of women with endometriosis: a pilot study. Hum Reprod 26(1):117–126. 10.1093/humrep/deq312.21106495
Campbell CA, Teschke K, Bert J, 1996. Pharmacokinetic model of dioxin and furan levels in adipose tissue from sawmill work involving chlorophenate fungicides. Chemosphere 33(12):2373–2381. 10.1016/s0045-6535(96)00341-4.8976054
Campin DN, Buckland SJ, Hannah DJ, 1991. The identification of dioxin sources in an integrated wood processing facility. Water Sci Technol 24(3–4):65–74. 10.2166/wst.1991.0463.
Campo L, Bechtold P, Borsari L, 2019. A systematic review on biomonitoring of individuals living near or working at solid waste incinerator plants. Crit Rev Toxicol 49(6):479–519. 10.1080/10408444.2019.1630362.31524034
Cao X, Ji L, Lin X, 2018. Comprehensive diagnosis of PCDD/F emission from three hazardous waste incinerators. R Soc Open Sci 5(7):172056. 10.1098/rsos.172056.30109050
CARB. 1989. Determination of body burdens for polychlorinated dibenzo-p-dioxins (PCDDs) and polychlorinated dibenzofurans (PCDFs) in California residents. Sacramento: California Air Resources Board. PB90148289. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB90148289.xhtml. June 17, 2020.
CARB. 1990. Ambient concentrations of PCDDs/PCDFs (polychlorinated dibenzodioxins/dibenzofurans) in the South Coast air basin. Sacramento, CA: California Air Resources Board. PB90169970. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB90169970.xhtml. June 19, 2020.
Carrier G, Brunet RC, Brodeur J. 1995a. Modeling of the toxicokinetics of polychlorinated dibenzo-p-dioxins and dibenzofurans in mammalians, including humans. I. Nonlinear distribution of PCDD/PCDF body burden between liver and adipose tissues. Toxicol Appl Pharmacol 131(2):253–266. 10.1006/taap.1995.1068.7716767
Carrier G, Brunet RC, Brodeur J. 1995b. Modeling of the toxicokinetics of polychlorinated dibenzo-p-dioxins and dibenzofurans in mammalians, including humans. II. Kinetics of absorption and disposition of PCDDs/PCDFs. Toxicol Appl Pharmacol 131(2):267–276. 10.1006/taap.1995.1069.7716768
Carsch S, Thoma H, Hutzinger O. 1986. Leaching of polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans from municipal waste incinerator fly ash by water and organic solvents. Chemosphere 15(9–12):1927–1930. 10.1016/0045-6535(86)90485-6.
CDC. 2021. Fourth report on human exposure to environmental chemicals, updated tables, (March 2021). Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/. July 10, 2021.
Chang KJ, Lu FJ, Tung TC, 1980. Studies on patients with polychlorinated biphenyl poisoning. 2. Determination of urinary coproporphyrin, uroporphyrin, delta-aminolevulinic acid and porphobilinogen. Res Commun Chem Pathol Pharmacol 30(3):547–554.6789414
Chang KJ, Hsieh KH, Lee TP, 1981. Immunologic evaluation of patients with polychlorinated biphenyl poisoning: determination of lymphocyte subpopulations. Toxicol Appl Pharmacol 61(1):58–63. 10.1016/0041-008x(81)90007-7.6794186
Chang KJ, Hsieh KH, Lee TP, 1982a. Immunologic evaluation of patients with polychlorinated biphenyl poisoning: determination of phagocyte Fc and complement receptors. Environ Res 28(2):329–334. 10.1016/0013-9351(82)90131-1.6811262
Chang KJ, Hsieh KH, Tang SY, 1982b. Immunologic evaluation of patients with polychlorinated biphenyl poisoning: evaluation of delayed-type skin hypersensitive response and its relation to clinical studies. J Toxicol Environ Health 9(2):217–223. 10.1080/15287398209530156.6804636
Chang RR, Jarman WM, King CC, 1990. Bioaccumulation of PCDDs and PCDFs in food animals III: A rapid cleanup of biological materials using reverse phase adsorbent columns. Chemosphere 20(7–9):881–886. 10.1016/0045-6535(90)90196-z.
Chang JW, Chen HL, Su HJ, 2010. Dioxin exposure and insulin resistance in Taiwanese living near a highly contaminated area. Epidemiology 21(1):56–61. 10.1097/EDE.0b013e3181c2fc6e.20010210
Chang JW, Chen HL, Su HJ, 2016. Abdominal obesity and insulin resistance in people exposed to moderate-to-high levels of dioxin. PLoS ONE 11(1):e0145818. 10.1371/journal.pone.0145818.26752053
Chao WY, Hsu CC, Guo YL. 1997. Middle-ear disease in children exposed prenatally to polychlorinated biphenyls and polychlorinated dibenzofurans. Arch Environ Health 52(4):257–262. 10.1080/00039899709602195.9210724
Chen PH, Hsu ST. 1986. PCB poisoning from toxic rice-bran oil in Taiwan. In: Waid JS, ed. PCBs and the environment. Vol. 3. Boca Raton, FL: CRC Press, 27–38.
Chen PH, Wong CK, Rappe C, 1985a. Polychlorinated biphenyls, dibenzofurans and quaterphenyls in toxic rice-bran oil and in the blood and tissues of patients with PCB poisoning (Yu-Cheng) in Taiwan. Environ Health Perspect 59:59–65. 10.1289/ehp.59-1568079.3921366
Chen RC, Tang SY, Miyata H, 1985b. Polychlorinated biphenyl poisoning: correlation of sensory and motor nerve conduction, neurologic symptoms, and blood levels of polychlorinated biphenyls, quaterphenyls, and dibenzofurans. Environ Res 37(2):340–348. 10.1016/0013-9351(85)90114-8.3926478
Chen YC, Guo YL, Hsu CC, 1992. Cognitive development of Yu-Cheng ('oil disease') children prenatally exposed to heat-degraded PCBs. JAMA 268(22):3213–3218.1433761
Chen K, Huang T, Zhang X, 2021. The footprint of dioxins in globally traded pork meat. iScience 24(11):103255. 10.1016/j.isci.2021.103255.34755094
Chia LG, Chu FL. 1984. Neurological studies on polychlorinated biphenyl (PCB)-poisoned patients. Am J Ind Med 5(1–2):117–126.6422742
Chia LG, Chu FL. 1985. A clinical and electrophysiological study of patients with polychlorinated biphenyl poisoning. J Neurol Neurosurg Psychiatry 48(9):894–901. 10.1136/jnnp.48.9.894.2995592
Choudhry GG, Hutzinger O. 1982. Mechanistic aspects of the thermal formation of halogenated organic compounds including polychlorinated dibenzo-p-dioxins. Part II. Thermochemical generation and destruction of dibenzofurans and dibenzo-p-dioxins. Toxicol Environ Chem 5(1):67–93. 10.1080/02772248209356970.
Choudhry GG, Sundstrom G, Ruzo LO, 1977. Photochemistry of chlorinated diphenyl ethers. J Agric Food Chem 25(6):1371–1376. 10.1021/jf60214a004.
Christmann W, Kasiske D, Klöppel KD, 1989a. Combustion of polyvinylchloride - an important source for the formation of PCDD/PCDF. Chemosphere 19(1–6):387–392. 10.1016/0045-6535(89)90340-8.
Christmann W, Klöppel KD, Partscht H, 1989b. PCDD/PCDF and chlorinated phenols in wood preserving formulations for household use. Chemosphere 18(1–6):861–865. 10.1016/0045-6535(89)90210-5.
Clark KE, Mackay D. 1991. Dietary uptake and biomagnification of four chlorinated hydrocarbons by guppies. Environ Toxicol Chem 10(9):1205–1217. 10.1002/etc.5620100912.
Clement RE, Tosine HM, Ali B. 1985. Levels of polychlorinated dibenzo-p-dioxins and dibenzofurans in wood burning stoves and fireplaces. Chemosphere 14(6–7):815–819. 10.1016/0045-6535(85)90194-8.
Clement RE, Suter SA, Tosine HM. 1989a. Analysis of large volume water samples near chemical dump sites using the aqueous phase liquid extractor (APLE). Chemosphere 18(1–6):133–140. 10.1016/0045-6535(89)90113-6.
Clement RE, Tosine HM, Osborne J, 1987a. Emissions of chlorinated organics from a municipal sewage sludge burning incinerator. Chemosphere 16(8–9):1895–1900. 10.1016/0045-6535(87)90184-6.
Clement RE, Tosine HM, Taguchi V, 1987b. Investigation of American lobster, Homarus americanus, for the presence of chlorinated dibenzo-p-dioxins and dibenzofurans. Bull Environ Contam Toxicol 39(6):1069–1075. 10.1007/bf01689600.3440145
Clement RE, Tashiro C, Suter S, 1989b. Chlorinated dibenzo-p-dioxins (CDDs) and dibenzofurans (CDFs) in effluents and sludges from pulp and paper mills. Chemosphere 18(1–6):1189–1197. 10.1016/0045-6535(89)90254-3.
Clement RE, Suter SA, Reiner E, 1989c. Concentrations of chlorinated dibenzo-p-dioxins and dibenzofurans in effluents and centrifuged particulates from Ontario pulp and paper mills. Chemosphere 19(1–6):649–654. 10.1016/0045-6535(89)90385-8.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Couture LA, Harris MW, Birnbaum LS. 1989. Developmental toxicity of 2,3,4,7,8-pentachlorodibenzofuran in the Fischer 344 rat. Fundam Appl Toxicol 12(2):358–366. 10.1016/0272-0590(89)90052-3.2714534
Cramer G, Bolger M, Henry S, 1991. USFDA assessment of exposure to 2,3,7,8-TCDD and 2,3,7,8-TCDF from foods contacting bleached paper products. Chemosphere 23(8–10):1537–1550. 10.1016/0045-6535(91)90179-h.
Crandall MS, Kinnes GM, Hartle RW. 1992. Levels of chlorinated dioxins and furans in three occupational environments. Chemosphere 25(1–2):255–258. 10.1016/0045-6535(92)90527-x.
Crofton KM, Craft ES, Hedge JM, 2005. Thyroid-hormone-disrupting chemicals: evidence for dose-dependent additivity or synergism. Environ Health Perspect 113(11):1549–1554. 10.1289/ehp.8195.16263510
Czuczwa JM, Hites RA. 1986a. Sources and fate of PCDD and PCDF. Chemosphere 15(9–12):1417–1420. 10.1016/0045-6535(86)90419-4.
Czuczwa JM, Hites RA. 1986b. Airborne dioxins and dibenzofurans: sources and fates. Environ Sci Technol 20(2):195–200. 10.1021/es00144a015.22288811
Czuczwa JM, Niessen F, Hites RA. 1985. Historical record of polychlorinated dibenzo-p-dioxins and dibenzofurans in Swiss lake sediments. Chemosphere 14(9):1175–1179. 10.1016/0045-6535(85)90139-0.
Czuczwa J, Katona V, Pitts G, 1989. Analysis of fog samples for PCDD and PCDF. Chemosphere 18(1–6):847–850. 10.1016/0045-6535(89)90207-5.
Dahl P, Lindstrom G, Wiberg K, 1995. Absorption of polychlorinated biphenyls, dibenzo-p-dioxins and dibenzofurans by breast-fed infants. Chemosphere 30(12):2297–2306. 10.1016/0045-6535(95)00102-e.7620852
Dahmer SC, Tetreault GR, Hall RI, 2015. Historical decline and altered congener patterns of polychlorinated dibenzo-p-dioxins and dibenzofurans in fish and sediment in response to process changes at a pulp mill discharging into Jackfish Bay, Lake Superior. Environ Toxicol Chem 34(11):2489–2502. 10.1002/etc.3126.26468966
Davis D, Safe S. 1988. Immunosuppressive activities of polychlorinated dibenzofuran congeners: quantitative structure-activity relationships and interactive effects. Toxicol Appl Pharmacol 94(1):141–149. 10.1016/0041-008x(88)90344-4.2836965
De Jongh J, Belfroid A, Sinnige T, 1992. Disposition, elimination and enzyme induction of 1,2,3,7,8-PnCDD, 1,2,3,6,7,8-HxCDD and 2,3,4,7,8-PnCDF in the liver of the mouse after a single oral dose. Chemosphere 25(12):1851–1859.
De Jongh J, Nieboer R, Schroders I, 1993. Toxicokinetic mixture interactions between chlorinated aromatic hydrocarbons in the liver of the C57BL/6J mouse: 2. Polychlorinated dibenzo-p-dioxins (PCDDs), dibenzofurans (PCDFs) and biphenyls (PCBs). Arch Toxicol 67(9):598–604. 10.1007/bf01974066.8311686
De Vault D, Dunn W, Bergqvist P- A, 1989. Polychlorinated dibenzofurans and polychlorinated dibenzo-p-dioxins in Great Lakes fish: A baseline and interlake comparison. Environ Toxicol Chem 8(11):1013–1022. 10.1002/etc.5620081107.
Decad GM, Birnbaum LS, Matthews HB. 1981a. 2,3,7,8-Tetrachlorodibenzofuran tissue distribution and excretion in guinea pig. Toxicol Appl Pharmacol 57(2):231–240. 10.1016/0041-008x(81)90284-2.7222040
Decad GM, Birnbaum LS, Matthews HB. 1981b. Distribution and excretion of 2,3,7,8-tetrachlorodibenzofuran in C57BL/6J and DBA/2J mice. Toxicol Appl Pharmacol 59(3):564–573. 10.1016/0041-008x(81)90311-2.7268779
Denison MS, Soshilov AA, He G, 2011. Exactly the same but different: promiscuity and diversity in the molecular mechanisms of action of the aryl hydrocarbon (dioxin) receptor. Toxicol Sci 124(1):1–22. 10.1093/toxsci/kfr218.21908767
des Rosiers PE. 1983. Remedial measures for wastes containing polychlorinated dibenzo-p-dioxins (PCDDs) and dibenzofurans (PCDFs): destruction, containment or process modification. Ann Occup Hyg 27(1):57–72. 10.1093/annhyg/27.1.57.6847045
des Rosiers PE. 1986. Methodologies for materials contaminated with PCDDs and related compounds. Chemosphere 15(9–12):1513–1528. 10.1016/0045-6535(86)90432-7.
des Rosiers PE. 1987. National dioxin study. ACS Symp Ser 338:34–53. 10.1021/bk-1987-0338.ch003.
des Rosiers PE, Lee A. 1986. PCBs fires: Correlation of chlorobenzene isomer and PCB homolog contents of PCB fluids with PCDD and PCDF contents of soot. Chemosphere 15(9–12):1313–1132. 10.1016/0045-6535(86)90406-6.
Deshmukh H, Aylward LL, Rose M, 2020. Association of endocrine active environmental compounds with body mass index and weight loss following bariatric surgery. Clin Endocrinol (Oxf) 93(3):280–287. 10.1111/cen.14257.32436601
DeVito MJ, Ross DR, Birnbaum LS. 1995. Disposition of PCDD/PCDF in mice. Organohalogen Compounds 25:11–15. http://dioxin20xx.org/wp-content/uploads/pdfs/1995/95-68.pdf. October 7, 2019.
DeVito MJ, Maier WE, Diliberto JJ, 1993. Comparative ability of various PCBs, PCDFs, and TCDD to induce cytochrome P450 1A1 and 1A2 activity following 4 weeks of treatment. Fundam Appl Toxicol 20(1):125–130.8432423
DeVito MJ, Diliberto JJ, Ross DG, 1997. Dose-response relationships for polyhalogenated dioxins and dibenzofurans following subchronic treatment in mice. I. CYP1A1 and CYP1A2 enzyme activity in liver, lung, and skin. Toxicol Appl Pharmacol 147(2):267–280. 10.1006/taap.1997.8261.9439722
DeVito MJ, Ross DG, Dupuy AE, 1998. Dose-response relationships for disposition and hepatic sequestration of polyhalogenated dibenzo-p-dioxins, dibenzofurans, and biphenyls following subchronic treatment in mice. Toxicol Sci 46(2):223–234. 10.1006/toxs.1998.2530.10048125
Dewailly E, Weber JP, Gingras S, 1991. Coplanar PCBs in human milk in the province of Quebec, Canada: are they more toxic than dioxin for breast fed infants? Bull Environ Contam Toxicol 47(4):491–498. 10.1007/bf01700935.1786431
Dickerson R, Howie L, Davis D, 1990. The structure-dependent effects of heptachlorodibenzofuran isomers in male C57BL/6 mice: immunotoxicity and monooxygenase enzyme induction. Fundam Appl Toxicol 15(2):298–307. 10.1016/0272-0590(90)90056-p.2227157
Diliberto JJ, Burgin D, Birnbaum LS. 1997. Role of CYP1A2 in hepatic sequestration of dioxin: studies using CYP1A2 knock-out mice. Biochem Biophys Res Commun 236(2):431–433. 10.1006/bbrc.1997.6973.9240455
Diliberto JJ, Burgin DE, Birnbaum LS. 1999. Effects of CYP1A2 on disposition of 2,3,7, 8-tetrachlorodibenzo-p-dioxin, 2,3,4,7,8-pentachlorodibenzofuran, and 2,2',4,4',5,5'-hexachlorobiphenyl in CYP1A2 knockout and parental (C57BL/6N and 129/Sv) strains of mice. Toxicol Appl Pharmacol 159(1):52–64. 10.1006/taap.1999.8720.10448125
Diliberto JJ, Akubue PI, Luebke RW, 1995. Dose-response relationships of tissue distribution and induction of Cyp1A1 and Cyp1A2 enzymatic activities following acute exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) in mice. Toxicol Appl Pharmacol 130(2):197–208. 10.1006/taap.1995.1025.7871533
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 6, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
Doyle EA, Fries GF. 1986. Induction of aryl hydrocarbon hydroxylase by chlorinated dibenzofurans in rats. Chemosphere 15(9-12):1745–1748. 10.1016/0045-6535(86)90462-5.
Draper WM, Park H, Stephens RD. 1991. Determination of OCDD and OCDF in soils and biological samples by GC-ECD. In: Friedman D, ed. Waste testing and quality assurance. Vol. 3. West Conshohocken, PA: ASTM International, 87–105.
Drechsler WD. 1986. Destruction of PCDD/PCDF by non-thermal methods. Chemosphere 15(9–12):1529–1534. 10.1016/0045-6535(86)90433-9.
Dusza HM, Manz KE, Pennell KD, 2022. Identification of known and novel nonpolar endocrine disruptors in human amniotic fluid. Environ Int 158:106904. 10.1016/j.envint.2021.106904.34607043
Eadon G, Kaminsky L, Silkworth J, 1986. Calculation of 2,3,7,8-TCDD equivalent concentrations of complex environmental contaminant mixtures. Environ Health Perspect 70:221–227. 10.1289/ehp.8670221.3830107
Edgerton SA, Czuczwa JM, Rench JD, 1989. Ambient air concentrations of polychlorinated dibenzo-p-dioxins and dibenzofurans in Ohio: Sources and health risk assessment. Chemosphere 18(9–10):1713–1730. 10.1016/0045-6535(89)90455-4.
Eitzer BD, Hites RA. 1988. Vapor pressures of chlorinated dioxins and dibenzofurans. Environ Sci Technol 22(11):1362–1364. 10.1021/es00176a018.
Eitzer BD, Hites RA. 1989a. Atmospheric transport and deposition of polychlorinated dibenzo-p-dioxins and dibenzofurans. Environ Sci Technol 23(11):1396–1401. 10.1021/es00069a011.
Eitzer BD, Hites RA. 1989b. Polychlorinated dibenzo-p-dioxins and dibenzofurans in the ambient atmosphere of Bloomington, Indiana. Environ Sci Technol 23(11):1389–1395. 10.1021/es00069a010.
Elliott JE, Butler RW, Norstrom RJ, 1989. Environmental contaminants and reproductive success of great blue herons Ardea herodias in British Columbia, 1986–1987. Environ Pollut 59(2):91–114. 10.1016/0269-7491(89)90099-7.15092407
EPA. 1985. Health assessment document for polychlorinated dibenzo-p-dioxins. U.S. Environmental Protection Agency. EPA600884014F. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001CBN.txt. April 24, 2020.
EPA. 1989a. NHATS broad scan analysis: population estimates from fiscal year 1982 specimens. Washington, DC: U.S. Environmental Protection Agency. EPA560590001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91012GAH.txt. June 17, 2020.
EPA. 1989b. Interim procedures for estimating risks associated with exposure to mixtures of chlorinated dibenzo-p-dioxins and dibenzofurans (CDDs and CDFs) and 1989 update. Washington, DC: U.S. Environmental Protection Agency. EPA625389016. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=300047JJ.txt. June 17, 2020.
EPA. 1990a. Waste analysis and identification and listing of hazardous waste. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264–341 and 40 CFR 261, App VII.
EPA. 1990b. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency. EPA600890966A. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001JXM.txt. June 19, 2020.
EPA. 1991. Proposed regulation of land application of sludge from pulp and paper mills using chlorine and chlorine derivative bleaching processes. U.S. Environmental Protection Agency. Fed Regist 56(91):21802–21803. https://www.loc.gov/item/fr056091/. June 17, 2020.
EPA. 1994. Method 1613: Tetra- through octa-chlorinated dioxins and furans by isotope dilution HRGC/HRMS. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-08/documents/method_1613b_1994.pdf. April 22, 2020.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://19january2017snapshot.epa.gov/sites/production/files/documents/ry2004rfi.pdf. June 19, 2020.
EPA. 2007a. 2001 National sewage sludge survey report. Washington, DC: U.S. Environmental Protection Agency. EPA822R07006. https://www.epa.gov/biosolids/sewage-sludge-surveys. April 23, 2020.
EPA. 2007b. Method 8280B: Polychlorinated dibenzo-p-dioxins (PCDDs) and polychlorinated dibenzofurans (PCDFs) by high-resolution gas chromatography/low-resolution mass spectrometry (HRGC/LRMS). U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-12/documents/8280b_0.pdf. April 23, 2020.
EPA. 2009. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2010. Final report bioavailability of dioxins and dioxin-like compounds in soil. Las Vegas, NV: U.S. Environmental Protection Agency. https://semspub.epa.gov/work/HQ/174554.pdf. September 14, 2022.
EPA. 2012. BCF-BAF output. Estimation Programs Interface Suite^™^ for Microsoft^®^ Windows, v 4.11. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/tsca-screeningtools/epi-suitetm-estimation-program-interface. April 20, 2020.
EPA. 2013. National Dioxin Air Monitoring Network (NDAMN): Report of the results of atmospheric measurements of polychlorinated dibenzo-p-dioxins (PCDDs), polychlorinated dibenzofurans (PCDFs), and dioxin-like polychlorinated biphenyls (PCBs) in rural and remote areas of the United States from June 1998 through November 2004. Washington, DC: U.S. Environmental Protection Agency. EPA600R13183F. PB2014104547. http://ofmpub.epa.gov/eims/eimscomm.getfile?p_download_id=515193. April 20, 2020.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
Erickson MD. 1989. PCDFs and related compounds produced from PCB fires - A review. Chemosphere 19(1–6):161–165. 10.1016/0045-6535(89)90305-6.
Everett CJ, Thompson OM. 2014. Dioxins, furans and dioxin-like PCBs in human blood: causes or consequences of diabetic nephropathy? Environ Res 132:126–131. 10.1016/j.envres.2014.03.043.24769561
Everett CJ, Thompson OM. 2016. Association of dioxins, furans and dioxin-like PCBs in human blood with nephropathy among US teens and young adults. Rev Environ Health 31(2):195–201. 10.1515/reveh-2015-0031.26982604
Fahrig R, Nilsson C, Rappe C. 1978. Genetic activity of chlorophenols and chlorophenol impurities. Environmental Science and Research 12:325–338. 10.1007/978-1-4615-8948-8_28.
Farrell K, Safe L, Safe S. 1987. Synthesis and aryl hydrocarbon receptor binding properties of radiolabeled polychlorinated dibenzofuran congeners. Arch Biochem Biophys 259(1):185–195. 10.1016/0003-9861(87)90485-1.2825595
FDA. 2007. Dioxin analysis results/exposure estimates. U.S. Food and Drug Administration. https://www.fda.gov/food/chemicals/dioxin-analysis-resultsexposure-estimates. April 23, 2020.
FDA. 2022. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. January 24, 2022.
Finley B, Fehling K, Warmerdam J, 2009. Oral bioavailability of polychlorinated dibenzo-p-dioxins/dibenzofurans in industrial soils. Hum Ecol Risk Assess 15(6):1146–1167. 10.1080/10807030903304765.
Fishbein L. 1992. Exposure from occupational versus other sources. Scand J Work Environ Health 18(Suppl 1):5–16.
Flesch-Janys D, Becher H, Gurn P, 1996. Elimination of polychlorinated dibenzo-p-dioxins and dibenzofurans in occupationally exposed persons. J Toxicol Environ Health 47(4):363–378. 10.1080/009841096161708.8600289
Fletcher N, Wahlstrom D, Lundberg R, 2005. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) alters the mRNA expression of critical genes associated with cholesterol metabolism, bile acid biosynthesis, and bile transport in rat liver: a microarray study. Toxicol Appl Pharmacol 207(1):1–24. 10.1016/j.taap.2004.12.003.
Frank APCG Schrap SM. 1990. Bioaccumulation of some polychlorinated dibenzo-p-dioxins and octachlorodibenzofuran in the guppy (Poecilia reticulata). Chemosphere 20(5):495–512. 10.1016/0045-6535(90)90107-5.
Fricker C, Hardy JK. 1990. Characterization of commercially available coffee filter papers. J Environ Sci Health A 25(8):927–936. 10.1080/10934529009375609.
Friesen KJ, Vilk J, Muir DC G. 1990. Aqueous solubilities of selected 2,3,7,8-substituted polychlorinated dibenzofurans (PCDFs). Chemosphere 20(1–2):27–32. 10.1016/0045-6535(90)90084-7.
Frommberger R. 1991. Cork products: a potential source of polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans. Chemosphere 23(2):133–139. 10.1016/0045-6535(91)90102-j.
Fu YA. 1984. Ocular manifestation of polychlorinated biphenyls intoxication. Am J Ind Med 5(1–2):127–132.6422743
Fukushi JI, Tsushima H, Matsumoto Y, 2019. Influence of dioxin-related compounds on physical function in Yusho incident victims. Heliyon 5(10):e02702. 10.1016/j.heliyon.2019.e02702.31687523
Funatsu I, Yamashita F, Yoshikane T, 1971. [A chlorobiphenyl induced fetopathy]. Fukuoka Igaku Zasshi 62:139–149. (Japanese)
Fürst P, Fürst C, Groebel W. 1990. Levels of PCDDs and PCDFs in food-stuffs from the Federal Republic of Germany. Chemosphere 20(7–9):787–792. 10.1016/0045-6535(90)90183-t.
Fürst P, Fürst C, Wilmers K. 1992. PCDDs and PCDFs in human milk-statistical evaluation of a 6-years survey. Chemosphere 25(7–10):1029–1038. 10.1016/0045-6535(92)90103-x.
Fürst P, Krüger C, Meemken H, 1989. PCDD and PCDF levels in human milk - dependence on the period of lactation. Chemosphere 18:439–444.
Garå A, Andersson K, Nilsson C, 1981. Synthesis of halogenated diphenyl ethers and dibenzofurans - A discussion of specific isomers available. Chemosphere 10(4):365–390. 10.1016/0045-6535(81)90233-2.
Gardner AM, White KD. 1990. Polychlorinated dibenzofurans in the edible portion of selected fish. Chemosphere 21(1-2):215–222. 10.1016/0045-6535(90)90393-8.
Garner AJ, Pagano JJ. 2019. Trends of polychlorinated dioxins, polychlorinated furans, and dioxin-like polychlorinated biphenyls in Chinook and Coho salmonid eggs from a Great Lakes tributary. Environ Pollut 247:1039–1045. 10.1016/j.envpol.2019.01.117.30823332
Geyer HJ, Scheunert I, Korte F. 1987. Correlation between the bioconcentration potential of organic environmental chemicals in humans and their n-octanol/water partition coefficients. Chemosphere 16(1):239–252. 10.1016/0045-6535(87)90128-7.
Gibbs J, Hansen M, Ferrario J. 2003. Ambient air sampling for dioxins, furans and coplanar PCBs in an urban industrialized corridor in Calcasieu Parish, Louisiana. Organohalogen Compounds 61:514–517. http://dioxin20xx.org/wp-content/uploads/pdfs/2003/03-269.pdf. April 23, 2020.
Gladen BC, Rogan WJ, Ragan NB, 1988. Urinary porphyrins in children exposed transplacentally to polyhalogenated aromatics in Taiwan. Arch Environ Health 43(1):54–58. 10.1080/00039896.1988.9934374.3128188
Gladen BC, Taylor JS, Wu YC, 1990. Dermatological findings in children exposed transplacentally to heat-degraded polychlorinated biphenyls in Taiwan. Br J Dermatol 122(6):799–808. 10.1111/j.1365-2133.1990.tb06269.x.2142435
Glasser H, Chang DP, Hickman DC. 1991. An analysis of biomedical waste incineration. J Air Waste Manage Assoc 41(9):1180–1188. 10.1080/10473289.1991.10466913.1756039
Glidden RM, Brown PJ, Sittig RA, 1990. Determination of 2,3,7,8-tetrachlorodibenzo-p-dioxin and 2,3,7,8-tetrachlorodibenzofuran in cow's milk. Chemosphere 20(10–12):1619–1624. 10.1016/0045-6535(90)90321-j.
Goldfarb TD, Harrad SJ. 1991. Consideration of the environmental impact of the volatilization of PCDDs and PCDFs. Chemosphere 23(11–12):1669–1674. 10.1016/0045-6535(91)90015-6.
Goldstein JA, Safe S. 1989. Mechanism of action and structure-activity relationships for the chlorinated dibenzo-p-dioxins and related compounds. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, naphthalenes, dibenzodioxins and related compounds. 2^nd^ ed. New York, NY: Elsevier, 239–293.
Goldstein JA, Hass JR, Linko P, 1978. 2,3,7,8-Tetrachlorodibenzofuran in a commercially available 99% pure polychlorinated biphenyl isomer identified as the inducer of hepatic cytochrome P-448 and aryl hydrocarbon hydroxylase in the rat. Drug Metab Dispos 6(3):258–264.26546
Golor G, Yamashita K, McLachlan MS, 1993. Comparison of the kinetics of chlorinated and brominated dioxins and furans in the rat. Organohalogen Compounds 13:203–206. http://dioxin20xx.org/wp-content/uploads/pdfs/1993/93-114.pdf. October 4, 2019.
González N, Domingo JL. 2021. Polychlorinated dibenzo-p-dioxins and dibenzofurans (PCDD/Fs) in food and human dietary intake: An update of the scientific literature. Food Chem Toxicol 157:112585. 10.1016/j.fct.2021.112585.34571053
Gorski T. 1981. Presence of polychlorinated dibenzo-p-dioxins in latex nipples. Bull Environ Contam Toxicol 27(1):68–71. 10.1007/bf01610988.7296039
Graham M, Hileman FD, Orth RG, 1986. Chlorocarbons in adipose tissue from a Missouri population. Chemosphere 15(9–12):1595–1600. 10.1016/0045-6535(86)90442-x.
Gray AP, Dipinto VM, Solomon IJ. 1976. Synthesis of specific polychlorinated dibenzofurans. J Org Chem 41(14):2428–2434. 10.1021/jo00876a016.
Groce DF, Alley CC, Patterson DG. 1989. Synthesis of tetrachloro-, pentachloro-, and hexachlorodibenzofurans from the pyrolysis of polychlorinated biphenyls. Chemosphere 19(1–6):225–232. 10.1016/0045-6535(89)90316-0.
Guo YL, Lin CJ, Yao WJ, 1994a. Musculoskeletal changes in children prenatally exposed to polychlorinated biphenyls and related compounds (Yu-Cheng children). J Toxicol Environ Health 41(1):83–93. 10.1080/15287399409531828.8277528
Guo YL, Chen YC, Yu ML, 1994b. Early development of Yu-Cheng children born seven to twelve years after the Taiwan PCB outbreak. Chemosphere 29(9–11):2395–2404.7850388
Guo YL, Lai TJ, Chen SJ, 1995. Gender-related decrease in Raven's progressive matrices scores in children prenatally exposed to polychlorinated biphenyls and related contaminants. Bull Environ Contam Toxicol 55(1):8–13. 10.1007/bf00212382.7663094
Guo YL, Yu ML, Hsu CC, 1999. Chloracne, goiter, arthritis, and anemia after polychlorinated biphenyl poisoning: 14-year follow-Up of the Taiwan Yucheng cohort. Environ Health Perspect 107(9):715–719. 10.1289/ehp.99107715.10464071
Guo YL, Hsu PC, Hsu CC, 2000. Semen quality after prenatal exposure to polychlorinated biphenyls and dibenzofurans. Lancet 356(9237):1240–1241. 10.1016/S0140-6736(00)02792-6.11072947
Hagenmaier H, Berchtold A. 1986. Analysis of waste from production of Na-pentachlorophenolate for polychlorinated dibenzodioxins (PCDD) and dibenzofurans (PCDF). Chemosphere 15(9–12):1991–1994. 10.1016/0045-6535(86)90499-6.
Hagenmaier H, Brunner H. 1987. Isomerspecific analysis of pentachlorophenol and sodium pentachlorophenate for 2,3,7,8-substituted PCDD and PCDF at sub-ppb levels. Chemosphere 16(8–9):1759–1764. 10.1016/0045-6535(87)90164-0.
Hagenmaier H, She J, Lindig C. 1992. Persistence of polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans in contaminated soil at Maulach and Rastatt in Southwest Germany. Chemosphere 25(7–10):1449–1456. 10.1016/0045-6535(92)90168-q.
Hagenmaier H, Brunner H, Haag R, 1987. Copper-catalyzed dechlorination/hydrogenation of polychlorinated dibenzo-p-dioxins, polychlorinated dibenzofurans, and other chlorinated aromatic compounds. Environ Sci Technol 21(11):1085–1088. 10.1021/es00164a007.
Hagenmaier H, Wiesmuller T, Golor G, 1990. Transfer of various polychlorinated dibenzo-p-dioxins and dibenzofurans (PCDDs and PCDFs) via placenta and through milk in a marmoset monkey. Arch Toxicol 64(8):601–615. 10.1007/BF01974688.2128593
Hagenmaier H, Horch K, Fahlenkamp H, 1991. Destruction of PCDD and PCDF in refuse incineration plants by primary and secondary measures. Chemosphere 23(8–10):1429–1437. 10.1016/0045-6535(91)90167-c.
Hahn JL, Von Dem Fange HP, Westerman G. 1989. A comparison of ambient and workplace dioxin levels from testing in and around modern resource recovery facilities with predicted ground level concentrations of dioxins from stack emission testing with corresponding workplace health risks. Chemosphere 19(1–6):629–636. 10.1016/0045-6535(89)90382-2.
Hardell L, Lindstrom G, Liljegren G, 1996. Increased concentrations of octachlorodibenzo-p-dioxin in cases with breast cancer - results from a case-control study. Eur J Cancer Prev 5(5):351–357. 10.1097/00008469-199610000-00007.8972254
Hardell L, Lindstrom G, van Bavel B, 2001. Adipose tissue concentrations of dioxins and dibenzofurans, titers of antibodies to Epstein-Barr virus early antigen and the risk for non-Hodgkin lymphoma. Environ Res 87(2):99–107. 10.1006/enrs.2001.4295.11683593
Hardell L, Fredrikson M, Eriksson M, 1995. Adipose tissue concentrations of dioxins and dibenzofurans in patients with malignant lymphoproliferative diseases and in patients without a malignant disease. Eur J Cancer Prev 4(3):225–229.7647690
Harper N, Connor K, Safe S. 1993. Immunotoxic potencies of polychlorinated biphenyl (PCB), dibenzofuran (PCDF) and dibenzo-p-dioxin (PCDD) congeners in C57BL/6 and DBA/2 mice. Toxicology 80(2–3):217–227. 10.1016/0300-483x(93)90183-s.8328002
Harrad SJ, Fernandes AR, Creaser CS, 1991a. Domestic coal combustion as a source of PCDDs and PCDFs in the British environment. Chemosphere 23(3):255–261. 10.1016/0045-6535(91)90181-c.
Harrad SJ, Malloy TA, Khan MA, 1991b. Levels and sources of PCDDs, PCDFs, chlorophenols (CPs) and chlorobenzenes (CBzs) in composts from a municipal yard waste composting facility. Chemosphere 23(2):181–191. 10.1016/0045-6535(91)90105-m.
Hassoun EA. 1987. In vivo and in vitro interactions of TCDD and other ligands of the Ah-receptor: effect on embryonic and fetal tissues. Arch Toxicol 61(2):145–149. 10.1007/bf00661373.2830866
Hassoun E, d'Argy R, Dencker L, 1984. Teratogenicity of 2,3,7,8-tetrachlorodibenzofuran in BXD recombinant inbred strains. Toxicol Lett 23(1):37–42. 10.1016/0378-4274(84)90007-9.6485016
Hassoun EA, Li F, Abushaban A, 2000. The relative abilities of TCDD and its congeners to induce oxidative stress in the hepatic and brain tissues of rats after subchronic exposure. Toxicology 145(2–3):103–113. 10.1016/s0300-483x(99)00221-8.10771135
Hassoun EA, Wang H, Abushaban A, 2002. Induction of oxidative stress in the tissues of rats after chronic exposure to TCDD, 2,3,4,7,8-pentachlorodibenzofuran, and 3,3',4,4',5-pentachlorobiphenyl. J Toxicol Environ Health 65(12):825–842. 10.1080/00984100290071054.
Hattemer-Frey HA, Travis CC. 1989. Comparison of human exposure to dioxin from municipal waste incineration and background environmental contamination. Chemosphere 18(1–6):643–649. 10.1016/0045-6535(89)90177-x.
Haws LC, Su SH, Harris M, 2006. Development of a refined database of mammalian relative potency estimates for dioxin-like compounds. Toxicol Sci 89(1):4–30. 10.1093/toxsci/kfi294.16120753
Hayabuchi H, Yoshimura T, Kuratsune M. 1979. Consumption of toxic rice oil by 'Yusho' patients and its relation to the clinical response and latent period. Food Cosmet Toxicol 17(5):455–461. 10.1016/0015-6264(79)90004-x.118100
Hayward DG, Charles JM, Voss de Bettancourt C, 1989. PCDD and PCDF in breast milk as correlated with fish consumption in Southern California. Chemosphere 18(1–6):455–468. 10.1016/0045-6535(89)90155-0.
Hayward DG, Petreas MX, Goldman LR, 1991. Assessing the risks from 2,3,7,8 TCDD and TCDF in milk packaged in paper. Chemosphere 23(11–12):1551–1559. 10.1016/0045-6535(91)90002-u.
Hebert CD, Harris MW, Elwell MR, 1990. Relative toxicity and tumor-promoting ability of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD), 2,3,4,7,8-pentachlorodibenzofuran (PCDF), and 1,2,3,4,7,8-hexachlorodibenzofuran (HCDF) in hairless mice. Toxicol Appl Pharmacol 102(2):362–377. 10.1016/0041-008x(90)90033-q.2300974
Heindl A, Hutzinger O. 1989. Search for industrial sources of PCDD/PCDFs: IV. Phthalocyanine dyes. Chemosphere 18(1–6):1207–1211. 10.1016/0045-6535(89)90256-7.
Hensley AR, Scott A, Rosenfeld PE, 2007. Attic dust and human blood samples collected near a former wood treatment facility. Environ Res 105(2):194–199. 10.1016/j.envres.2007.03.011.17517389
Hernández CS, Pardo O, Corpas-Burgos F, 2020. Biomonitoring of polychlorinated dibenzo-p-dioxins (PCDDs), polychlorinated dibenzofurans (PCDFs) and dioxin-like polychlorinated biphenyls (dl-PCBs) in human milk: Exposure and risk assessment for lactating mothers and breastfed children from Spain. Sci Total Environ 744:140710. 10.1016/j.scitotenv.2020.140710.32712415
Hites RA. 2002. Environmental behavior of chlorinated dioxins and furans. Acc Chem Res 23(6):194–201. 10.1021/ar00174a005.
Hodson PV, McWhirter M, Ralph K, 1992. Effects of bleached kraft mill effluent on fish in the St. Maurice River, Quebec. Environ Toxicol Chem 11(11):1635–1651.
Holcomb M, Yao C, Safe S. 1988. Biologic and toxic effects of polychlorinated dibenzo-p-dioxin and dibenzofuran congeners in the guinea pig. Quantitative structure-activity relationships. Biochem Pharmacol 37(8):1535–1539. 10.1016/0006-2952(88)90015-9.3358783
Hood A, Klaassen CD. 2000. Effects of microsomal enzyme inducers on outer-ring deiodinase activity toward thyroid hormones in various rat tissues. Toxicol Appl Pharmacol 163(3):240–248. 10.1006/taap.1999.8883.10702363
Hood A, Allen ML, Liu Y, 2003. Induction of T4 UDP-GT activity, serum thyroid stimulating hormone, and thyroid follicular cell proliferation in mice treated with microsomal enzyme inducers. Toxicol Appl Pharmacol 188(1):6–13. 10.1016/s0041-008x(02)00071-6.12668117
Hryhorczuk DO, Orris P, Kominsky JŔ, 1986. PCB, PCDF, and PCDD exposure following a transformer fire: Chicago. Chemosphere 15(9–12):1297–1303. 10.1016/0045-6535(86)90404-2.
Hsu MM L, Chang JC, Hsu CC. 1993. Nail changes in PCB poisoning. Organohalogen Compounds 13:251–252. http://dioxin20xx.org/wp-content/uploads/pdfs/1993/93-154.pdf. April 23, 2020.
Hsu ST, Ma CI, Hsu SK, 1984. Discovery and epidemiology of PCB poisoning in Taiwan. Am J Ind Med 5(1–2):71–79.6230931
Hsu ST, Ma CI, Hsu SK, 1985. Discovery and epidemiology of PCB poisoning in Taiwan: a four-year followup. Environ Health Perspect 59:5–10. 10.1289/ehp.59-1568088.3921364
Hsu PC, Lai TJ, Guo NW, 2005. Serum hormones in boys prenatally exposed to polychlorinated biphenyls and dibenzofurans. J Toxicol Environ Health A 68(17–18):1447–1456. 10.1080/15287390590967360.16076757
Hsu PC, Li MC, Lee YC, 2016. Polychlorinated biphenyls and dibenzofurans increased abnormal sperm morphology without alterations in aneuploidy: The Yucheng study. Chemosphere 165:294–297. 10.1016/j.chemosphere.2016.09.035.27662390
Hu Z, Li J, Li B, 2019. Annual changes in concentrations and health risks of PCDD/Fs, DL-PCBs and organochlorine pesticides in ambient air based on the Global Monitoring Plan in São Paulo. Environ Pollut 255(Pt 2):113310. 10.1016/j.envpol.2019.113310.31600699
Huisman M, Eerenstein SE, Koopman-Esseboom C, 1995. Perinatal exposure to polychlorinated biphenyls and dioxins through dietary intake. Chemosphere 31(10):4273–4287. 10.1016/0045-6535(95)00296-k.8520928
Humppi T. 1986. Synthesis of polychlorinated phenoxyphenols (PCPP), phenoxyanisoles (PCPA), dibenzo-p-dioxins (PCDD), dibenzofurans (PCDF) and diphenyl ethers (PCDE). Chemosphere 15(9–12):2003–2006. 10.1016/0045-6535(86)90502-3.
Hunt GT, Maisel BE. 1990. Atmospheric PCDDs/PCDFs in wintertime in a northeastern U.S. urban coastal environment. Chemosphere 20(10–12):1455–1462. 10.1016/0045-6535(90)90297-7.
Hutzinger O, Fiedler H. 1989. Sources and emissions of PCDD/PCDF. Chemosphere 18(1–6):23–32. 10.1016/0045-6535(89)90102-1.
Hutzinger O, Safe S, Wentzell BR, 1973. Photochemical degradation of di- and octachlorodibenzofuran. Environ Health Perspect 5:267–271. 10.1289/ehp.7305267.4752909
Hutzinger O, Choudhry GG, Chittim BG, 1985a. Formation of polychlorinated dibenzofurans and dioxins during combustion, electrical equipment fires and PCB incineration. Environ Health Perspect 60:3–9. 10.1289/ehp.85603.
Hutzinger O, Blumich MJ, Berg MD V, 1985b. Sources and fate of PCDDs and PCDFs: An overview. Chemosphere 14:581–560.
Iamiceli AL, Abate V, Abballe A, 2021. Biomonitoring of the adult population living near the waste incinerator of Turin: Serum concentrations of PCDDs, PCDFs, and PCBs after three years from the plant start-up. Chemosphere 272:129882. 10.1016/j.chemosphere.2021.129882.33588142
IARC. 1997. Polychlorinated dibenzo-para-dioxins and polychlorinated dibenzofurans. IARC monographs on the evaluation of carcinogenic risks to humans. Volume 69. Lyon, France: International Agency for Research on Cancer. https://publications.iarc.fr/87. June 17, 2020.
IARC. 2012. 2,3,7,8-Tetrachlorodibenzopara-dioxin, 2,3,4,7,8-pentachlorodibenzofuran, and 3,3′,4,4′,5-pentachlorobiphenyl. IARC monographs on the evaluation of carcinogenic risks to humans. Volume 110F. Chemical agents and related occupations. Lyon, France: International Agency for Research on Cancer. 339–378. http://publications.iarc.fr/123. April 20, 2020.
Iida T, Hirakawa H, Matsueda T, 1999a. Polychlorinated dibenzo-p-dioxins and related compounds: correlations of levels in human tissues and in blood. Chemosphere 38(12):2767–2774. 10.1016/s0045-6535(98)00478-0.10214714
Iida T, Hirakawa H, Matsueda T, 1999b. Recent trend of polychlorinated dibenzo-p-dioxins and their related compounds in the blood and sebum of Yusho and Yu-Cheng patients. Chemosphere 38(5):981–993.10028655
Iida T, Todaka T, Hirakawa H, 2007. Concentration and distribution of dioxins and related compounds in human tissues. Chemosphere 67(9):S263–S271. 10.1016/j.chemosphere.2006.05.107.17215028
Imamura T, Kanagawa Y, Matsumoto S, 2007. Relationship between clinical features and blood levels of pentachlorodibenzofuran in patients with Yusho. Environ Toxicol 22(2):124–131. 10.1002/tox.20251.17366567
Imamura T, Matsumoto S, Akahane M, 2009. Cutaneous symptoms such as acneform eruption and pigmentation are closely associated with blood levels of 2,3,4,7,8-penta-chlorodibenzofurans in Yusho patients, using data mining analysis. BMC Res Notes 2:27. 10.1186/1756-0500-2-27.19284523
Ioannou YM, Birnbaum LS, Matthews HB. 1983. Toxicity and distribution of 2,3,7,8-tetrachlorodibenzofuran in male guinea pigs. J Toxicol Environ Health 12(4–6):541–553. 10.1080/15287398309530448.6668609
IRIS. 2022. Alphabetical index. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://iris.epa.gov/AtoZ/?list_type=alpha. September 12, 2022.
Iyer R, Aggarwal J, Iken B. 2016. A review of the Texas, USA San Jacinto Superfund site and the deposition of polychlorinated dibenzo-p-dioxins and dibenzofurans in the San Jacinto River and Houston Ship Channel. Environ Sci Pollut Res Int 23(23):23321–23338. 10.1007/s11356-016-7501-8.27662860
Jackson JA, Diliberto JJ, Birnbaum LS. 1993. Estimation of octanol-water partition coefficients and correlation with dermal absorption for several polyhalogenated aromatic hydrocarbons. Fundam Appl Toxicol 21(3):334–344.8258387
Jain RB. 2021. Trends in concentrations of selected dioxins and furans across various stages of kidney function for US adults. Environ Sci Pollut Res Int 28(32):43763–43776. 10.1007/s11356-021-13844-3.33840024
Jarman WM, Burns SA, Chang RR, 1993. Determination of PCDDS, PCDFs, and PCBs in California peregrine falcons (Falco peregrinus) and their eggs. Environ Toxicol Chem 12(1):105–114. 10.1002/etc.5620120112.
Jay K, Stieglitz L. 1991. On the mechanism of formation of polychlorinated aromatic compounds with copper(II) chloride. Chemosphere 22(11):987–996. 10.1016/0045-6535(91)90299-s.
Jensen AA. 1987. Polychlorobiphenyls (PCBs), polychlorodibenzo-p-dioxins (PCDDs) and polychlorodibenzofurans (PCDFs) in human milk, blood and adipose tissue. Sci Total Environ 64(3):259–293. 10.1016/0048-9697(87)90250-6.3110947
Jödicke B, Enge M, Helge H, 1992. Fecal excretion of PCDDs/PCDFs in a 3-month-old breast-fed infant. Chemosphere 25(7–10):1061–1065.
Johnson KL, Cummings AM, Birnbaum LS. 1997. Promotion of endometriosis in mice by polychlorinated dibenzo-p-dioxins, dibenzofurans, and biphenyls. Environ Health Perspect 105(7):750–755. 10.1289/ehp.97105750.9294722
Johnson CW, Williams WC, Copeland CB, 2000. Sensitivity of the SRBC PFC assay versus ELISA for detection of immunosuppression by TCDD and TCDD-like congeners. Toxicology 156(1):1–11. 10.1016/s0300-483x(00)00330-9.11162871
Johnson KJ, Passage J, Lin H, 2020. Dioxin male rat reproductive toxicity mode of action and relative potency of 2,3,7,8-tetrachlorodibenzo-p-dioxin and 2,3,7,8-tetrachlorodibenzofuran characterized by fetal pituitary and testis transcriptome profiling. Reprod Toxicol 93:146–162. 10.1016/j.reprotox.2020.02.008.32109520
Jones PD, Giesy JP, Newsted JL, 1993. 2,3,7,8-Tetrachlorodibenzo-p-dioxin equivalents in tissues of birds at Green Bay, Wisconsin, USA. Arch Environ Contam Toxicol 24(3):345–354. 10.1007/bf01128732.
Jordan RJ. 1987. The feasibility of wet scrubbing for treating waste-to-energy flue gas. J Air Pollut Control Assoc 37(4):422–430. 10.1080/08940630.1987.10466237.
Kamio Y, Gunge Y, Koike Y, 2020. Insight into innate immune response in "Yusho": The impact of natural killer cell and regulatory T cell on inflammatory prone diathesis of Yusho patients. Environ Res 185:109415. 10.1016/j.envres.2020.109415.32240844
Kanagawa Y, Matsumoto S, Koike S, 2008. Association of clinical findings in Yusho patients with serum concentrations of polychlorinated biphenyls, polychlorinated quarterphenyls and 2,3,4,7,8-pentachlorodibenzofuran more than 30 years after the poisoning event. Environ Health 7:47. 10.1186/1476-069X-7-47.18831733
Kang HK, Watanabe KK, Breen J, 1991. Dioxins and dibenzofurans in adipose tissue of US Vietnam veterans and controls. Am J Public Health 81(3):344–349. 10.2105/ajph.81.3.344.1994743
Kang Y, Yang J, Ahn J, 2017. Simultaneous determination of PCDD/Fs, dioxin-like PCBs and indicator PCBs in food. Organohalogen Compounds 79:387–393. https://dioxin20xx.org/wp-content/uploads/pdfs/2017/9884.pdf. September 15, 2022.
Kashimoto T, Miyata H. 1986. Differences between Yusho and other kinds of poisoning involving only PCBs. In: Waid JS, ed. PCBs and the environment. Vol. 3. Boca Raton, FL: CRC Press, 1–26.
Kashimoto T, Miyata H, Fukushima S, 1985. PCBs, PCQs and PCDFs in blood of Yusho and Yu-Cheng patients. Environ Health Perspect 59:73–78. 10.1289/ehp.59-1568089.3921368
Kawano S, Hiraga K. 1978. Polychlorinated dibenzofurans - potent inducers of rat hepatic drug-metabolizing enzymes. Jpn J Pharmacol 28(2):305–315. 10.1254/jjp.28.305.99592
Keenan RE, Sullivan MJ. 1989. Assessing potential health risks of dioxin in paper products. Environ Sci Technol 23(6):643–644. 10.1021/es00064a002.
Kelada FS. 1990. Occupational intake by dermal exposure to polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans in pulp mill industry. Am Ind Hyg Assoc J 51(9):519–521. 10.1080/15298669091370022.2220570
Kerger BD, Leung HW, Scott PK, 2007a. An adaptable internal dose model for risk assessment of dietary and soil dioxin exposures in young children. Toxicol Sci 100(1):224–237. 10.1093/toxsci/kfm199.17682006
Kerger BD, Leung HW, Scott PK, 2007b. Refinements on the age-dependent half-life model for estimating child body burdens of polychlorodibenzodioxins and dibenzofurans. Chemosphere 67(9):S272–278. 10.1016/j.chemosphere.2006.05.108.17207842
Kerkvliet NI, Brauner JA, Matlock JP. 1985. Humoral immunotoxicity of polychlorinated diphenyl ethers, phenoxyphenols, dioxins and furans present as contaminants of technical grade pentachlorophenol. Toxicology 36(4):307–324. 10.1016/0300-483x(85)90033-2.4049436
Keys B, Piskorska-Pliszczynska J, Safe S. 1986. Polychlorinated dibenzofurans as 2,3,7,8-TCDD antagonists: in vitro inhibition of monooxygenase enzyme induction. Toxicol Lett 31(2):151–158. 10.1016/0378-4274(86)90009-3.3012826
Khairy MA, Lohmann R. 2020. Assessing benthic bioaccumulation of polychlorinated dioxins/furans and polychlorinated biphenyls in the lower Passaic River (NJ, USA) based on in situ passive sampling. Environ Toxicol Chem 39(6):1174–1185. 10.1002/etc.4716.32200571
Khairy MA, Noonan GO, Lohmann R. 2019. Uptake of hydrophobic organic compounds, including organochlorine pesticides, polybrominated diphenyl ethers, and perfluoroalkyl acids in fish and blue crabs of the lower Passaic River, New Jersey, USA. Environ Toxicol Chem 38(4):872–882. 10.1002/etc.4354.30614049
Khera KS. 1992. Extraembryonic tissue changes induced by 2,3,7,8-tetrachlorodibenzo-p-dioxin and 2,3,4,7,8-pentachlorodibenzofuran with a note on direction of maternal blood flow in the labyrinth of C57BL/6N mice. Teratology 45(6):611–627. 10.1002/tera.1420450606.1412054
Kitunen VH, Salkinoja-Salonen MS. 1989. Occurrence of PCDDs and PCDFs in pulp and board products. Chemosphere 19(1–6):721–726. 10.1016/0045-6535(89)90397-4.
Kitunen VH, Valo RJ, Salkinoja-Salonen MS. 1987. Contamination of soil around wood-preserving facilities by polychlorinated aromatic compounds. Environ Sci Technol 21(1):96–101. 10.1021/es00155a012.
Kjeller LO, Jones KC, Johnston AE, 1991. Increases in the polychlorinated dibenzo-p-dioxin and furan content of soils and vegetation since the 1840s. Environ Sci Technol 25(9):1619–1627. 10.1021/es00021a014.
Koester CJ, Hites RA. 1992. Photodegradation of polychlorinated dioxins and dibenzofurans adsorbed to fly ash. Environ Sci Technol 26(3):502–507. 10.1021/es00027a008.
Kominsky JR, Kwoka CD. 1989. Background concentrations of polychlorinated dibenzofurans (PCDFs) and polychlorinated dibenzo-p-dioxins (PCDDs) in office buildings in Boston, Massachusetts. Chemosphere 18(1–6):599–608. 10.1016/0045-6535(89)90172-0.
Kondo H, Tanio K, Nagaura Y, 2018. Sleep disorders among Yusho patients highly intoxicated with dioxin-related compounds: A 140-case series. Environ Res 166:261–268. 10.1016/j.envres.2018.05.033.29908457
Konishi K, Sasaki S, Kato S, 2009. Prenatal exposure to PCDDs/PCDFs and dioxin-like PCBs in relation to birth weight. Environ Res 109(7):906–913. 10.1016/j.envres.2009.07.010.19683226
Korner W, Golor G, Schulz T, 2002. Tissue concentrations and induction of a hepatic monooxygenase in male Wistar rats after repeated doses of defined polychlorinated dibenzo-p-dioxin and dibenzofuran (PCDDs and PCDFs) mixtures. Arch Toxicol 75(11–12):653–664. 10.1007/s002040100276.11876498
Körner W, Dawidowsky N, Hagenmaier H. 1993. Fecal excretion rates of PCDDs and PCDFs in two breast-fed infants. Chemosphere 27(1–3):157–162.
Koshioka M, Iizuka H, Kanazawa J, 2014. Photodegradation of octachlorodi-benzofuran in 1,4-dioxane under xenon lamp irradiation. Agric Biol Chem 51(3):949–952. 10.1080/00021369.1987.10868130.
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Krowke R. 1986. Studies on distribution and embryotoxicity of different PCDD and PCDF in mice and marmosets. Chemosphere 15(9–12):2011–2022. 10.1016/0045-6535(86)90504-7.
Kuehl DW, Haebler R, Potter C. 1991. Chemical residues in dolphins from the U.S. Atlantic coast including Atlantic bottlenose obtained during the 1987/88 mass mortality. Chemosphere 22(11):1071–1084. 10.1016/0045-6535(91)90308-z.
Kuehl DW, Cook PM, Batterman AR, 1987. Bioavailability of polychlorinated dibenzo-p-dioxins and dibenzofurans from contaminated Wisconsin River sediment to carp. Chemosphere 16(4):667–679. 10.1016/0045-6535(87)90003-8.
Kunita N, Kashimoto T, Miyata H, 1984. Causal agents of Yusho. Am J Ind Med 5(1–2):45–58.6422749
Kurachi M, Hashimoto S, Obata A, 2002. Identification of 2,3,7,8-tetrachlorodibenzo-p-dioxin-responsive genes in mouse liver by serial analysis of gene expression. Biochem Biophys Res Commun 292(2):368–377. 10.1006/bbrc.2002.6669.11906171
Kuratsune M. 1989. Yusho, with reference to Yu-Cheng. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalene, dibenzodioxins and related products. Vol. 4. 2^nd^ ed. Amsterdam: Elsevier Science Publishers, 381–400.
Kuratsune M, Nakamura Y, Ikeda M, 1987. Analysis of deaths seen among patients with Yusho. Chemosphere 16(8–9):2085–2088. 10.1016/0045-6535(87)90212-8.
Kuroiwa Y, Murai Y, Santa T. 1969. [Neurological and nerve conduction velocity studies on 23 patients with chlorobiphenyls poisoning]. Fukuoka Igaku Zasshi 60:462–463. (Japanese)
Kuroki H, Haraguchi K, Masuda Y. 1984. Synthesis of polychlorinated dibenzofuran isomers and their gas chromatographic profiles. Chemosphere 13(4):561–573. 10.1016/0045-6535(84)90151-6.
Kusuda M. 1971. [A study on the sexual functions of women suffering from rice-bran oil poisoning]. Sanka to Fujinka 38:1063–1072. (Japanese)
Kuwatsuka Y, Shimizu K, Akiyama Y, 2014. Yusho patients show increased serum IL-17, IL-23, IL-1β, and TNFα levels more than 40 years after accidental polychlorinated biphenyl poisoning. J Immunotoxicol 11(3):246–249. 10.3109/1547691X.2013.835890.24083809
LaKind JS, Hays SM, Aylward LL, 2009. Perspective on serum dioxin levels in the United States: an evaluation of the NHANES data. J Expo Sci Environ Epidemiol 19(4):435–441. 10.1038/jes.2008.63.18854873
Lan SJ, Yen YY, Yang CH, 1987. [A study on the birth weight of transplacental Yu-Cheng babies]. Gaoxiong Yi Xue Ke Xue Za Zhi 3(4):273–282. (Chinese)3132560
Lan SJ, Yen YY, Lan JL, 1990. Immunity of PCB transplacental Yu-Cheng children in Taiwan. Bull Environ Contam Toxicol 44(2):224–229. 10.1007/bf01700140.2108741
LeBel GL, Williams DT, Benoit FM. 1992. Chlorinated dibenzodioxins and dibenzofurans in consumer paper products. Chemosphere 25(11):1683–1690. 10.1016/0045-6535(92)90315-i.
LeBel GL, Williams DT, Benoit FM, 1990. Polychlorinated dibenzodioxins and dibenzofurans in human adipose tissue samples from five Ontario municipalities. Chemosphere 21(12):1465–1475. 10.1016/0045-6535(90)90052-u.
Leung HW, Kerger BD, Paustenbach DJ. 2006. Elimination half-lives of selected polychlorinated dibenzodioxins and dibenzofurans in breast-fed human infants. J Toxicol Environ Health 69(6):437–443. 10.1080/15287390500246886.
Leung HW, Kerger BD, Paustenbach D, 2005. Age- and concentration-dependent elimination half lives of chlorinated dibenzofurans in Yusho and Yucheng patients. Organohalogen Compounds 67:1589–1592. https://dioxin20xx.org/wp-content/uploads/pdfs/2005/05-471.pdf. September 15, 2022.
Leung HW, Kerger BD, Paustenbach DJ, 2007. Concentration and age-dependent elimination kinetics of polychlorinated dibenzofurans in Yucheng and Yusho patients. Toxicol Ind Health 23(8):493–501. 10.1177/0748233708089024.18669171
Li MC, Tsai PC, Chen PC, 2013. Mortality after exposure to polychlorinated biphenyls and dibenzofurans: 30 years after the "Yucheng accident". Environ Res 120:71–75. 10.1016/j.envres.2012.09.003.23026800
Li MC, Chen PC, Tsai PC, 2015a. Mortality after exposure to polychlorinated biphenyls and polychlorinated dibenzofurans: a meta-analysis of two highly exposed cohorts. Int J Cancer 137(6):1427–1432. 10.1002/ijc.29504.25754105
Li MC, Wu HP, Yang CY, 2015b. Gestational exposure to polychlorinated biphenyls and dibenzofurans induced asymmetric hearing loss: Yucheng children study. Environ Res 137:65–71. 10.1016/j.envres.2014.12.002.25490244
Li ZM, Hernandez-Moreno D, Main KM, 2018. Association of in utero persistent organic pollutant exposure with placental thyroid hormones. Endocrinology 159:3473–3481. 10.1210/en.2018-00542.30059991
Ligon WV, Dorn SB, May RJ, 1989. Chlorodibenzofuran and chlorodibenzo-p-dioxin levels in Chilean mummies dated to about 2800 years before the present. Environ Sci Technol 23(10):1286–1290. 10.1021/es00068a016.
Lin KC, Guo NW, Tsai PC, 2008. Neurocognitive changes among elderly exposed to PCBs/PCDFs in Taiwan. Environ Health Perspect 116(2):184–189. 10.1289/ehp.10134.18288316
Lin KC, Huang PC, Yeh PS, 2010. Comparing mini-mental state examination and attention and digit span in elderly exposed to polychlorinated biphenyls and polychlorinated dibenzofurans. Psychogeriatrics 10(4):191–197. 10.1111/j.1479-8301.2010.00341.x.21159054
Lindner G, Jenkins AC, McCormack J, 1990. Dioxins and furans in emissions from medical waste incinerators. Chemosphere 20(10–12):1793–1800. 10.1016/0045-6535(90)90344-s.
Lofroth G, Zebuhr Y. 1992. Polychlorinated dibenzo-p-dioxins (PCDDs) and dibenzofurans (PCDFs) in mainstream and sidestream cigarette smoke. Bull Environ Contam Toxicol 48(6):789–794. 10.1007/bf00201136.1568054
Lu YC, Wu YC. 1985. Clinical findings and immunological abnormalities in Yu-Cheng patients. Environ Health Perspect 59:17–29. 10.1289/ehp.59-1568085.3921359
Lu FJ, Chang KJ, Lin SC, 1980. [Studies on patients with polychlorinated biphenyls poisoning. Determination of urinary coproporphyrin, uroporphyrin, delta-aminolevulinic acid, and porphobilinogen (author's transl)]. Taiwan Yi Xue Hui Za Zhi 79(11):990–995. (Chinese)6788895
Lucier GW, Sunahara GI, Wong TK. 1990. Placental markers of human exposure to polychlorinated dibenzofurans and polychlorinated biphenyls: implications for risk assessment. IARC Sci Publ 104(104):55–62.
Lucier GW, Nelson KG, Everson RB, 1987. Placental markers of human exposure to polychlorinated biphenyls and polychlorinated dibenzofurans. Environ Health Perspect 76:79–87. 10.1289/ehp.877679.2834196
Lundgren K, Collman GW, Wang-Wuu S, 1988. Cytogenetic and chemical detection of human exposure to polyhalogenated aromatic hydrocarbons. Environ Mol Mutagen 11(1):1–11. 10.1002/em.2850110103.
Luster MI, Faith RE, Clark G. 1979a. Laboratory studies on the immune effects of halogenated aromatics. Ann N Y Acad Sci 320:473–486. 10.1111/j.1749-6632.1979.tb56628.x.287400
Luster MI, Faith RE, Lawson LD. 1979b. Effects of 2,3,7,8-tetrachlorodibenzofuran (TCDF) on the immune system in guinea pigs. Drug Chem Toxicol 2(1–2):49–60. 10.3109/01480547908993181.548255
Madsen C, Larsen JC. 1989. Relative toxicity of chlorinated dibenzo-p-dioxins, and dibenzofurans measured by thymus weight and liver enzyme induction in perinatally dosed rats, 2,3,7,8-TCDD, 2,3,4,7,8-PeCDF, 1,2,3,7,8-PeCDD. Chemosphere 18(1–6):955–966. 10.1016/0045-6535(89)90223-3.
Maisel BE, Hunt GT. 1990. Background concentrations of PCDDs/PCDFs in ambient air - A comparison of toxic equivalency factor (TEF) models. Chemosphere 20(7–9):771–778. 10.1016/0045-6535(90)90181-r.
Mäntykoski K, Paasivirta J, Mannila E. 1989. Combustion products of biosludge from pulp mill. Chemosphere 19(1–6):413–416. 10.1016/0045-6535(89)90344-5.
Marklund S, Rappe C, Tysklind M, 1987. Identification of polychlorinated dibenzofurans and dioxins in exhausts from cars run on leaded gasoline. Chemosphere 16(1):29–36. 10.1016/0045-6535(87)90105-6.
Marshall NB, Kerkvliet NI. 2010. Dioxin and immune regulation: emerging role of aryl hydrocarbon receptor in the generation of regulatory T cells. Ann N Y Acad Sci 1183:25–37. 10.1111/j.1749-6632.2009.05125.x.20146706
Martinez-Zamora MA, Mattioli L, Parera J, 2015. Increased levels of dioxin-like substances in adipose tissue in patients with deep infiltrating endometriosis. Hum Reprod 30(5):1059–1068. 10.1093/humrep/dev026.25743783
Maruyama W, Yoshida K, Tanaka T, 2002. Possible range of dioxin concentration in human tissues: simulation with a physiologically based model. J Toxicol Environ Health A 65(24):2053–2073. 10.1080/00984100290071829.12515586
Maruyama W, Yoshida K, Tanaka T, 2003. Simulation of dioxin accumulation in human tissues and analysis of reproductive risk. Chemosphere 53(4):301–313. 10.1016/S0045-6535(03)00015-8.12946389
Mason G, Sawyer T, Keys B, 1985. Polychlorinated dibenzofurans (PCDFs): Correlation between in vivo and in vitro structure-activity relationships. Toxicology 37(1–2):1–12. 10.1016/0300-483x(85)90108-8.3933143
Masuda Y. 2001. Fate of PCDF/PCB congeners and change of clinical symptoms in patients with Yusho PCB poisoning for 30 years. Chemosphere 43(4–7):925–930. 10.1016/s0045-6535(00)00452-5.11372885
Masuda Y, Yoshimura H. 1984. Polychlorinated biphenyls and dibenzofurans in patients with Yusho and their toxicological significance: a review. Am J Ind Med 5(1–2):31–44.6422748
Masuda Y, Kuroki H, Haraguchi K, 1985. PCB and PCDF congeners in the blood and tissues of Yusho and Yu-Cheng patients. Environ Health Perspect 59:53–58. 10.1289/ehp.59-1568081.3921365
Matsumoto S, Akahane M, Kanagawa Y, 2009. Variation in half-life of penta-chlorodibenzofuran (PeCDF) blood level among Yusho patients. Chemosphere 77(5):658–662. 10.1016/j.chemosphere.2009.08.009.19748112
Matsumoto S, Kanagawa Y, Koike S, 2010. Twenty-year changes of penta-chlorodibenzofuran (PeCDF) level and symptoms in Yusho patients, using association analysis. BMC Res Notes 3:129. 10.1186/1756-0500-3-129.20444288
Matsumoto S, Akahane M, Kanagawa Y, 2016. Change in decay rates of dioxin-like compounds in Yusho patients. Environ Health 15(1):95. 10.1186/s12940-016-0178-0.27605091
Matsumura F. 2009. The significance of the nongenomic pathway in mediating inflammatory signaling of the dioxin-activated Ah receptor to cause toxic effects. Biochem Pharmacol 77(4):608–626. 10.1016/j.bcp.2008.10.013.18996358
McConnell EE. 1989. Acute and chronic toxicity and carcinogenesis in animals. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. Vol. 4. 2nd ed. Amsterdam: Elsevier Science Publishers, 161–193.
McKee P, Burt A, McCurvin D, 1990. Levels of dioxins, furans and other organic contaminants in harbour sediments near a wood preserving plant using pentachlorophenol and creosote. Chemosphere 20(10–12):1679–1685. 10.1016/0045-6535(90)90329-r.
McLachlan MS. 1993. Digestive tract absorption of polychlorinated dibenzo-p-dioxins, dibenzofurans, and biphenyls in a nursing infant. Toxicol Appl Pharmacol 123(1):68–72. 10.1006/taap.1993.1222.8236263
McLaughlin DL, Pearson RG, Clement RE. 1989. Concentrations of chlorinated dibenzo-p-dioxins (CDD) and dibenzofurans (CDF) in soil from the vicinity of a large refuse incinerator in Hamilton Ontario. Chemosphere 18(1–6):851–854. 10.1016/0045-6535(89)90208-7.
McNulty WP, Pomerantz I, Farrell T. 1981. Chronic toxicity of 2,3,7,8-tetrachlorodibenzofuran for rhesus macaques. Food Cosmet Toxicol 19(1):57–65. 10.1016/0015-6264(81)90304-7.6790390
Meyer C, O'Keefe P, Hilker D, 1989. A survey of twenty community water systems in New York State for PCDDs and PCDFs. Chemosphere 19(1–6):21–26. 10.1016/0045-6535(89)90284-1.
Mikolajczyk S, Warenik-Bany M, Pajurek M. 2021. PCDD/Fs and PCBs in Baltic fish - Recent data, risk for consumers. Mar Pollut Bull 171:112763. 10.1016/j.marpolbul.2021.112763.34332355
Mikolajczyk S, Warenik-Bany M, Pajurek M. 2022. Dioxins and PCBs in freshwater fish and sediments from Polish lakes. Food Addit Contam Part B Surveill 15(3):159–167. 10.1080/19393210.2022.2055154.35410583
Milbrath MO, Wenger Y, Chang CW, 2009. Apparent half-lives of dioxins, furans, and polychlorinated biphenyls as a function of age, body fat, smoking status, and breast-feeding. Environ Health Perspect 117(3):417–425. 10.1289/ehp.11781.19337517
Mitoma C, Mine Y, Utani A, 2015. Current skin symptoms of Yusho patients exposed to high levels of 2,3,4,7,8-pentachlorinated dibenzofuran and polychlorinated biphenyls in 1968. Chemosphere 137:45–51. 10.1016/j.chemosphere.2015.03.070.25985428
Miyata H, Takayama K, Ogaki J, 1989. Levels of PCDDs, coplanar PCBs and PCDFs in patients with Yusho disease and in the Yusho oil. Chemosphere 18(1–6):407–416. 10.1016/0045-6535(89)90149-5.
Moore JA, Gupta BN, Vos JG. 1976. Toxicity of 2,3,7,8-tetrachlorodibenzofuran-preliminary results. In: National conference on polychlorinated biphenyls. Washington, DC: U.S. Environmental Protection Agency, 77–80.
Moore JA, McConnell EE, Dalgard DW, 1979. Comparative toxicity of three halogenated dibenzofurans in guinea pigs, mice, and rhesus monkeys. Ann N Y Acad Sci 320:151–163. 10.1111/j.1749-6632.1979.tb56598.x.110190
Morales L, Dachs J, Gonzalez-Gaya B, 2014. Background concentrations of polychlorinated dibenzo-p-dioxins, dibenzofurans, and biphenyls in the global oceanic atmosphere. Environ Sci Technol 48(17):10198–10207. 10.1021/es5023619.25083749
Morrissey RE, Schwetz BA. 1989. Reproductive and developmental toxicity in animals. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalene, dibenzodioxins and related products. 2nd ed. Amsterdam, Netherlands: Elsevier Science Publishers, 195–225.
Moser GA, McLachlan MS. 2001. The influence of dietary concentration on the absorption and excretion of persistent lipophilic organic pollutants in the human intestinal tract. Chemosphere 45(2):201–211. 10.1016/s0045-6535(00)00551-8.11572612
Muir DC G, Lawrence S, Holoka M, 1992. Partitioning of polychlorinated dioxins and furans between water, sediments and biota in Lake Mesocosms. Chemosphere 25(1–2):119–124. 10.1016/0045-6535(92)90494-c.
Mukerjee D, Papke O, Karmaus W. 1989. Indoor air contamination with polychlorinated dibenzo-p-dioxins and dibenzofurans. Toxicol Ind Health 5(5):731–745. 10.1177/074823378900500511.2815103
Mundy KJ, Brown RS, Pettit K, 1989. Environmental assessment at and around a chemical waste treatment facility: I - Measurements on PCDFs and PCDDs. Chemosphere 19(1–6):381–386. 10.1016/0045-6535(89)90339-1.
Muto H, Takizawa Y. 1991. The liquid-phase photolyses of tetra- and octa-CDDs and their CDFs in hexane solution. Chem Lett (Jpn) 20(2):273–276. 10.1246/cl.1991.273.
Muto H, Saito K, Shinada M, 1991. Concentrations of polychlorinated dibenzo-p-dioxins and dibenzofurans from chemical manufacturers and waste disposal facilities. Environ Res 54(2):170–182. 10.1016/s0013-9351(05)80099-4.2029878
Nadal M, Mari M, Schuhmacher M, 2019. Monitoring dioxins and furans in plasma of individuals living near a hazardous waste incinerator: Temporal trend after 20 years. Environ Res 173:207–211. 10.1016/j.envres.2019.03.051.30927599
Naf C, Broman D, Pettersen H, 1992. Flux estimates and pattern recognition of particulate polycyclic aromatic hydrocarbons, polychlorinated dibenzo-p-dioxins, and dibenzofurans in the waters outside various emission sources on the Swedish Baltic coast. Environ Sci Technol 26(7):1444–1457. 10.1021/es00031a024.
Nagai J, Furukawa M, Tojo A, 1971. [Coulimetric and gas-chromatographic determinations of urinary 17-ketosteroids: Survey of chlorobiphenyls poisoning patients by these methods]. Fukuoka Igaku Zasshi 62:51–65. (Japanese)
Nagao T, Golor G, Hagenmaier H, 1993. Teratogenic potency of 2,3,4,7,8-pentachlorodibenzofuran and of three mixtures of polychlorinated dibenzo-p-dioxins and dibenzofurans in mice. Problems with risk assessment using TCDD toxic-equivalency factors. Arch Toxicol 67(9):591–597.8311685
Nagayama J, Masuda Y, Kuratsune M. 1977. Determination of polychlorinated dibenzofurans in tissues of patients with 'Yusho'. Food Cosmet Toxicol 15(3):195–198. 10.1016/s0015-6264(77)80389-1.408249
Nagayama J, Tsuji H, Iida T, 2001. Effects of contamination level of dioxins and related chemicals on thyroid hormone and immune response systems in patients with "Yusho". Chemosphere 43(4–7):1005–1010.11372817
Nagayama J, Kohno H, Kunisue T, 2007. Concentrations of organochlorine pollutants in mothers who gave birth to neonates with congenital hypothyroidism. Chemosphere 68(5):972–976. 10.1016/j.chemosphere.2007.01.010.17307219
Nakajima S, Saijo Y, Kato S, 2006. Effects of prenatal exposure to polychlorinated biphenyls and dioxins on mental and motor development in Japanese children at 6 months of age. Environ Health Perspect 114(5):773–778. 10.1289/ehp.8614.16675436
Nakajima S, Saijo Y, Miyashita C, 2017. Sex-specific differences in effect of prenatal exposure to dioxin-like compounds on neurodevelopment in Japanese children: Sapporo cohort study. Environ Res 159:222–231. 10.1016/j.envres.2017.08.006.28803151
Nakanishi Y, Shigematsu N, Kurita Y, 1985. Respiratory involvement and immune status in Yusho patients. Environ Health Perspect 59:31–36. 10.1289/ehp.59-1568074.3921360
Nakano T, Tsuji M, Okuno T. 1990. Distribution of PCDDs, PCDFs and PCBs in the atmosphere. Atmos Environ 24(6):1361–1368. 10.1016/0960-1686(90)90042-l.
Nakano S, Noguchi T, Takekoshi H, 2005. Maternal-fetal distribution and transfer of dioxins in pregnant women in Japan, and attempts to reduce maternal transfer with Chlorella (Chlorella pyrenoidosa) supplements. Chemosphere 61(9):1244–1255. 10.1016/j.chemosphere.2005.03.080.15985279
Nakao T, Aozasa O, Ohta S, 2002. Assessment of human exposure to PCDDs, PCDFs and Co-PCBs using hair as a human pollution indicator sample I: Development of analytical method for human hair and evaluation for exposure assessment. Chemosphere 48(8):885–896. 10.1016/s0045-6535(02)00156-x.12222782
Narang AS, Swami K, Narang RS, 1991. Pyrolysis and combustion of liquids and solids containing pentachlorophenol. Chemosphere 22(11):1029–1043. 10.1016/0045-6535(91)90304-v.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Neamah WH, Busbee PB, Alghetaa H, 2020. AhR Activation leads to alterations in the gut microbiome with consequent effect on induction of myeloid derived suppressor cells in a CXCR2-dependent manner. Int J Mol Sci 21(24):9613. 10.3390/ijms21249613.33348596
Nebert DW, Robinson JR, Niwa A, 1975. Genetic expression of aryl hydrocarbon hydroxylase activity in the mouse. Arch Biochem Biophys 85(S1):393–414. 10.1002/jcp.1040850407.
Needham LL, Patterson DG, Alley CC, 1987. Polychlorinated dibenzo-p-dioxins and dibenzofurans levels in persons with high and normal levels of 2,3,7,8-tetrachlorodibenzo-p-dioxin. Chemosphere 16(8–9):2027–2031. 10.1016/0045-6535(87)90203-7.
Neubert D, Wiesmuller T, Abraham K, 1990. Persistence of various polychlorinated dibenzo-p-dioxins and dibenzofurans (PCDDs and PCDFs) in hepatic and adipose tissue of marmoset monkeys. Arch Toxicol 64(6):431–442. 10.1007/BF01977624.2125825
Nguyen AT N, Nishijo M, Pham TT, 2018. Sex-specific effects of perinatal dioxin exposure on eating behavior in 3-year-old Vietnamese children. BMC Pediatr 18(1):213. 10.1186/s12887-018-1171-2.29976197
NIOSH. 2018. Index of CAS no. In: NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgdcas.html. September 28, 2020.
Nishijo M, Tai PT, Nui NM, 2012. Effects of dioxins exposure on social emotional behavior of children living in a hot spot area, Vietnam. Organohalogen Compounds 74:1332–1335. http://dioxin20xx.org/wp-content/uploads/pdfs/2012/1341.pdf. October 7, 2019.
Norstrom RJ, Simon M, Muir DC G. 1990. Polychlorinated dibenzo-p-dioxins and dibenzofurans in marine mammals in the Canadian North. Environ Pollut 66(1):1–19. 10.1016/0269-7491(90)90195-i.15092247
Norström Å, Chaudhary S, Albro PW, 1979. Synthesis of chlorinated dibenzofurans and chlorinated amino-dibenzofurans from the corresponding diphenyl ethers and nitro-diphenylethers. Chemosphere 8(6):331–343. 10.1016/0045-6535(79)90121-8.
Norwood CB, Hackett M, Pruell RJ, 1989. Polychlorinated dibenzo-p-dioxins and dibenzofurans in selected estuarine sediments. Chemosphere 18(1–6):553–560. 10.1016/0045-6535(89)90166-5.
NTP. 2006. Toxicology and carcinogenesis studies of 2,3,4,7,8-pentachlorodibenzofuran (PeCDF) (Cas No. 57117–31-4) in female Harlan Sprague-Dawley rats (gavage studies). Research Triangle Park, NC: National Toxicology Program. NIH Publication No. 06–4461. NTP TR 525. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr526.pdf. June 19, 2020.
NTP. 2021. CASRN index. In: Report on carcinogens. 15th ed. National Toxicology Program. https://ntp.niehs.nih.gov/whatwestudy/assessments/cancer/roc/index.html. January 10, 2022.
Nygren M, Hansson M, Sjöström M, 1988. Development and validation of a method for determination of PCDDs and PCDFs in human blood plasma. A multivariate comparison of blood and adipose tissue levels between Viet Nam veterans and matched controls. Chemosphere 17(9):1663–1692. 10.1016/0045-6535(88)90095-1.
Oanh NT P, Kido T, Honma S, 2018. Androgen disruption by dioxin exposure in 5-year-old Vietnamese children: Decrease in serum testosterone level. Sci Total Environ 640–641:466–474. 10.1016/j.scitotenv.2018.05.257.
Öberg T, Bergström JG T. 1987. Emission and chlorination pattern of PCDD/PCDF predicted from indicator parameters. Chemosphere 16(6):1221–1230. 10.1016/0045-6535(87)90059-2.
Öberg LG, Rappe C. 1992. Biochemical formation of PCDD/Fs from chlorophenols. Chemosphere 25:49–45.
Oehme M. 1991. Dispersion and transport paths of toxic persistent organochlorines to the Arctic - levels and consequences. Sci Total Environ 106(1–2):43–53. 10.1016/0048-9697(91)90019-b.1948014
Oehme M, Manø S, Bjerke B. 1989. Formation of polychlorinated dibenzofurans and dibenzo-p-dioxins by production processes for magnesium and refined nickel. Chemosphere 18(7–8):1379–1389. 10.1016/0045-6535(89)90029-5.
Oehme M, Bartonova A, Knutzen J. 1990. Estimation of polychlorinated dibenzofuran and dibenzo-p-dioxin contamination of a coastal region using isomer profiles in crabs. Environ Sci Technol 24(12):1836–1841. 10.1021/es00082a008.
Ogura I. 2004. Half-life of each dioxin and PCB congener in the human body. Organohalogen Compounds 66:3329–3337. http://dioxin20xx.org/wp-content/uploads/pdfs/2004/04-286.pdf. October 7, 2019.
Ogura I, Masunaga S, Nakanishi J. 2001. Congener-specific characterization of PCDDs/PCDFs in atmospheric deposition: comparison of profiles among deposition, source, and environmental sink. Chemosphere 45(2):173–183. 10.1016/s0045-6535(00)00584-1.11572609
Oishi S, Hiraga K. 1978. Is a mixture of polychlorinated dibenzofurans an inducer of hepatic porphyria? Food Cosmet Toxicol 16(1):47–48. 10.1016/s0015-6264(78)80326-5.415950
Oishi S, Hiraga K. 1980. Effect of polychlorinated biphenyl, dibenzofuran and dibenzo-p-dioxin on the susceptibility of male mice to endotoxin. J Environ Sci Health B 15(1):77–85. 10.1080/03601238009372165.6766964
Oishi S, Morita M, Fukuda H. 1978. Comparative toxicity of polychlorinated biphenyls and dibenzofurans in rats. Toxicol Appl Pharmacol 43(1):13–22. 10.1016/s0041-008x(78)80028-3.415381
O'Keefe P, Hilker D, Meyer C, 1984. Tetrachlorodibenzo-p-dioxins and tetrachlorodibenzofurans in Atlantic coast striped bass and in selected Hudson River fish, waterfowl and sediments. Chemosphere 13(8):849–860. 10.1016/0045-6535(84)90158-9.
O'Keefe PW, Hilker DR, Smith RM, 1986. Nonaccumulation of chlorinated dioxins and furans by goldfish exposed to contaminated sediment and flyash. Bull Environ Contam Toxicol 36(3):452–459. 10.1007/BF01623534.3955259
Okumura M. 1984. Past and current medical states of Yusho patients. Am J Ind Med 5(1–2):13–18.6422744
Okumura M, Yamanaka M, Nakamuta S. 1979. [Ten year follow-up study on serum triglyceride levels in 24 patients with PCB poisoning (author's transl)]. Fukuoka Igaku Zasshi 70(4):208–210. (Japanese)113316
Olson JR, McGarrigle BP, Gigliotti PJ, 1994. Hepatic uptake and metabolism of 2,3,7,8-tetrachlorodibenzo-p-dioxin and 2,3,7,8-tetrachlorodibenzofuran. Fundam Appl Toxicol 22(4):631–640. 10.1006/faat.1994.1069.8056209
Onozuka D, Yoshimura T, Kaneko S, 2009. Mortality after exposure to polychlorinated biphenyls and polychlorinated dibenzofurans: a 40-year follow-up study of Yusho patients. Am J Epidemiol 169(1):86–95. 10.1093/aje/kwn295.18974082
Onozuka D, Nakamura Y, Tsuji G, 2020. Mortality in Yusho patients exposed to polychlorinated biphenyls and polychlorinated dibenzofurans: a 50-year retrospective cohort study. Environ Health 19(1):119. 10.1186/s12940-020-00680-0.33228703
Onozuka D, Nakamura Y, Tsuji G, 2021. Cancer- and noncancer-specific cumulative incidence of death after exposure to polychlorinated biphenyls and dioxins: A competing risk analysis among Yusho patients. Environ Int 147:106320. 10.1016/j.envint.2020.106320.33321390
Opperhuizen A, Sijm DTHM. 1990. Bioaccumulation and biotransformation of polychlorinated dibenzo-p-dioxins and dibenzofurans in fish. Environ Toxicol Chem 9(2):175–186. 10.1002/etc.5620090207.
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1000.pdf. August 28, 2022.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-55.pdf. August 28, 2022.
Oyama Y, Phuc HD, Honma S, 2021. Decreased serum testosterone levels associated with 17β-hydroxysteroid dehydrogenase activity in 7-year-old children from a dioxin-exposed area of Vietnam. Sci Total Environ 783:146701. 10.1016/j.scitotenv.2021.146701.33865132
Pagano JJ, Garner AJ. 2020. Concentrations, toxic equivalence, and age-corrected trends of legacy organic contaminants in Lake Champlain lake trout: 2012–2018. Environ Res 184:109329. 10.1016/j.envres.2020.109329.32169735
Pagano JJ, Garner AJ, McGoldrick DJ, 2018. Age-corrected trends and toxic equivalence of PCDD/F and CP-PCBs in lake trout and walleye from the Great Lakes: 2004–2014. Environ Sci Technol 52(2):712–721. 10.1021/acs.est.7b05568.29249152
Palauschek N, Scholz B. 1987. Destruction of polychlorinated dibenzo-p-dioxins and dibenzofurans in contaminated water samples using ozone. Chemosphere 16(8–9):1857–1863. 10.1016/0045-6535(87)90177-9.
Päpke O, Ball M, Lis ZA, 1989. PCDD/PCDF in whole blood samples of unexposed persons. Chemosphere 19(1–6):941–948. 10.1016/0045-6535(89)90437-2.
Patterson DG, Holler JS, Smith SJ, 1986. Human adipose data for 2,3,7,8-tetrachlorodibenzo-p-dioxin in certain U.S. samples. Chemosphere 15(9–12):2055–2060. 10.1016/0045-6535(86)90512-6.
Patterson DG, Hampton L, Lapeza CR, 1987. High-resolution gas chromatographic/high-resolution mass spectrometric analysis of human serum on a whole-weight and lipid basis for 2,3,7,8-tetrachlorodibenzo-p-dioxin. Anal Chem 59(15):2000–2005. 10.1021/ac00142a023.3631519
Patterson DG, Fürst P, Henderson LO, 1989. Partitioning of in vivo bound PCDDs/PCDFs among various compartments in whole blood. Chemosphere 19(1–6):135–142. 10.1016/0045-6535(89)90301-9.
Perrot-Applanat M, Pimpie C, Cano-Sancho G, 2021. Detection of persistent organic pollutants in omental adipose tissue from patients with diffuse-gastric cancer: A pilot study. Cancers (Basel) 13(19):4874. 10.3390/cancers13194874.34638358
Petreas MX, Goldman LR, Hayward DG, 1991. Biotransfer and bioaccumulation of PCDD/PCDFs from soil: Controlled exposure studies of chickens. Chemosphere 23(11–12):1731–1741. 10.1016/0045-6535(91)90021-5.
Petty JD, Stalling DL, Smith LM, 1983. Occurrence and potential impact of PCDFs and PCDDs in aquatic ecosystems. Trace Subst Environ Health 17:96–102.
Pham TN, Nishijo M, Pham TT, 2020. Dioxin exposure and sexual dimorphism of gaze behavior in prepubertal Vietnamese children living in Da Nang, a hot spot for dioxin contamination. Sci Total Environ 749:141083. 10.1016/j.scitotenv.2020.141083.32829268
Piacitelli LA, Sweeney MH, Fingerhut MA, 1992. Serum levels of PCDDs and PCDFs among workers exposed to 2,3,7,8-TCDD contaminated chemicals. Chemosphere 25(1–2):251–254. 10.1016/0045-6535(92)90526-w.
Pluess N, Poiger H, Hohbach C, 1988a. Subchronic toxicity of some chlorinated dibenzofurans (PCDFs) and a mixture of PCDFs and chlorinated dibenzodioxins (PCDDs) in rats. Chemosphere 17(5):973–984. 10.1016/0045-6535(88)90068-9.
Pluess N, Poiger H, Hohbach C, 1988b. Subchronic toxicity of 2,3,4,7,8-pentachlorodibenzofuran (PeCDF) in rats. Chemosphere 17(6):1099–1110. 10.1016/0045-6535(88)90176-2.
Pluim HJ, Wever J, Koppe JG, 1993. Intake and faecal excretion of chlorinated dioxins and dibenzofurans in breast-fed infants at different ages. Chemosphere 26(11):1947–1952.
Pluim HJ, Van Der Slikke JW, Olie K, 1994. Dioxins and vitamin K status of the newborn. J Environ Sci Health A 29(4):793–802. 10.1080/10934529409376072.
Poiger H, Pluess N, Buser HR. 1989. The metabolism of selected PCDFs in the rat. Chemosphere 18(1–6):259–264. 10.1016/0045-6535(89)90129-x.
Poland A, Knutson JC. 1982. 2,3,7,8-Tetrachlorodibenzo-p-dioxin and related halogenated aromatic hydrocarbons: examination of the mechanism of toxicity. Annu Rev Pharmacol Toxicol 22:517–554. 10.1146/annurev.pa.22.040182.002505.6282188
Poland A, Glover E, Kende AS. 1976. Stereospecific, high affinity binding of 2,3,7,8-tetrachlorodibenzo-p-dioxin by hepatic cytosol. Evidence that the binding species is receptor for induction of aryl hydrocarbon hydroxylase. J Biol Chem 251(16):4936–4946.956169
Poland A, Palen D, Glover E. 1982. Tumour promotion by TCDD in skin of HRS/J hairless mice. Nature 300(5889):271–273. 10.1038/300271a0.7144882
Portier CJ, Edler L, Jung D, 1999. Half-lives and body burdens for dioxin and dioxin-like compounds in humans estimated from an occupational cohort in Germany. Organohalogen Compounds 42:129–138. http://dioxin20xx.org/wp-content/uploads/pdfs/1999/99-453.pdf. October 7, 2019.
Rappe C. 1987. Global distribution of polychlorinated dioxins and dibenzofurans. ACS Symp Ser 338:20–33. 10.1021/bk-1987-0338.ch002.
Rappe C. 1989. Analytical methods and exposure assessment. Chemosphere 18(1–6):17–12.
Rappe C. 1991. Sources of and human exposure to PCDDs and PCDFs. In: Banbury Report 35: Biological basis for risk assessment of dioxins and related compounds. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 121–131.
Rappe C. 1992. Dietary exposure and human levels of PCDs and PCDFs. Chemosphere 25(1–2):231–234.
Rappe C, Buser HR. 1981. Occupational exposure to polychlorinated dioxins and dibenzofurans. ACS Symp Ser 149:319–342. 10.1021/bk-1981-0149.ch020.
Rappe C, Buser HR, Bosshardt HP. 1979. Dioxins, dibenzofurans and other polyhalogenated aromatics: production, use, formation, and destruction. Ann NY Acad Sci 320:1–18. 10.1111/j.1749-6632.1979.tb56588.x.287392
Rappe C, Nygren M, Lindstrom G, 1987. Polychlorinated dibenzofurans and dibenzo-p-dioxins and other chlorinated contaminants in cow milk from various locations in Switzerland. Environ Sci Technol 21(10):964–970. 10.1021/es50001a009.19994994
Rappe C, Marklund S, Kjeller LO, 1989. Long-range transport of PCDDs and PCDFs on airborne particles. Chemosphere 18(1–6):1283–1129.
Rappe C, Glas B, Kjeller LO, 1990a. Levels of PCDDs and PCDFs in products and effluent from the Swedish pulp and paper industry and chloralkali process. Chemosphere 20(10–12):1701–1706. 10.1016/0045-6535(90)90332-n.
Rappe C, Andersson R, Lundström K, 1990b. Levels of polychlorinated dioxins and dibenzofurans in commercial detergents and related products. Chemosphere 21(1–2):43–50. 10.1016/0045-6535(90)90376-5.
Rappe C, Lundstroem G, Glas B, 1990c. Levels of PCDDs in milk cartons in commercial milk. Chemosphere 20:1649–1165.
Rappe C, Kjeller L, Kulp S, 1991a. Levels, profile and pattern of PCDDs and PCDFs in samples related to the production and use of chlorine. Chemosphere 23(11–12):1629–1636. 10.1016/0045-6535(91)90010-B.
Rappe C, Bergqvist P, Kjeller L, 1991b. Levels and patterns of PCDD and PCDF contamination in fish, crabs, and lobsters from Newark Bay and the New York Bight. Chemosphere 22(3–4):239–266. 10.1016/0045-6535(91)90314-4.
Rayne S, Ikonomou MG, Butt CM, 2005. Polychlorinated dioxins and furans from the World Trade Center attacks in exterior window films from lower Manhattan in New York City. Environ Sci Technol 39(7):1995–2003. 10.1021/es049211k.15871229
Reed LW, Hunt GT, Maisel BE, 1990. Baseline assessment of PCDDs/PCDFs in the vicinity of the Elk River, Minnesota generating station. Chemosphere 21(1–2):159–171. 10.1016/0045-6535(90)90388-a.
Reid NW, Orr DB, Shackleton MN, 1990. Monitoring dioxins and dibenzofurans in precipitation in Ontario. Chemosphere 20(10–12):1467–1472. 10.1016/0045-6535(90)90299-9.
Reischl A, Reissinger M, Thoma H, 1989. Accumulation of organic air constituents by plant surfaces: Part IV. Chemosphere 18(1–6):561–568. 10.1016/0045-6535(89)90167-7.
Remmers J, Dupuy A, McDaniel D, 1992. Polychlorinated dibenzo-p-dioxin and dibenzofuran contamination in chloranil and carbazole violet. Chemosphere 25(7–10):1505–1508. 10.1016/0045-6535(92)90177-S.
RePORTER. 2022. Chlorinated dibenzofurans. National Institutes of Health, Research Portfolio Online Reporting Tools. https://projectreporter.nih.gov/reporter.cfm. September 7, 2022.
Reynolds P, Hurley SE, Petreas M, 2005. Adipose levels of dioxins and risk of breast cancer. Cancer Causes Control 16(5):525–535. 10.1007/s10552-004-7840-5.15986107
Richardson TA, Klaassen CD. 2010. Role of UDP-glucuronosyltransferase (UGT) 2B2 in metabolism of triiodothyronine: effect of microsomal enzyme inducers in Sprague Dawley and UGT2B2-deficient Fischer 344 rats. Toxicol Sci 116(2):413–421. 10.1093/toxsci/kfq125.20421340
Roberts SM, Lowney YW, Stuchal LD. 2019. Bioaccessibility of polychlorinated dioxins and furans in soil from a Superfund site. Chemosphere 214:418–423. 10.1016/j.chemosphere.2018.09.044.30268897
Rogan WJ. 1989. Yu-Cheng. In: Kimbrough RD, Jensen AA, eds. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2nd ed. Amsterdam: Elsevier Science Publishers, 401–415.
Rogan WJ, Gladen BC, Hung KL, 1988. Congenital poisoning by polychlorinated biphenyls and their contaminants in Taiwan. Science 241(4863):334–336.3133768
Rohde S, Moser GA, Papke O, 1999. Clearance of PCDD/Fs via the gastrointestinal tract in occupationally exposed persons. Chemosphere 38(14):3397–3410. 10.1016/s0045-6535(98)00551-7.10390849
Rordorf BF. 1989. Prediction of vapor pressures, boiling points and enthalpies of fusion for twenty-nine halogenated dibenzo-p-dioxins and fifty-five dibenzofurans by a vapor pressure correlation method. Chemosphere 18(1–6):783–788. 10.1016/0045-6535(89)90196-3.
Ross DG, Crofton KM, DeVito MJ. 2000. Changes in thyroxine glucuronidation and total serum thyroxine in rats treated with polychlorinated biphenyls and dibenzofurans. Organohalogen Compounds 49:243–246. http://dioxin20xx.org/wp-content/uploads/pdfs/2000/00-436.pdf. October 4, 2019.
Ryan JJ. 1986. Variation of dioxins and furans in human tissues. Chemosphere 15(9–12):1585–1593. 10.1016/0045-6535(86)90441-8.
Ryan JJ, Lizotte R, Lewis D. 1987b. Human tissue levels of PCDDs and PCDFs from a fatal pentachlorophenol poisoning. Chemosphere 16(8–9):1989–1996. 10.1016/0045-6535(87)90199-8.
Ryan JJ, Gasiewicz TA, Brown JF. 1990. Human body burden of polychlorinated dibenzofurans associated with toxicity based on the Yusho and Yucheng incidents. Fundam Appl Toxicol 15(4):722–731. 10.1016/0272-0590(90)90188-p.2128284
Ryan JJ, Guo Y, Masuda Y. 2001. Long-term human elimination and half lives of PCDFs in Yu-Cheng individuals. Organohalogen Compounds 54:304–307. http://dioxin20xx.org/wp-content/uploads/pdfs/2001/01-466.pdf (http://dioxin20xx.org/wp-content/uploads/pdfs/2001/01–466.pdf). October 7, 2019.
Ryan JJ, Schecter A, Lizotte R, 1985a. Tissue distribution of dioxins and furans in humans from the general population. Chemosphere 14(6–7):929–932. 10.1016/0045-6535(85)90218-8.
Ryan JJ, Lizotte R, Sakuma T, 1985b. Chlorinated dibenzo-p-dioxins, chlorinated dibenzofurans, and pentachlorophenol in Canadian chicken and pork samples. J Agric Food Chem 33(6):1021–1026. 10.1021/jf00066a003.
Ryan JJ, Schecter A, Sun NF, 1986. Distribution of chlorinated dibenzo-p-dioxins and chlorinated dibenzofurans in human tissues from the general population. In: Rappe C, Choudhry G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in Perspective. Chelsea, MI: Lewis Publishers, Inc., 3–16.
Ryan JJ, Schecter A, Masuda Y, 1987a. Comparison of PCDDs and PCDFs in the tissues of Yusho patients with those from the general population in Japan and China. Chemosphere 16(8–9):2017–2025. 10.1016/0045-6535(87)90202-5.
Ryan JJ, Conacher HB S, Panopio LG, 1991. Gas chromatographic separations of all 136 tetra- to octa-polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans on nine different stationary phases. J Chromatogr 541:131–118.
Ryan JJ, Shewchuk C, Lau BP Y, 1992. Polychlorinated dibenzo-p-dioxins and polychlorinated dibenzofurans in Canadian bleached paperboard milk containers (1988–1989) and their transfer to fluid milk. J Agric Food Chem 40(5):919–923.
Ryan JJ, Levesque D, Panopio LG, 1993. Elimination of polychlorinated dibenzofurans (PCDFs) and polychlorinated biphenyls (PCBs) from human blood in the Yusho and Yu-Cheng rice oil poisonings. Arch Environ Contam Toxicol 24(4):504–512. 10.1007/bf01146170.8507107
Safe S. 1990a. Polychlorinated dibenzofurans: Environmental impact, toxicology and risk assessment. In: Saxena J, ed. Hazard assessment of chemicals - Current developments. Vol. 7. Washington, DC: Hemisphere Publishing Company, 283–327.
Safe S. 1990b. Polychlorinated biphenyls (PCBs), dibenzo-p-dioxins (PCDDs), dibenzofurans (PCDFs), and related compounds: environmental and mechanistic considerations which support the development of toxic equivalency factors (TEFs). Crit Rev Toxicol 21(1):51–88. 10.3109/10408449009089873.2124811
Safe S. 1991. Polychlorinated dibenzofurans: Environmental impact, toxicology, and risk assessment. Toxic Subst J 11:177–228.
Safe S. 2001. Molecular biology of the Ah receptor and its role in carcinogenesis. Toxicol Lett 120(1–3):1–7. 10.1016/s0378-4274(01)00301-0.11323156
Safe SH, Safe LM. 1984. Synthesis and characterization of twenty-two purified polychlorinated dibenzofuran congeners. J Agric Food Chem 32(1):68–67. 10.1021/jf00121a018.
Safe S, Bunce NJ, Chittim B, 1977. Photodecomposition of halogenated aromatic compounds. In: Keith LH, ed. Identification and analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science, 35–47.
Safe S, Mason G, Keys B, 1986. Polychlorinated dibenzo-p-dioxins and dibenzofurans: Correlation between in vitro and in vivo structure-activity relationships (SARs). Chemosphere 15(9–12):1725–1731. 10.1016/0045-6535(86)90460-1.
Safe S, Brown KW, Donnelly KC, 1992. Polychlorinated dibenzo-p-dioxins and dibenzofurans associated with wood-preserving chemical sites: Biomonitoring with pine needles. Environ Sci Technol 26(2):394–396. 10.1021/es00026a023.
Salisbury TB, Marcinkiewicz JL. 2002. In utero and lactational exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin and 2,3,4,7,8-pentachlorodibenzofuran reduces growth and disrupts reproductive parameters in female rats. Biol Reprod 66(6):1621–1626. 10.1095/biolreprod66.6.1621.12021039
Schecter A. 1991. Dioxins and related chemicals in humans and in the environment. In: Banbury Report 35: Biological basis for risk assessment of dioxins and related compounds. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 169–214.
Schecter A, Gasiewicz TA. 1987a. Human breast milk levels of dioxins and dibenzofurans: Significance with respect to current risk assessments. ACS Symp Ser 338:162–173. 10.1021/bk-1987-0338.ch012.
Schecter A, Gasiewicz TA. 1987b. Health hazard assessment of chlorinated dioxins and dibenzofurans contained in human milk. Chemosphere 16(8–9):2147–2154. 10.1016/0045-6535(87)90223-2.
Schecter A, Ryan JJ. 1989. Blood and adipose tissue levels of PCDDs/PCDFs over three years in a patient after exposure to polychlorinated dioxins and dibenzofurans. Chemosphere 18(1–6):635–642. 10.1016/0045-6535(89)90176-8.
Schecter A, Ryan JJ, Gitlitz G. 1986. Chlorinated dioxin and dibenzofuran levels in human adipose tissues from exposed and control populations. In: Rappe C, Choudhry G, Keith LH, eds. Chlorinated dioxins and dibenzofurans in perspective. Chelsea, MI: Lewis Publishers, Inc., 51–65.
Schecter A, Ryan JJ, Constable JD. 1987. Polychlorinated dibenzo-p-dioxin and polychlorinated dibenzofuran levels in human breast milk from Vietnam compared with cow's milk and human breast milk from the North American continent. Chemosphere 16(8–9):2003–2016. 10.1016/0045-6535(87)90201-3.
Schecter A, Mes J, Davies D. 1989a. Polychlorinated biphenyl (PCB), DDT, DDE and hexachlorobenzene (HCB) and PCDD/F isomer levels in various organs in autopsy tissue from North American patients. Chemosphere 18(1–6):811–818. 10.1016/0045-6535(89)90201-4.
Schecter A, Ryan JJ, Constable JD. 1989c. Chlorinated dioxins and dibenzofurans in human milk from Japan, India, and the United States of America. Chemosphere 18(1–6):975–980. 10.1016/0045-6535(89)90225-7.
Schecter A, Päpke O, Ball M. 1990a. Evidence for transplacental transfer of dioxins from mother to fetus: Chlorinated dioxin and dibenzofuran levels in the livers of stillborn infants. Chemosphere 21(8):1017–1022. 10.1016/0045-6535(90)90124-C.
Schecter A, Ryan JJ, Kostyniak PJ. 1990b. Decrease over a six year period of dioxin and dibenzofuran tissue levels in a single patient following exposure. Chemosphere 20(7–9):911–917. 10.1016/0045-6535(90)90200-D.
Schecter A, Ryan JJ, Päpke O. 1998. Decrease in levels and body burden of dioxins, dibenzofurans, PCBS, DDE, and HCB in blood and milk in a mother nursing twins over a thirty-eight month period. Chemosphere 37(9–12):1807–1816. 10.1016/s0045-6535(98)00246-x.9828309
Schecter A, Tiernan T, Schaffner F, 1985a. Patient fat biopsies for chemical analysis and liver biopsies for ultrastructural characterization after exposure to polychlorinated dioxins, furans and PCBs. Environ Health Perspect 60:241–254. 10.1289/ehp.8560241.3928350
Schecter A, Ryan JJ, Lizotte R, 1985b. Chlorinated dibenzodioxins and dibenzofurans in human adipose tissue from exposed and control New York State patients. Chemosphere 14:933–993.
Schecter A, Fürst P, Fürst C, 1989b. Levels of polychlorinated dibenzodioxins and dibenzofurans in cow's milk and in soy bean derived infant formulas sold in the United States and other countries. Chemosphere 19(1–6):913–918. 10.1016/0045-6535(89)90431-1.
Schecter A, Furst P, Ryan JJ, 1989d. Polychlorinated dioxin and dibenzofuran levels from human milk from several locations in the United States, Germany and Vietnam. Chemosphere 19:979–984.
Schecter A, Fürst P, Fürst C, 1990c. Levels of dioxins, dibenzofurans and other chlorinated xenobiotics in human milk from the Soviet Union. Chemosphere 20:927–993.
Schecter AJ, Malkin R, Papke O, 1991a. Dioxin levels in blood of municipal incinerator workers. Med Sci Res 19:331–332.
Schecter A, Fürst P, Fürst C, 1991b. Dioxins, dibenzofurans and selected chlorinated organic compounds in human milk and blood from Cambodia, Germany, Thailand, the USA, the USSR, and Vietnam. Chemosphere 23(11–12):1903–1912. 10.1016/0045-6535(91)90037-E.
Schecter A, Päpke O, Ball M, 1991c. Partitioning of dioxins and dibenzofurans: Whole blood, blood plasma and adipose tissue. Chemosphere 23(11–12):1913–1919. 10.1016/0045-6535(91)90038-F.
Schecter A, Startin J, Wright C, 1993. Dioxin levels in food from the United States with estimated daily intake. Organohalogen Compounds 13:97–100. http://dioxin20xx.org/wp-content/uploads/pdfs/1993/93–302.pdf. April 24, 2020.
Schecter A, Päpke O, Lis A, 1996. Decrease in milk and blood dioxin levels over two years in a mother nursing twins: Estimates of decreased maternal and increased infant dioxin body burden from nursing. Chemosphere 32(3):543–549. 10.1016/0045-6535(95)00248-0.8907231
Schlummer M, Moser GA, McLachlan MS. 1998. Digestive tract absorption of PCDD/Fs, PCBs, and HCB in humans: mass balances and mechanistic considerations. Toxicol Appl Pharmacol 152(1):128–137. 10.1006/taap.1998.8487.9772208
Schoeny R. 1982. Mutagenicity testing of chlorinated biphenyls and chlorinated dibenzofurans. Mutat Res 101(1):45–56. 10.1016/0165-1218(82)90164-1.7043248
Schramm KW, Kuettner T, Weber S, 1992. Dioxin hair analysis as monitoring pool. Chemosphere 24(3):351–358. 10.1016/0045-6535(92)90303-9.
Schrey P, Wittsiepe J, Mackrodt P, 1998. Human fecal PCDD/F-excretion exceeds the dietary intake. Chemosphere 37(9–12):1825–1831. 10.1016/s0045-6535(98)00248-3.9828311
Sedman RM, Esparza JR. 1991. Evaluation of the public health risks associated with semivolatile metal and dioxin emissions from hazardous waste incinerators. Environ Health Perspect 94:181–187. 10.1289/ehp.94-1567951.1954929
Sherman RK, Clement RE, Tashiro C. 1990. The distribution of polychlorinated dibenzo-p-dioxins and dibenzofurans in Jackfish Bay, Lake Superior, in relation to a kraft pulp mill effluent. Chemosphere 20(10–12):1641–1648. 10.1016/0045-6535(90)90324-m.
Shi LL, Wang MQ, Nakayama SF, 2020. The association between dioxins and steroid hormones in general adult males: a cross-sectional study in an e-waste region of China. Environ Sci Pollut Res Int 27(21):26511–26519. 10.1007/s11356-020-09086-4.32367235
Shigematsu N, Norimatsu Y, Ishibashi T, 1971. [Clinical and experimental studies on respiratory involvement in chlorobiphenyls poisoning]. Fukuoka Igaku Zasshi 62:150–156. (Japanese)
Shigematsu N, Ishimaru S, Ikeda T, 1977. [Further studies on respiratory disorders in polychlorinated biphenyls (PCB) poisoning. Relationship between respiratory disorders and PCB concentrations in blood and sputum (author's transl)]. Fukuoka Igaku Zasshi 68(3):133–138. (Japanese)405296
Siebert PC, Alston DR, Walsh JF, 1987. Statistical properties of available worldwide MSW combustion dioxin/furan emissions. Proc APCA Annu Meet 80:1–20.
Sijm DTHM, Wever H, de Vries PJ, 1989. Octan-1-ol/water partition coefficients of polychlorinated dibenzo-p-dioxins and dibenzofurans: Experimental values determined with a stirring method. Chemosphere 19(1–6):263–266. 10.1016/0045-6535(89)90321-4.
Smith RM, O'Keefe PW, Hilker DR, 1986. Determination of picogram per cubic meter concentrations of tetra- and pentachlorinated dibenzofurans and dibenzo-p-dioxins in indoor air by high-resolution gas chromatography/high-resolution mass spectrometry. Anal Chem 58(12):2414–2420. 10.1021/ac00125a014.3789396
Smith RM, O’Keefe PW, Aldous KM, 1990a. Chlorinated dibenzofurans and dioxins in atmospheric samples from cities in New York. Environ Sci Technol 24:1502–1150.
Smith LM, Schwartz TR, Feltz K, 1990b. Determination and occurrence of AHH-active polychlorinated biphenyls, 2,3,7,8-tetrachloro-p-dioxin and 2,3,7,8-tetrachlorodibenzofuran in Lake Michigan sediment and biota. The question of their relative toxicological significance. Chemosphere 21(9):1063–1085. 10.1016/0045-6535(90)90128-g.
Sola-Gutierrez C, Schroder S, San Roman MF, 2019. PCDD/Fs traceability during triclosan electrochemical oxidation. J Hazard Mater 369:584–592. 10.1016/j.jhazmat.2019.02.066.30818123
Someshwar AV, Jain AK, Whittemore RC, 1990. The effects of sludge burning on the PCDD/PCDF content of ashes from pulp and paper mill hog fuel boilers. Chemosphere 20(10–12):1715–1722. 10.1016/0045-6535(90)90334-p.
Stalling DL, Norstrom RJ, Smith LM, 1985. Patterns of PCDD, PCDF, and PCB contamination in Great Lakes fish and birds and their characterization by principal components analysis. Chemosphere 14(6–7):627–643. 10.1016/0045-6535(85)90171-7.
Stanley JS, Boggess KE, Onstot J, 1986. PCDDs and PCDFs in human adipose tissue from the EPA FY82 NHATS repository. Chemosphere 15(9–12):1605–1612. 10.1016/0045-6535(86)90444-3.
Steer P, Tashiro C, Clement R, 1990. Ambient air sampling of polychlorinated dibenzo-p-dioxins and dibenzofurans in Ontario: preliminary results. Chemosphere 20(10–12):1431–1437. 10.1016/0045-6535(90)90294-4.
Stephens RD. 1986. Transformer fire Spear Street Tower One Market Plaza San Francisco, California. Chemosphere 15(9–12):1281–1289. 10.1016/0045-6535(86)90402-9.
Stieglitz L, Zwick G, Beck J, 1989. Carbonaceous particles in fly ash -a source for the de-novo synthesis of organochlorocompounds. Chemosphere 19(1–6):283–290. 10.1016/0045-6535(89)90325-1.
Sun XL, Kido T, Honma S, 2016. Influence of dioxin exposure upon levels of prostate-specific antigen and steroid hormones in Vietnamese men. Environ Sci Pollut Res Int 23(8):7807–7813. 10.1007/s11356-015-5931-3.26758301
Sun XL, Kido T, Honma S, 2017. The relationship between dioxins exposure and risk of prostate cancer with steroid hormone and age in Vietnamese men. Sci Total Environ 595:842–848. 10.1016/j.scitotenv.2017.04.013.28412653
Sun S, Cao R, Jin J, 2021. Accumulation characteristics and estimated dietary intakes of polychlorinated dibenzo-p-dioxins, polychlorinated dibenzofurans and polychlorinated biphenyls in plant-origin foodstuffs from Chinese markets. Sci Total Environ 775:145830. 10.1016/j.scitotenv.2021.145830.33621885
Sunahara GI, Nelson KG, Wong TK, 1987. Decreased human birth weights after in utero exposure to PCBs and PCDFs are associated with decreased placental EGF-stimulated receptor autophosphorylation capacity. Mol Pharmacol 32(5):572–578.3119985
Sutter TR, Greenlee WF. 1992. Classification of members of the Ah gene battery. Chemosphere 25(1–2):223–226.
Svenson A, Kjeller L, Rappe C. 1989a. Enzymatic chlorophenol oxidation as a means of chlorinated dioxin and dibenzofuran formation. Chemosphere 19:585–558.
Svenson A, Kjeller L, Rappe C. 1989b. Enzyme-mediated formation of 2,3,7,8-tetra-substituted chlorinated dibenzodioxins and dibenzofurans. Environ Sci Technol 23:900–990.
Svensson BG, Nilsson A, Hansson M, 1991. Exposure to dioxins and dibenzofurans through the consumption of fish. N Engl J Med 324(1):8–12. 10.1056/NEJM199101033240102.1898530
Tai H, McReynolds JH, Goldstein JA, 1993. Cytochrome P4501A1 mediates the metabolism of 2,3,7,8-tetrachlorodibenzofuran in the rat and human. Toxicol Appl Pharmacol 123(1):34–42. 10.1006/taap.1993.1218.8236259
Tai PT, Nishijo M, Anh NT N, 2013. Perinatal dioxin exposure and neurodevelopment of children aged 3 years - a follow up study in Vietnam. Organohalogen Compounds 75:1321–1324. http://dioxin20xx.org/wp-content/uploads/pdfs/2013/8009.pdf. October 7, 2019.
Takayama K, Miyata H, Mimura M, 1991. Evaluation of biological effects of polychlorinated compounds found in contaminated cooking oil responsible for the disease “Yusho”. Chemosphere 22(5–6):537–546. 10.1016/0045-6535(91)90065-l.
Takeshita R, Akimoto Y. 1989. Control of PCDD and PCDF formation in fluidized bed incinerators. Chemosphere 19(1–6):345–352. 10.1016/0045-6535(89)90334-2.
Taki I, Hisanaga S, Amagase Y. 1969. [Report on Yusho (chlorobiphenyls poisoning) pregnant women and their fetuses]. Fukuoka Igaku Zasshi 60:471–474. (Japanese)
Tanabe S, Kannan N, Wakimoto T, 1989. Isomer‐specific determination and toxic evaluation of potentially hazardous coplanar PCBs, dibenzofurans and dioxins in the tissues of “Yusho” PCB poisoning victim and in the causal oil. Toxicol Environ Chem 24(4):215–231. 10.1080/02772248909357494.
Taucher JA, Hannah DJ, Green NJ L, 1992. PCDD, PCDF and PCB emissions under variable operating conditions from a waste oil furnace. Chemosphere 25(7–10):1429–1433. 10.1016/0045-6535(92)90165-n.
Taura J, Takeda T, Fujii M, 2014. 2,3,4,7,8-Pentachlorodibenzofuran is far less potent than 2,3,7,8-tetrachlorodibenzo-p-dioxin in disrupting the pituitary-gonad axis of the rat fetus. Toxicol Appl Pharmacol 281(1):48–57. 10.1016/j.taap.2014.09.001.25220434
Tawara K, Nishijo M, Nakagawa H, 2008. Association of having birth defect children with serum dioxin levels in Vietnam. Organohalogen Compounds 69:568–571. http://dioxin20xx.org/wp-content/uploads/pdfs/2007/07–305.pdf. October 4, 2019.
Tawara K, Nishijo M, Honda R, 2009. Effects of maternal dioxin exposure on newborn size at birth among Japanese mother-infant pairs. Environ Health Prev Med 14(2):88–95. 10.1007/s12199-008-0061-x.19568852
Thoma H, Mücke W, Kauert G. 1990. Comparison of the polychlorinated dibenzo-p-dioxin and dibenzofuran in human tissue and human liver. Chemosphere 20(3–4):433–442. 10.1016/0045-6535(90)90074-4.
Thomas RG. 1982. Volatilization from water. In: Lyman WH, Riehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book Company, 15–11 to 15–34.
Thompson HC, Kendall DC, Korfmacher WA, 1986. Assessment of the contamination of a multibuilding facility by polychlorinated biphenyls, polychlorinated dibenzo-p-dioxins, and polychlorinated dibenzofurans. Environ Sci Technol 20(6):597–603. 10.1021/es00148a009.19994957
Tiernan TO, Taylor ML, Van Ness GF, 1984. Analyses of human tissues for chlorinated dibenzo-p-dioxins and chlorinated dibenzofurans: The state of the art. In: Lowrance WW, ed. Public health risks of the dioxins. New York, NY: Rockefeller University, 31–56.
Tiernan TO, Taylor ML, Garrett JH, 1985. Sources and fate of polychlorinated dibenzodioxins, dibenzofurans and related compounds in human environments. Environ Health Perspect 59:145–158. 10.1289/ehp.59-1568078.3921357
Tiernan TO, Wagel DJ, Garrett JH, 1989. Laboratory and field tests to demonstrate the efficacy of KPEG reagent for detoxification of hazardous wastes containing polychlorinated dibenzo-p-dioxins (PCDD) and dibenzofurans (PCDF) and soils contaminated with such chemical wastes. Chemosphere 18(1–6):835–841. 10.1016/0045-6535(89)90205-1.
Tirler W, Voto G, Donega M. 2001. PCDD/F, PCB and hexachlorobenzene levels in hair. Organohalogen Compounds 52:290–292. http://dioxin20xx.org/wp-content/uploads/pdfs/2001/01-534.pdf. October 7, 2019.
Todaka T, Hirakawa H, Kajiwara J, 2010. Relationship between the concentrations of polychlorinated dibenzo-p-dioxins, polychlorinated dibenzofurans, and polychlorinated biphenyls in maternal blood and those in breast milk. Chemosphere 78(2):185–192. 10.1016/j.chemosphere.2009.09.047.19850319
Tondeur Y, Beckert WF, Billets S, 1989. Method 8290: An analytical protocol for the multimedia characterization of polychlorinated dibenzodioxins and dibenzofurans by high-resolution gas chromatography/high-resolution mass spectrometry. Chemosphere 18(1–6):119–131. 10.1016/0045-6535(89)90112-4.
Tong HY, Karasek FW. 1986. Comparison of PCDD and PCDF in flyash collected from municipal incinerators of different countries. Chemosphere 15(9–12):1219–1224. 10.1016/0045-6535(86)90394-2.
Travis CC, Hattemer-Frey HA. 1989. A perspective on dioxin emissions from municipal solid waste incinerators. Risk Anal 9(1):91–97. 10.1111/j.1539-6924.1989.tb01223.x.2469111
TRI21. 2022. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. February 10, 2020.
Tsai PC, Ko YC, Huang W, 2007. Increased liver and lupus mortalities in 24-year follow-up of the Taiwanese people highly exposed to polychlorinated biphenyls and dibenzofurans. Sci Total Environ 374(2–3):216–222. 10.1016/j.scitotenv.2006.12.024.17257654
Tsukimori K, Tokunaga S, Shibata S, 2008. Long-term effects of polychlorinated biphenyls and dioxins on pregnancy outcomes in women affected by the Yusho incident. Environ Health Perspect 116(5):626–630. 10.1289/ehp.10686.18470296
Tsukimori K, Uchi H, Mitoma C, 2011. Comparison of the concentrations of polychlorinated biphenyls and dioxins in mothers affected by the Yusho incident and their children. Chemosphere 84(7):928–935. 10.1016/j.chemosphere.2011.06.009.21723585
Tsukimori K, Morokuma S, Hori T, 2013. Characterization of placental transfer of polychlorinated dibenzo-p-dioxins, dibenzofurans and polychlorinated biphenyls in normal pregnancy. J Obstet Gynaecol 39(1):83–90. 10.1111/j.1447-0756.2012.01906.x.
Tue NM, Suzuki G, Takahashi S, 2013. Dioxin-related compounds in house dust from New York State: occurrence, in vitro toxic evaluation and implications for indoor exposure. Environ Pollut 181:75–80. 10.1016/j.envpol.2013.06.010.23838483
Tuomisto J, Airaksinen R, Kiviranta H, 2016. A pharmacokinetic analysis and dietary information are necessary to confirm or reject the hypothesis on persistent organic pollutants causing type 2 diabetes. Toxicol Lett 261:41–48. 10.1016/j.toxlet.2016.08.024.27575567
Tysklind M, Rappe C. 1991. Photolytic transformation of polychlorinated dioxins and dibenzofurans in fly ash. Chemosphere 23(8–10):1365–1375. 10.1016/0045-6535(91)90161-6.
Uemura H, Arisawa K, Hiyoshi M, 2009. Prevalence of metabolic syndrome associated with body burden levels of dioxin and related compounds among Japan's general population. Environ Health Perspect 117(4):568–573. 10.1289/ehp.0800012.19440495
Uzawa H, Ito Y, Notomi A, 1969. [Hyperglyceridemia resulting from intake of rice oil contaminated with chlorinated biphenyls]. Fukuoka Igaku Zasshi 60:449–454. (Japanese)
Vainio H, Hesso A, Jappinen P. 1989. Chlorinated dioxins and dibenzofurans in the environment - a hazard to public health? Scand J Work Environ Health 15(6):377–382. 10.5271/sjweh.1837.2482540
Valenzuela CM, García AG, Avila VC, 2022. Applying the Global Monitoring Plan and analysis of POPs results in atmospheric air in Mexico (2017–2018). Chemosphere 303(Part 2):135154. 10.1016/j.chemosphere.2022.135154.35640689
van den Berg M, Olie K, Hutzinger. 1985. Polychlorinated dibenzofurans (PCDFs): Environmental occurrence and physical, chemical and biological properties. Toxicol Environ Chem 9(3):171–217. 10.1080/02772248509357079.
van den Berg M, van der Wielen FW M, Olie K, 1986. The presence of PCDDs and PCDFs in human breast milk from the Netherlands. Chemosphere 15(6):693–706. 10.1016/0045-6535(86)90035-4.
van den Berg M, de Jongh J, Eckhart P, 1989. Disposition and elimination of three polychlorinated dibenzofurans in the liver of the rat. Fundam Appl Toxicol 12:738–774.2744276
van den Berg M, Birnbaum L, Bosveld AT C, 1998. WHO Toxic equivalent factors (TEFs) for dioxin-like compounds for humans and wildlife. Environ Health Perspect 106(12):775–792.9831538
van den Berg M, Birnbaum LS, Denison M, 2006. The 2005 World Health Organization reevaluation of human and mammalian toxic equivalency factors for dioxins and dioxin-like compounds. Toxicol Sci 93(2):223–241. 10.1093/toxsci/kfl055.16829543
van Ede KI, Aylward LL, Andersson PL, 2013. Tissue distribution of dioxin-like compounds: potential impacts on systemic relative potency estimates. Toxicol Lett 220(3):294–302. 10.1016/j.toxlet.2013.05.001.23680695
Van Luong H, Tai PT, Nishijo M, 2018. Association of dioxin exposure and reproductive hormone levels in men living near the Bien Hoa airbase, Vietnam. Sci Total Environ 628–629:484–489. 10.1016/j.scitotenv.2018.02.094.
Van Tung D, Kido T, Honma S, 2016. Low birth weight of Vietnamese infants is related to their mother's dioxin and glucocorticoid levels. Environ Sci Pollut Res Int 23(11):10922–10929. 10.1007/s11356-016-6233-0.26898930
Vanden Heuvel JP, Clark GC, Tritscher A, 1994. Accumulation of polychlorinated dibenzo-p-dioxins and dibenzofurans in liver of control laboratory rats. Fundam Appl Toxicol 23(3):465–469.7835546
Vartiainen T, Jaakkola JJ, Saarikoski S, 1998. Birth weight and sex of children and the correlation to the body burden of PCDDs/PCDFs and PCBs of the mother. Environ Health Perspect 106(2):61–66. 10.1289/ehp.9810661.9432971
Veerkamp W, Wever J, Hutzinger G. 1981. The metabolism of some chlorinated dibenzofurans by rats. Chemosphere 10(4):397–340.
Venier M, Ferrario J, Hites RA. 2009. Polychlorinated dibenzo-p-dioxins and dibenzofurans in the atmosphere around the Great Lakes. Environ Sci Technol 43(4):1036–1041. 10.1021/es802644w.19320154
Venkatesan AK, Halden RU. 2014. Contribution of polybrominated dibenzo-p-dioxins and dibenzofurans (PBDD/Fs) to the toxic equivalency of dioxin-like compounds in archived biosolids from the U.S. EPA's 2001 national sewage sludge survey. Environ Sci Technol 48(18):10843–10849. 10.1021/es503110j.25157505
Vigh E, Colombo A, Benfenati E, 2013. Individual breast milk consumption and exposure to PCBs and PCDD/Fs in Hungarian infants: a time-course analysis of the first three months of lactation. Sci Total Environ 449:336–344. 10.1016/j.scitotenv.2013.01.024.23435065
Villanueva EC, Jennings RW, Burse VW, 1974. Evidence of chlorodibenzo-p-dioxin and chlorodibenzofuran in hexachlorobenzene. J Agric Food Chem 22(5):916–917. 10.1021/jf60195a021.4419686
Vos JG, Luster MI. 1989. Immune alterations. In: Kimbrough RD JA, ed. Halogenated biphenyls, terphenyls, naphthalenes, dibenzodioxins and related products. 2^nd^ ed. Amsterdam: Elsevier Science Publishers, 295–322.
Waddell D, Chittim B, Clement R, 1990. Database of PCDD/PCDF levels in ambient air and in samples related to the pulp and paper industry. Chemosphere 20(10–12):1463–1466. 10.1016/0045-6535(90)90298-8.
Wang S, Guo YL, Lin C, 2002. Body burden of polychlorinated dibenzo-p-dioxins, dibenzofurans and biphenyls in pregnant women and their infants - correlation between prenatal and postnatal exposure to infants. Organohalogen Compounds 55:255–258. http://dioxin20xx.org/wp-content/uploads/pdfs/2002/02–61.pdf. October 4, 2019.
Wang S, Chen T, Hsu J, 2003. Neonatal and childhood teeth in relation to perinatal exposure to polychlorinated biphenyls and dibenzofurans: observations of the Yucheng children in Taiwan. Environ Res 93(2):131–137. 10.1016/s0013-9351(03)00040-9.12963397
Wang S, Lin C, Guo YL, 2004. Infant exposure to polychlorinated dibenzo-p-dioxins, dibenzofurans and biphenyls (PCDD/Fs, PCBs) - correlation between prenatal and postnatal exposure. Chemosphere 54(10):1459–1473. 10.1016/j.chemosphere.2003.08.012.14659948
Wang S, Tsai P, Yang C, 2008. Increased risk of diabetes and polychlorinated biphenyls and dioxins: a 24-year follow-up study of the Yucheng cohort. Diabetes Care 31(8):1574–1579. 10.2337/dc07-2449.18487481
Wang Z, Hang JG, Feng H, 2019. Effects of perinatal dioxin exposure on development of children: a 3-year follow-up study of China cohort. Environ Sci Pollut Res Int 26(20):20780–20786. 10.1007/s11356-019-05362-0.31102233
Wang Z, Sun Y, Dong JJ, 2022. Relationship between dioxins and steroid hormone in 6-year-olds: A follow-up study in an e-waste region of China. Chemosphere 296:134018. 10.1016/j.chemosphere.2022.134018.35181420
Warenik-Bany M, Maszewski S, Mikolajczyk S, 2019. Impact of environmental pollution on PCDD/F and PCB bioaccumulation in game animals. Environ Pollut 255(Pt 1):113159. 10.1016/j.envpol.2019.113159.
Watanabe MX, Kunisue T, Ueda N, 2013. Toxicokinetics of dioxins and other organochlorine compounds in Japanese people: association with hepatic CYP1A2 expression levels. Environ Int 53:53–61. 10.1016/j.envint.2012.12.008.23333656
Weber H, Birnbaum LS. 1985. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) and 2,3,7,8-tetrachlorodibenzofuran (TCDF) in pregnant C57BL/6N mice: distribution to the embryo and excretion. Arch Toxicol 57(3):159–162. 10.1007/bf00290880.4062549
Weber H, Lamb JC, Harris MW, 1984. Teratogenicity of 2.3.7.8-tetrachlorodibenzofuran (TCDF) in mice. Toxicol Lett 20(2):183–188. 10.1016/0378-4274(84)90145-0.6695410
Weber H, Harris MW, Haseman JK, 1985. Teratogenic potency of TCDD, TCDF and TCDD-TCDF combinations in C57BL/6N mice. Toxicol Lett 26(2–3):159–167. 10.1016/0378-4274(85)90161-4.4035709
Weichenthal S, Van Rijswijk D, Kulka R, 2015. The impact of a landfill fire on ambient air quality in the north: A case study in Iqaluit, Canada. Environ Res 142:46–50. 10.1016/j.envres.2015.06.018.26093783
Whitlock JP. 1999. Induction of cytochrome P4501A1. Annu Rev Pharmacol Toxicol 39:103–125. 10.1146/annurev.pharmtox.39.1.103.10331078
Whittemore RC, LaFleur LE, Gillespie WJ, 1990. USEPA/paper industry cooperative dioxin study: The 104 mill study. Chemosphere 20(10–12):1625–1632. 10.1016/0045-6535(90)90322-k.
WHO. 2000. Air quality guidelines for Europe. Copenhagen, Denmark: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0005/74732/E71922.pdf. April 22, 2020.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Wiberg K, Lundström K, Glas B, 1989. PCDDs and PCDFs in consumers' paper products. Chemosphere 19(1–6):735–740. 10.1016/0045-6535(89)90400-1.
Williams DT, LeBel GL, Benoit FM. 1992. Polychlorodibenzodioxins and polychlorodibenzofurans in dioxazine dyes and pigments. Chemosphere 24(2):169–180. 10.1016/0045-6535(92)90390-d.
Wittsiepe J, Erlenkamper B, Welge P, 2007a. Bioavailability of PCDD/F from contaminated soil in young Goettingen minipigs. Chemosphere 67(9):S355–S364. 10.1016/j.chemosphere.2006.05.129.17223170
Wittsiepe J, Fürst P, Schrey P, 2007b. PCDD/F and dioxin-like PCB in human blood and milk from German mothers. Chemosphere 67(9):S286–S294. 10.1016/j.chemosphere.2006.05.118.17217986
Xu P, Chen Z, Wu L, 2019. Health risk of childhood exposure to PCDD/Fs emitted from a municipal waste incinerator in Zhejiang, China. Sci Total Environ 689:937–944. 10.1016/j.scitotenv.2019.06.425.31280174
Xu S, Hansen S, Rautio A, 2022. Monitoring temporal trends of dioxins, organochlorine pesticides and chlorinated paraffins in pooled serum samples collected from Northern Norwegian women: The MISA cohort study. Environ Res 204(Pt A):111980. 10.1016/j.envres.2021.111980.
Yamagishi T, Miyazaki T, Akiyama K, 1981. Polychlorinated dibenzo-p-dioxins and dibenzofurans in commercial diphenyl ether herbicides, and in freshwater fish collected from the application area. Chemosphere 10(10):1137–1144. 10.1016/0045-6535(81)90184-3.
Yamaguchi A, Yoshimura T, Kuratsune M. 1971. [Investigation concerning babies born from women who consumed oil contaminated with chlorobiphenyl]. Fukuoka Igaku Zasshi 62(1):117–122. (Japanese)
Yamazaki K, Itoh S, Ikeda-Araki A, 2022. Association of prenatal exposure to dioxin-like compounds, polychlorinated biphenyl, and methylmercury with event-related brain potentials in school-aged children: The Hokkaido study. Neurotoxicology 91:11–21. 10.1016/j.neuro.2022.04.011.35490840
Yanders AF, Orazio CE, Puri RK, 1989. On translocation of 2,3,7,8-tetrachlorodibenzo-p-dioxin: Time dependent analysis at the Times Beach experimental site. Chemosphere 19(1–6):429–432. 10.1016/0045-6535(89)90347-0.
Yang C, Yu M, Guo H, 2005. The endocrine and reproductive function of the female Yucheng adolescents prenatally exposed to PCBs/PCDFs. Chemosphere 61(3):355–360. 10.1016/j.chemosphere.2005.02.089.15885742
Yang C, Wang Y, Chen P, 2008. Exposure to a mixture of polychlorinated biphenyls and polychlorinated dibenzofurans resulted in a prolonged time to pregnancy in women. Environ Health Perspect 116(5):599–604. 10.1289/ehp.10715.18470317
Yang C, Huang T, Lin K, 2011. Menstrual effects among women exposed to polychlorinated biphenyls and dibenzofurans. Environ Res 111(2):288–294. 10.1016/j.envres.2010.11.011.21186023
Yen Y, Lan S, Yang C, 1994. Follow-up study of intrauterine growth of transplacental Yu-Cheng babies in Taiwan. Bull Environ Contam Toxicol 53(5):633–641. 10.1007/bf00196933.7833597
Yoshihara S, Nagata K, Yoshimura H, 1981. Inductive effect on hepatic enzymes and acute toxicity of individual polychlorinated dibenzofuran congeners in rats. Toxicol Appl Pharmacol 59(3):580–588. 10.1016/0041-008x(81)90313-6.7268781
Yoshimura T. 1974. [Epidemiological study on Yusho babies born to mothers who had consumed oil contaminated by PCB]. Fukuoka Igaku Zasshi 65:74–80. (Japanese)
Yoshimura T, Kaneko S, Hayabuchi H. 2001. Sex ratio in offspring of those affected by dioxin and dioxin-like compounds: the Yusho, Seveso, and Yucheng incidents. Occup Environ Med 58(8):540–541. 10.1136/oem.58.8.540.11452050
Young AL. 1984. Analysis of dioxins and furans in human adipose tissue. In: Lowrance WW, ed. Public health risks of the dioxins: Proceedings of a symposium held in New York City on October 19–20, 1983. New York, NY: Rockefeller University, 63–75.
Yu M, Hsu C, Gladen BC, 1991. In utero PCB/PCDF exposure: relation of developmental delay to dysmorphology and dose. Neurotoxicol Teratol 13(2):195–202. 10.1016/0892-0362(91)90011-k.1710764
Yu M, Guo YL, Hsu C, 1997. Increased mortality from chronic liver disease and cirrhosis 13 years after the Taiwan "Yucheng" ("oil disease") incident. Am J Ind Med 31(2):172–175. 10.1002(sici)1097-0274(199702)31:2<172::aid-ajim6>3/.0.co;2-1.9028433
Yu M, Hsin J, Hsu C, 1998. The immunologic evaluation of the Yucheng children. Chemosphere 37(9–12):1855–1865. 10.1016/s0045-6535(98)00251-3.9828314
Zacharewski T, Safe L, Safe S, 1989. Comparative analysis of polychlorinated dibenzo-p-dioxin and dibenzofuran congeners in Great Lakes fish extracts by gas chromatography-mass spectrometry and in vitro enzyme induction activities. Environ Sci Technol 23(6):730–735. 10.1021/es00064a012.
Zeytun A, McKallip RJ, Fisher M, 2002. Analysis of 2,3,7,8-tetrachlorodibenzo-p-dioxin-induced gene expression profile in vivo using pathway-specific cDNA arrays. Toxicology 178(3):241–260. 10.1016/s0300-483x(02)00230-5.12167310
Zhang Z, Zhou M, He J, 2020. Polychlorinated dibenzo-dioxins and polychlorinated dibenzo-furans exposure and altered lung function: The mediating role of oxidative stress. Environ Int 137:105521. 10.1016/j.envint.2020.105521.32007688
Zhang F, Wang H, Cui Y, 2022. Association between mixed dioxin exposure and hyperuricemia in U.S. adults: A comparison of three statistical models. Chemosphere 303(Part 3):135134. 10.1016/j.chemosphere.2022.135134.35644240
Zitko V. 1992. Patterns of 2,3,7,8-substituted chlorinated dibenzodioxins and dibenzofurans in aquatic fauna. Sci Total Environ 111(2–3):95–108. 10.1016/0048-9697(92)90349-W.