# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding CDFs in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for CDFs.

Table 7-1 Regulations and Guidelines Applicable to Chlorodibenzofurans (CDFs)

Agency | Description | Information | Reference
Air
EPA | RfC | No data | IRIS 2022
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018a
| National primary drinking water regulations | Not listed | EPA 2009
| RfD | No data | IRIS 2022
WHO | Drinking water quality guidelines | Not listed | WHO 2022
FDA | Substances Added to Food | No data^a^ | FDA 2022
Cancer
HHS | Carcinogenicity classification | No data | NTP 2021
EPA | Carcinogenicity classification | No data | IRIS 2022
IARC | Carcinogenicity classification
| 2,3,4,7,8-PentaCDF | Group 1^b^ | IARC 2012
| 2,3,7,8-TetraCDF | Group 3^d^ | IARC 1997
| 1,2,3,4,7,8-HexaCDF
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction | No data | OSHA 2021a, 2021b, 2021c
NIOSH | REL (up to 10-hour TWA) | No data | NIOSH 2018
Emergency Criteria
EPA | AEGLs-air | Not listed | EPA 2018b
DOE | PACs-air | | DOE 2018a
| 2,3,7,8-TetraCDF and 2,3,4,7,8-pentaCDF
| PAC-1^c^ | 4.30×10^−4^ mg/m^3^
| PAC-2^c^ | 0.0046 mg/m^3^
| PAC-3^c^ | 0.028 mg/m^3^
| 1,2,3,7,8-PentaCDF
| PAC-1^c^ | 0.0043 mg/m^3^
| PAC-2^c^ | 0.046 mg/m^3^
| PAC-3^c^ | 0.28 mg/m^3^
| 1,2,3,4,7,8-HexaCDF, 1,2,3,6,7,8-hexaCDF, 1,2,3,7,8,9-hexaCDF, 2,3,4,6,7,8-hexaCDF, 1,2,3,4,6,7,8-heptaCDF, and 1,2,3,4,7,8,9-heptaCDF
| PAC-1^c^ | 0.0013 mg/m^3^
| PAC-2^c^ | 0.014 mg/m^3^
| PAC-3^c^ | 0.085 mg/m^3^
| 1,2,3,4,6,7,8-HeptaCDF and 1,2,3,4,7,8,9-heptaCDF
| PAC-1^c^ | 0.013 mg/m^3^
| PAC-2^c^ | 0.14 mg/m^3^
| PAC-3^c^ | 0.85 mg/m^3^
| 1,2,3,4,6,7,8,9-OctaCDF
| PAC-1^c^ | 0.43 mg/m^3^
| PAC-2^c^ | 4.7 mg/m^3^
| PAC-3^c^ | 28 mg/m^3^

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b Group 1: carcinogenic to humans.

c Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization