# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Dibenzofuran is an organic compound that contains two benzene rings fused to a central furan ring. CDFs are a class of organic compounds in which one to eight chlorine atoms are attached to the benzene ring positions of a dibenzofuran structure.

Based on the number of chlorine substituents (one to eight) on the benzene rings, there are eight homologues of CDFs (monochlorinated through octachlorinated). Each homologous group contains one or more isomers. There are 135 possible CDF isomers, including 4 monoCDFs, 16 diCDFs, 28 triCDFs, 38 tetraCDFs, 28 pentaCDFs, 16 hexaCDFs, 4 heptaCDFs, and 1 octaCDF. Each one of these compounds is called a congener. Because of molecular asymmetry, CDFs have 135 congeners, compared to 75 for CDDs.

The synonyms, chemical formulas, chemical structure, and identification numbers of selected CDFs are reported in Table 4-1. CDFs that are known or suspected to be most toxic (2,3,7,8-substituted congeners) and other CDFs, for which health effects data are discussed in Chapter 2, have been selected for inclusion in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

CDFs have been synthesized in quantities <1 g. The methods needed to separate the isomeric compounds in a congener series make the isolation of an individual congener difficult. Therefore, data pertaining to the simplest physical and chemical properties of the individual congener are not generally available. The extremely low water solubilities and vapor pressures contribute to the difficulty in determining these and related physico-chemical properties (e.g., K_ow_ and Henry’s law constant) of these compounds. In general, the melting point increases and the vapor pressures and water solubilities of the CDFs decrease as the number of chlorine substituents increases (see Table 4-2). These hydrophobic compounds are generally colorless solids and are soluble in nonpolar organic solvents (Gray et al. 1976). The CDFs are relatively stable towards acid and alkali attack, but they start to decompose at 700°C (van den Berg et al. 1985). The physical and chemical properties of CDFs are given in Table 4-2.

Table 4-1 Chemical Identity of Chlorodibenzofurans (CDFs)

Characteristic | Information
Chemical name | 1,3,7,8-TetraCDF | 2,3,6,8-TetraCDF | 2,3,7,8-TetraCDF | 1,2,3,4,8-PentaCDF
Registered trade name(s) | No data | No data | No data | No data
Chemical formula | C_12_H_4_Cl_4_O | C_12_H_4_Cl_4_O | C_12_H_4_Cl_4_O | C_12_H_3_Cl_5_O
Chemical structure | [image] | [image] | [image] | [image]
CAS Registry Number^a^ | 57117-35-8 | 57117-37-0 | 51207-31-9 | 67517-48-0
Chemical name | 1,2,3,7,8-PentaCDF | 2,3,4,7,8-PentaCDF | 1,2,3,4,7,8-HexaCDF | 1,2,3,6,7,8-HexaCDF
Registered trade name(s) | No data | No data | No data | No data
Chemical formula | C_12_H_3_Cl_5_O | C_12_H_3_Cl_5_O | C_12_H_2_Cl_6_O | C_12_H_2_Cl_6_O
Chemical structure | [image] | [image] | [image] | [image]
CAS Registry Number^a^ | 57117-41-6 | 57117-31-4 | 70648-26-9 | 57117-44-9
Chemical name | 1,2,3,7,8,9-HexaCDF | 1,2,4,6,7,9-HexaCDF | 2,3,4,6,7,8-HexaCDF | 1,2,3,4,6,7,8-HeptaCDF
Registered trade name(s) | No data | No data | No data | No data
Chemical formula | [image] | [image] | [image] | [image]
Chemical structure | C_12_H_2_Cl_6_O | C_12_H_2_Cl_6_O | C_12_H_2_Cl_6_O | C_12_HCl_7_O
CAS Registry Number^a^ | 72918-21-9 | 75627-02-0 | 60851-34-5 | 67562-39-4
Chemical name | 1,2,3,4,6,7,9-HeptaCDF | 1,2,3,4,6,8,9-HeptaCDF | 1,2,3,4,7,8,9-HeptaCDF | 1,2,3,4,6,7,8,9-OctaCDF
Registered trade name(s) | No data | No data | No data | No data
Chemical formula | C_12_HCl_7_O | C_12_HCl_7_O | C_12_HCl_7_O | C_12_Cl_8_O
Chemical structure | [image] | [image] | [image] | [image]
CAS Registry Number^a^ | 70648-25-8 | 69698-58-4 | 55673-89-7 | 39001-02-0

a EPA 1985

CAS = Chemical Abstracts Services

Table 4-2 Physical and Chemical Properties of Chlorodibenzofurans (CDFs)

Property | 1,3,7,8-TetraCDF | 2,3,6,8-TetraCDF | 2,3,7,8-TetraCDF | 1,2,3,4,8-PentaCDF
Molecular weight | 305.9 | 305.9 | 305.9 | 340.42
Color^a^ | No data | Colorless^b^ | Colorless | No data
Physical state^c^ | Solid | Solid | Solid | Solid
Melting point, °C^a^ | No data | 197–198 | 219–221 | 177–178
Boiling point °C | No data | No data | No data | No data
Density at 20°C | No data | No data | No data | No data
Odor | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water^d^ | No data | No data | 1.37×10^−9^ mol/L (0.43 μg/L) | No data
Organic solvents^e^ | Soluble in toluene | Soluble in toluene and chloroform | Soluble in toluene | Soluble in toluene
Partition coefficients:
Log K_ow_^f^ | 6.73 | 6.73 | 6.53 | 6.79
Log K_oc_^h^ | No data | No data | 5.61 (estimated) | No data
pKa | Not applicable | Not applicable | Not applicable | Not applicable
Vapor pressure at 25°C^i^ | 1.95×10^−8j^ | 1.95×10^−8j^ | 9.21×10^−7^ | No data
Henry’s law constant^k^ | 1.48×10^−5^ | 1.48×10^−5^ | 1.48×10^−5^ | 2.63×10^−5^
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors
Air^a^ | 1 ppb = 12.72 μg/m^3^ | 1 ppb = 12.72 μg/m^3^ | 1 ppb = 12.72 μg/m^3^ | 1 ppb = 14.15 μg/m^3^
Water | 1 ppb = 1 μg/L | 1 ppb = 1 μg/L | 1 ppb = 1 μg/L | 1 ppb = 1 μg/L
Soil | 1 ppb = 1 μg/kg | 1 ppb = 1 μg/kg | 1 ppb = 1 μg/kg | 1 ppb = 1 gg/kg
Explosive limits | No data | No data | No data | No data
Property | 1,2,3,7,8-PentaCDF | 2,3,4,7,8-PentaCDF | 1,2,3,4,7,8-HexaCDF | 1,2,3,6,7,8-HexaCDF
Molecular weight | 340.42 | 340.42 | 374.87 | 374.87
Color^a^ | Colorless | No data | No data | No data
Physical state^c^ | Solid | Solid | Solid | Solid
Melting point °C^a^ | 225–227 | 196–16.5 | 225.5–226.5 | 232–234
Boiling point °C | No data | No data | No data | No data
Density at 20°C | No data | No data | No data | No data
Odor | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water^d^ | No data | 6.92×10^−10^ mol/L (0.24 μg/L) | 2.20×10^−11^ mol/L (0.008 μg/L) | 4.72×10^−11^ mol/L (0.018 μg/L)
Organic solvents^e^ | Soluble in hexane^a^ and toluene | Soluble in toluene | Soluble in toluene | Soluble in toluene
Partition coefficients:
Log K_ow_^f^ | 6.79 | 6.92 | No data | No data
Log K_oc_^h^ | No data | No data | No data | No data
pKa | Not applicable | Not applicable | Not applicable | Not applicable
Vapor pressure at 25°C^i^ | 2.73×10^−7^ | 1.63×10^−7^ | 6.07×10^−8^ | 6.07×10^−8^
Henry’s law constant^k^ | 2.63×10^−5^ | 2.63×10^−5^ | 2.78×10^−5^ | 2.78×10^−5^
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors
Air^a^ | 1 ppb = 14.15 μg/m^3^ | 1 ppb = 14.15 μg/m^3^ | 1 ppb = 15.58 μg/m^3^ | 1 ppb = 15.58 μg/m^3^
Water | 1 ppb = 1 μg/L | 1 ppb = 1 μg/L | 1 ppb = 1 μg/L | 1 ppb = 1 μg/L
Soil | 1 ppb = 1 μg/kg | 1 ppb = 1 μg/kg | 1 ppb = 1 μg/kg | 1 ppb = 1 μg/kg
Explosive limits | No data | No data | No data | No data
Property | 1,2,3,7,8,9-HexaCDF | 1,2,3,7,8,9-HexaCDF | 2,3,4,6,7,8-HexaCDF | 1,2,3,4,6,7,8-HeptaCDF
Molecular weight | 374.87 | 374.87 | 374.87 | 409.31
Color^a^ | No data | No data | No data | No data
Physical state^c^ | Solid | Solid | Solid | Solid
Melting point, °C^a^ | No data | 180–181 | 239–240 | 236–237
Boiling point, °C | No data | No data | No data | No data
Density at 20°C | No data | No data | No data | No data
Odor | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water^d^ | No data | No data | No data | 3.31×10^−12^ mol/L (0.014 μg//L)
Organic solvents^e^ | Soluble in toluene | Soluble in toluene | Soluble in toluene | Soluble in toluene
Partition coefficients:
Log K_ow_^f^ | No data | No data | No data | No data
Log K_oc_^h^ | No data | No data | No data | No data
pKa | Not applicable | Not applicable | Not applicable | Not applicable
Vapor pressure at 25°C^i^ | 3.74×10^−8^ | No data | 3.74×10^−8^ | 1.68×10^−8^
Henry’s law constant^k^ | 2.78×10^−5^ | 2.78×10^−5^ | 2.78×10^−5^ | 4.1×10^−6^
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors
Air^a^ | 1 ppb = 15.58 μg/m^3^ | 1 ppb = 15.58 μg/m^3^ | 1 ppb = 15.58 μg/m^3^ | 1 ppb = 17.02 μg/m^3^
Water | 1 ppb = 1 μg/L | 1 ppb = 1 μg/L | 1 ppb = 1 μg/L | 1 ppb = 1 μg/L
Soil | 1 ppb = 1 μg/kg | 1 ppb = 1 μg/kg | 1 ppb = 1 μg/kg | 1 ppb = 1 μg/kg
Explosive limits | No data | No data | No data | No data
Property | 1,2,3,4,6,7,9-HeptaCDF | 1,2,3,4,6,8,9-HeptaCDF | 1,2,3,4,7,8,9-HeptaCDF | 1,2,3,4,6,7,8,9-OctaCDF
Molecular weight | 409.31 | 409.31 | 409.31 | 443.76
Color^a^ | No data | No data | No data | No data
Physical state^c^ | Solid | Solid | Solid | Solid
Melting point, °C^a^ | No data | 211–212 | 212–223 | 25^c^
Boiling point, °C | No data | No data | No data | 537^c^
Density at 20°C | No data | No data | No data | No data
Odor | No data | No data | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water^d^ | No data | No data | No data | 2.61×10^−12^ mol/L (0.0012 μg/L) (3.0 μg/L)^l^
Organic solvents^e^ | Soluble in toluene | Soluble in toluene | Soluble in toluene | Soluble in toluene
Partition coefficients:
Log K_ow_^f^ | No data | No data | No data | 8.20 (7.97)^i^
Log K_oc_^h^ | No data | No data | No data | 8.57 (estimated)
pKa | Not applicable | Not applicable | Not applicable | Not applicable
Vapor pressure at 25°C^i^ | No data | No data | 9.79×10^−9^ | No data
Henry’s law constant^k^ | 4.1×10^−6^ | 4.1×10^−6^ | 4.1×10^−6^ | 1.7×10^−6^
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | No data | No data
Conversion factors
Air^a^ | 1 ppb = 17.02 μg/m^3^ | 1 ppb = 17.02 μg/m^3^ | 1 ppb = 17.02 μg/m^3^ | 1 ppb = 18.45 μg/m^3^
Water | 1 ppb = 1 μg/L | 1 ppb = 1 μg/L | 1 ppb = 1 μg/L | 1 ppb =1 μg/L
Soil | 1 ppb = 1 μg/kg | 1 ppb = 1 μg/kg | 1 ppb = 1 μg/kg | 1 ppb = 1 μg/kg
Explosive limits | No data | No data | No data | No data

a Kuroki et al. 1984 unless otherwise stated.

b The polychlorinated dibenzofurans are present predominantly in the particulate phase in ambient air (Hunt and Maisel 1990).

c WHO 2000.

d Friesen et al. 1990 unless otherwise stated.

e Ryan et al. 1991 unless otherwise stated.

f Sijm et al. 1989 unless otherwise stated; some of the values are for two isomers that could not be separated.

g Burkhard and Kuehl 1986.

h EPA 1985.

i Eitzer and Hites 1988.

j Rordorf 1989.

k Eitzer and Hites 1989a; the values are for unseparated isomers of each homologous series.

l Frank and Schrap 1990.