# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR CDFS

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to CDFs.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for CDFs. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of CDFs have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of CDFs are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for CDFs released for public comment in 2022; thus, the literature search was restricted to studies published between January 2018 and June 2022. The following main databases were searched in June 2022:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for CDFs. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to CDFs were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
06/2022 | ((“Dibenzofurans, Polychlorinated/toxicity”[mh] OR “Dibenzofurans, Polychlorinated/adverse effects”[mh] OR “Dibenzofurans, Polychlorinated/poisoning”[mh] OR “Dibenzofurans, Polychlorinated/pharmacokinetics”[mh]) OR (“Dibenzofurans, Polychlorinated”[mh] AND (“environmental exposure”[mh] OR “occupational groups”[mh] OR ci[sh])) OR (“Dibenzofurans, Polychlorinated”[mh] AND toxicokinetics[mh:noexp]) OR (“Dibenzofurans, Polychlorinated/blood”[mh] OR “Dibenzofurans, Polychlorinated/cerebrospinal fluid”[mh] OR “Dibenzofurans, Polychlorinated/urine”[mh]) OR (“Dibenzofurans, Polychlorinated”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Dibenzofurans, Polychlorinated”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Dibenzofurans, Polychlorinated/antagonists and inhibitors”[mh]) OR (“Dibenzofurans, Polychlorinated/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Dibenzofurans, Polychlorinated/pharmacology”[majr])) AND (2019/06/01:3000[mhda] OR 2019/06/01:3000[crdat] OR 2019/06/01:3000[edat] OR 2019:3000[dp])
| ((“Dibenzofurans, Polychlorinated”[mh]) OR (39001-02-0[rn] OR 51207-31-9[rn] OR 55673-89-7[rn] OR 57117-31-4[rn] OR 57117-35-8[rn] OR 57117-37-0[rn] OR 57117-41-6[rn] OR 57117-44-9[rn] OR 60851-34-5[rn] OR 67517-48-0[rn] OR 67562-39-4[rn] OR 69698-58-4[rn] OR 70648-25-8[rn] OR 70648-26-9[rn] OR 72918-21-9[rn] OR 75627-02-0[rn] OR 42934-53-2[rn] OR 30402-14-3[rn] OR 30402-15-4[rn] OR 55684-94-1[rn] OR 38998-75-3[rn] OR “1,2,3,4,6,7,8-heptachlorodibenzofuran”[nm] OR “1,2,3,4-tetrachlorodibenzofuran”[nm] OR “polychlorodibenzofuran”[nm]) OR (136677-10-6[rn] OR 43047-99-0[rn] OR 51230-49-0[rn] OR 25074-67-3[rn] OR 74992-96-4[rn] OR 94538-00-8[rn] OR 5409-83-6[rn] OR 64560-14-1[rn] OR 54589-71-8[rn] OR 24478-72-6[rn] OR 58802-19-0[rn] OR 58802-20-3[rn] OR 71998-72-6[rn] OR 74992-98-6[rn] OR 43048-00-6[rn] OR 57117-39-2[rn] OR 57117-40-5[rn] OR 57117-43-8[rn] OR 75198-38-8[rn] OR 79060-60-9[rn] OR 91538-83-9[rn] OR 91538-84-0[rn] OR 92341-05-4[rn] OR 92341-06-5[rn] OR 92341-07-6[rn]) OR (“DCDF”[tw] OR “diCDF”[tw] OR “di-CDF”[tw] OR “HCDF”[tw] OR “heptaCDF”[tw] OR “hepta-CDF”[tw] OR “hexaCDF”[tw] OR “hexa-CDF”[tw] OR “HpCDF”[tw] OR “HxCDF”[tw] OR “moCDF”[tw] OR “monoCDF”[tw] OR “mono-CDF”[tw] OR “OCDF”[tw] OR “octaCDF”[tw] OR “octa-CDF”[tw] OR “PCDF”[tw] OR “PeCDF”[tw] OR “pentaCDF”[tw] OR “penta-CDF”[tw] OR “Tcdbf”[tw] OR “TCDF”[tw] OR “tetraCDF”[tw] OR “tetra-CDF”[tw] OR “triCDF”[tw] OR “tri-CDF”[tw]) OR (“DCDFs”[tw] OR “diCDFs”[tw] OR “di-CDFs”[tw] OR “HCDFs”[tw] OR “heptaCDFs”[tw] OR “hepta-CDFs”[tw] OR “hexaCDFs”[tw] OR “hexa-CDFs”[tw] OR “HpCDFs”[tw] OR “HxCDFs”[tw] OR “moCDFs”[tw] OR “monoCDFs”[tw] OR “mono-CDFs”[tw] OR “OCDFs”[tw] OR “octaCDFs”[tw] OR “octa-CDFs”[tw] OR “PCDFs”[tw] OR “PeCDFs”[tw] OR “pentaCDFs”[tw] OR “penta-CDFs”[tw] OR “Tcdbfs”[tw] OR “TCDFs”[tw] OR “tetraCDFs”[tw] OR “tetra-CDFs”[tw] OR “triCDFs”[tw] OR “tri-CDFs”[tw]) OR (“CDF”[tw] AND “Benzofurans”[mh]) OR (“CDFs”[tw] AND “Benzofurans”[mh]) OR (“chlorodibenzofuran”[tw] OR “polychlorodibenzofuran”[tw] OR “monochlorodibenzofuran”[tw] OR “dichlorodibenzofuran”[tw] OR “trichlorodibenzofuran”[tw] OR “tetrachlorodibenzofuran”[tw] OR “pentachlorodibenzofuran”[tw] OR “hexachlorodibenzofuran”[tw] OR “heptachlorodibenzofuran”[tw] OR “octachlorodibenzofuran”[tw] OR “perchlorodibenzofuran”[tw] OR “chlorinated dibenzofuran”[tw] OR “polychlorinated dibenzofuran”[tw]) OR (“chlorodibenzofurans”[tw] OR “polychlorodibenzofurans”[tw] OR “monochlorodibenzofurans”[tw] OR “dichlorodibenzofurans”[tw] OR “trichlorodibenzofurans”[tw] OR “tetrachlorodibenzofurans”[tw] OR “pentachlorodibenzofurans”[tw] OR “hexachlorodibenzofurans”[tw] OR “heptachlorodibenzofurans”[tw] OR “octachlorodibenzofurans”[tw] OR “perchlorodibenzofurans”[tw] OR “chlorinated dibenzofurans”[tw] OR “polychlorinated dibenzofurans”[tw]) OR (“chloro dibenzofuran”[tw] OR “polychloro dibenzofuran”[tw] OR “monochloro dibenzofuran”[tw] OR “dichloro dibenzofuran”[tw] OR “trichloro dibenzofuran”[tw] OR “tetrachloro dibenzofuran”[tw] OR “pentachloro dibenzofuran”[tw] OR “hexachloro dibenzofuran”[tw] OR “heptachloro dibenzofuran”[tw] OR “octachloro dibenzofuran”[tw] OR “perchloro dibenzofuran”[tw]) OR (“chloro dibenzofurans”[tw] OR “polychloro dibenzofurans”[tw] OR “monochloro dibenzofurans”[tw] OR “dichloro dibenzofurans”[tw] OR “trichloro dibenzofurans”[tw] OR “tetrachloro dibenzofurans”[tw] OR “pentachloro dibenzofurans”[tw] OR “hexachloro dibenzofurans”[tw] OR “heptachloro dibenzofurans”[tw] OR “octachloro dibenzofurans”[tw] OR “perchloro dibenzofurans”) OR (“dibenzofuran, chloro-”[tw] OR “dibenzofuran, dichloro-”[tw] OR “dibenzofuran, trichloro-”[tw] OR “dibenzofuran, tetrachloro-”[tw] OR “dibenzofuran, pentachloro-”[tw] OR “dibenzofuran, hexachloro-”[tw] OR “dibenzofuran, heptachloro-”[tw] OR “Dibenzofuran, octachloro-”[tw] OR “monochlordibenzofuran”[tw] OR “chlorinated dibenzo-furan”[tw] OR “polychlorinated dibenzo-furan”[tw]) OR (“chlorinated dibenzo-furans”[tw] OR “dibenzofurans, chlorinated”[tw] OR “hepta chloro furans”[tw] OR “heptachlorofurans”[tw] OR “penta chloro furans”[tw] OR “polychlorinated dibenzo-furans”[tw]) OR ((“chlorinated”[tw] AND “dibenzofuran”[tw]) OR (“polychlorinated”[tw] AND “dibenzofuran”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated”[tw] OR “pentachlorinated”[tw] OR “hexachlorinated”[tw] OR “heptachlorinated”[tw] OR “octachlorinated”[tw] OR “perchlorinated”) AND “dibenzofuran”[tw]) OR ((“dipolychlorinated”[tw] OR “tripolychlorinated”[tw] OR “tetrapolychlorinated”[tw] OR “pentapolychlorinated”[tw] OR “hexapolychlorinated”[tw] OR “heptapolychlorinated”[tw] OR “octapolychlorinated”[tw] OR “perpolychlorinated”[tw] OR “polypolychlorinated”[tw]) AND “dibenzofuran”[tw])) OR ((“chlorinated”[tw] AND “dibenzofurans”[tw]) OR (“polychlorinated”[tw] AND “dibenzofurans”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated''[tw] OR “pentachlorinated''[tw] OR “hexachlorinated''[tw] OR “heptachlorinated''[tw] OR “octachlorinated''[tw] OR “perchlorinated'') AND “dibenzofurans''[tw]) OR ((“dipolychlorinated''[tw] OR “tripolychlorinated''[tw] OR “tetrapolychlorinated''[tw] OR “pentapolychlorinated''[tw] OR “hexapolychlorinated''[tw] OR “heptapolychlorinated''[tw] OR “octapolychlorinated''[tw] OR “perpolychlorinated''[tw] OR “polypolychlorinated''[tw]) AND “dibenzofurans''[tw])) OR (“CDD/F”[tw] OR “DCDD/F ”[tw] OR “diCDD/F”[tw] OR “HCDD/F”[tw] OR “HpCDD/F”[tw] OR “HxCDD/F”[tw] OR “MCDD/F”[tw] OR “moCDD/F”[tw] OR “monoCDD/F”[tw] OR “OCDD/F”[tw] OR “PCDD/F”[tw] OR “PeCDD/F”[tw] OR “TCDD/F”[tw] OR “triCDD/F”[tw] OR “CDD/Fs”[tw] OR “DCDD/Fs”[tw] OR “diCDD/Fs”[tw] OR “HCDD/Fs”[tw] OR “HpCDD/Fs”[tw] OR “HxCDD/Fs”[tw] OR “MCDD/Fs”[tw] OR “moCDD/Fs”[tw] OR “monoCDD/Fs”[tw] OR “OCDD/Fs”[tw] OR “PCDD/Fs”[tw] OR “PeCDD/Fs”[tw] OR “TCDD/Fs”[tw] OR “triCDD/Fs”[tw]) OR (“chlorodiphenylene oxide”[tw] OR “monochlorodiphenylene oxide”[tw] OR “dichlorodiphenylene oxide”[tw] OR “trichlorodiphenylene oxide”[tw] OR “tetrachlorodiphenylene oxide”[tw] OR “pentachlorodiphenylene oxide”[tw] OR “hexachlorodiphenylene oxide”[tw] OR “heptachlorodiphenylene oxide”[tw] OR “octachlorodiphenylene oxide”[tw] OR “perchlorodiphenylene oxide”[tw] OR “polychlorodiphenylene oxide”[tw] OR “chlorodiphenylene oxides”[tw] OR “monochlorodiphenylene oxides”[tw] OR “dichlorodiphenylene oxides”[tw] OR “trichlorodiphenylene oxides”[tw] OR “tetrachlorodiphenylene oxides”[tw] OR “pentachlorodiphenylene oxides”[tw] OR “hexachlorodiphenylene oxides”[tw] OR “heptachlorodiphenylene oxides”[tw] OR “octachlorodiphenylene oxides”[tw] OR “perchlorodiphenylene oxides”[tw] OR “polychlorodiphenylene oxides”[tw]) OR (“12378 PeCDFuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8,9-octachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 2,3,4,7,8-pentachloro-”[tw] OR “Dibenzofuran, 2,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetra-chloro-”[tw]) OR (“Dibenzofuran, 3-chloro-”[tw] OR “Dibenzofuran, 2-chloro-”[tw] OR “Dibenzofuran, 2,4,8-trichloro-”[tw] OR “Dibenzofuran, 1,3-dichloro-”[tw] OR “Dibenzofuran, 2,4,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,3,4-tetrachloro-”[tw] OR “Dibenzofuran, 2,8-dichloro-”[tw] OR “Dibenzofuran, 1,4,8-trichloro-”[tw] OR “Dibenzofuran, 2,3,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 3,4,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7-pentachloro-”[tw] OR “Dibenzofuran, 2,7-dichloro-”[tw] OR “Dibenzofuran, 1,2,3,6,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8,9-hexachloro-”[tw])) AND ((“Benzofurans/toxicity”[mh] OR “Benzofurans/adverse effects”[mh] OR “Benzofurans/poisoning”[mh] OR “Benzofurans/pharmacokinetics”[mh]) OR (“Benzofurans”[mh] AND (“environmental exposure”[mh] OR “occupational groups”[mh] OR ci[sh])) OR (“Benzofurans”[mh] AND toxicokinetics[mh:noexp]) OR (“Benzofurans/blood”[mh] OR “Benzofurans/cerebrospinal fluid”[mh] OR “Benzofurans/urine”[mh]) OR (“Benzofurans”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Benzofurans”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Benzofurans/antagonists and inhibitors”[mh]) OR (“Benzofurans/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Benzofurans/pharmacology”[majr])) AND (2019/06/01:3000[mhda] OR 2019/06/01:3000[crdat] OR 2019/06/01:3000[edat] OR 2019:3000[dp])
| ((“Dibenzofurans, Polychlorinated”[mh]) OR (39001-02-0[rn] OR 51207-31-9[rn] OR 55673-89-7[rn] OR 57117-31-4[rn] OR 57117-35-8[rn] OR 57117-37-0[rn] OR 57117-41-6[rn] OR 57117-44-9[rn] OR 60851-34-5[rn] OR 67517-48-0[rn] OR 67562-39-4[rn] OR 69698-58-4[rn] OR 70648-25-8[rn] OR 70648-26-9[rn] OR 72918-21-9[rn] OR 75627-02-0[rn] OR 42934-53-2[rn] OR 30402-14-3[rn] OR 30402-15-4[rn] OR 55684-94-1[rn] OR 38998-75-3[rn] OR “1,2,3,4,6,7,8-heptachlorodibenzofuran”[nm] OR “1,2,3,4-tetrachlorodibenzofuran”[nm] OR “polychlorodibenzofuran”[nm]) OR (136677-10-6[rn] OR 43047-99-0[rn] OR 51230-49-0[rn] OR 25074-67-3[rn] OR 74992-96-4[rn] OR 94538-00-8[rn] OR 5409-83-6[rn] OR 64560-14-1[rn] OR 54589-71-8[rn] OR 24478-72-6[rn] OR 58802-19-0[rn] OR 58802-20-3[rn] OR 71998-72-6[rn] OR 74992-98-6[rn] OR 43048-00-6[rn] OR 57117-39-2[rn] OR 57117-40-5[rn] OR 57117-43-8[rn] OR 75198-38-8[rn] OR 79060-60-9[rn] OR 91538-83-9[rn] OR 91538-84-0[rn] OR 92341-05-4[rn] OR 92341-06-5[rn] OR 92341-07-6[rn]) OR (“DCDF”[tw] OR “diCDF”[tw] OR “di-CDF”[tw] OR “HCDF”[tw] OR “heptaCDF”[tw] OR “hepta-CDF”[tw] OR “hexaCDF”[tw] OR “hexa-CDF”[tw] OR “HpCDF”[tw] OR “HxCDF”[tw] OR “moCDF”[tw] OR “monoCDF”[tw] OR “mono-CDF”[tw] OR “OCDF”[tw] OR “octaCDF”[tw] OR “octa-CDF”[tw] OR “PCDF”[tw] OR “PeCDF”[tw] OR “pentaCDF”[tw] OR “penta-CDF”[tw] OR “Tcdbf”[tw] OR “TCDF”[tw] OR “tetraCDF”[tw] OR “tetra-CDF”[tw] OR “triCDF”[tw] OR “tri-CDF”[tw]) OR (“DCDFs”[tw] OR “diCDFs”[tw] OR “di-CDFs”[tw] OR “HCDFs”[tw] OR “heptaCDFs”[tw] OR “hepta-CDFs”[tw] OR “hexaCDFs”[tw] OR “hexa-CDFs”[tw] OR “HpCDFs”[tw] OR “HxCDFs”[tw] OR “moCDFs”[tw] OR “monoCDFs”[tw] OR “mono-CDFs”[tw] OR “OCDFs”[tw] OR “octaCDFs”[tw] OR “octa-CDFs”[tw] OR “PCDFs”[tw] OR “PeCDFs”[tw] OR “pentaCDFs”[tw] OR “penta-CDFs”[tw] OR “Tcdbfs”[tw] OR “TCDFs”[tw] OR “tetraCDFs”[tw] OR “tetra-CDFs”[tw] OR “triCDFs”[tw] OR “tri-CDFs”[tw]) OR (“CDF”[tw] AND “Benzofurans”[mh]) OR (“CDFs”[tw] AND “Benzofurans”[mh]) OR (“chlorodibenzofuran”[tw] OR “polychlorodibenzofuran”[tw] OR “monochlorodibenzofuran”[tw] OR “dichlorodibenzofuran”[tw] OR “trichlorodibenzofuran”[tw] OR “tetrachlorodibenzofuran”[tw] OR “pentachlorodibenzofuran”[tw] OR “hexachlorodibenzofuran”[tw] OR “heptachlorodibenzofuran”[tw] OR “octachlorodibenzofuran”[tw] OR “perchlorodibenzofuran”[tw] OR “chlorinated dibenzofuran”[tw] OR “polychlorinated dibenzofuran”[tw]) OR (“chlorodibenzofurans”[tw] OR “polychlorodibenzofurans”[tw] OR “monochlorodibenzofurans”[tw] OR “dichlorodibenzofurans”[tw] OR “trichlorodibenzofurans”[tw] OR “tetrachlorodibenzofurans”[tw] OR “pentachlorodibenzofurans”[tw] OR “hexachlorodibenzofurans”[tw] OR “heptachlorodibenzofurans”[tw] OR “octachlorodibenzofurans”[tw] OR “perchlorodibenzofurans”[tw] OR “chlorinated dibenzofurans”[tw] OR “polychlorinated dibenzofurans”[tw]) OR (“chloro dibenzofuran”[tw] OR “polychloro dibenzofuran”[tw] OR “monochloro dibenzofuran”[tw] OR “dichloro dibenzofuran”[tw] OR “trichloro dibenzofuran”[tw] OR “tetrachloro dibenzofuran”[tw] OR “pentachloro dibenzofuran”[tw] OR “hexachloro dibenzofuran”[tw] OR “heptachloro dibenzofuran”[tw] OR “octachloro dibenzofuran”[tw] OR “perchloro dibenzofuran”[tw]) OR (“chloro dibenzofurans”[tw] OR “polychloro dibenzofurans”[tw] OR “monochloro dibenzofurans”[tw] OR “dichloro dibenzofurans”[tw] OR “trichloro dibenzofurans”[tw] OR “tetrachloro dibenzofurans”[tw] OR “pentachloro dibenzofurans”[tw] OR “hexachloro dibenzofurans”[tw] OR “heptachloro dibenzofurans”[tw] OR “octachloro dibenzofurans”[tw] OR “perchloro dibenzofurans”) OR (“dibenzofuran, chloro-”[tw] OR “dibenzofuran, dichloro-”[tw] OR “dibenzofuran, trichloro-”[tw] OR “dibenzofuran, tetrachloro-”[tw] OR “dibenzofuran, pentachloro-”[tw] OR “dibenzofuran, hexachloro-”[tw] OR “dibenzofuran, heptachloro-”[tw] OR “Dibenzofuran, octachloro-”[tw] OR “monochlordibenzofuran”[tw] OR “chlorinated dibenzo-furan”[tw] OR “polychlorinated dibenzo-furan”[tw]) OR (“chlorinated dibenzo-furans”[tw] OR “dibenzofurans, chlorinated”[tw] OR “hepta chloro furans”[tw] OR “heptachlorofurans”[tw] OR “penta chloro furans”[tw] OR “polychlorinated dibenzo-furans”[tw]) OR ((“chlorinated”[tw] AND “dibenzofuran”[tw]) OR (“polychlorinated”[tw] AND “dibenzofuran”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated”[tw] OR “pentachlorinated”[tw] OR “hexachlorinated”[tw] OR “heptachlorinated”[tw] OR “octachlorinated”[tw] OR “perchlorinated”) AND “dibenzofuran”[tw]) OR ((“dipolychlorinated”[tw] OR “tripolychlorinated”[tw] OR “tetrapolychlorinated”[tw] OR “pentapolychlorinated”[tw] OR “hexapolychlorinated”[tw] OR “heptapolychlorinated”[tw] OR “octapolychlorinated”[tw] OR “perpolychlorinated”[tw] OR “polypolychlorinated”[tw]) AND “dibenzofuran”[tw])) OR ((“chlorinated”[tw] AND “dibenzofurans”[tw]) OR (“polychlorinated”[tw] AND “dibenzofurans”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated”[tw] OR “pentachlorinated”[tw] OR “hexachlorinated”[tw] OR “heptachlorinated”[tw] OR “octachlorinated”[tw] OR “perchlorinated”) AND “dibenzofurans”[tw]) OR ((“dipolychlorinated”[tw] OR “tripolychlorinated”[tw] OR “tetrapolychlorinated”[tw] OR “pentapolychlorinated”[tw] OR “hexapolychlorinated”[tw] OR “heptapolychlorinated”[tw] OR “octapolychlorinated”[tw] OR “perpolychlorinated”[tw] OR “polypolychlorinated”[tw]) AND “dibenzofurans”[tw])) OR (“CDD/F”[tw] OR “DCDD/F”[tw] OR “diCDD/F”[tw] OR “HCDD/F”[tw] OR “HpCDD/F”[tw] OR “HxCDD/F”[tw] OR “MCDD/F”[tw] OR “moCDD/F”[tw] OR “monoCDD/F”[tw] OR “OCDD/F”[tw] OR “PCDD/F”[tw] OR “PeCDD/F”[tw] OR “TCDD/F”[tw] OR “triCDD/F”[tw] OR “CDD/Fs”[tw] OR “DCDD/Fs”[tw] OR “diCDD/Fs”[tw] OR “HCDD/Fs”[tw] OR “HpCDD/Fs”[tw] OR “HxCDD/Fs”[tw] OR “MCDD/Fs”[tw] OR “moCDD/Fs”[tw] OR “monoCDD/Fs”[tw] OR “OCDD/Fs”[tw] OR “PCDD/Fs”[tw] OR “PeCDD/Fs”[tw] OR “TCDD/Fs”[tw] OR “triCDD/Fs”[tw]) OR (“chlorodiphenylene oxide”[tw] OR “monochlorodiphenylene oxide”[tw] OR “dichlorodiphenylene oxide”[tw] OR “trichlorodiphenylene oxide”[tw] OR “tetrachlorodiphenylene oxide”[tw] OR “pentachlorodiphenylene oxide”[tw] OR “hexachlorodiphenylene oxide”[tw] OR “heptachlorodiphenylene oxide”[tw] OR “octachlorodiphenylene oxide”[tw] OR “perchlorodiphenylene oxide”[tw] OR “polychlorodiphenylene oxide”[tw] OR “chlorodiphenylene oxides”[tw] OR “monochlorodiphenylene oxides”[tw] OR “dichlorodiphenylene oxides”[tw] OR “trichlorodiphenylene oxides”[tw] OR “tetrachlorodiphenylene oxides”[tw] OR “pentachlorodiphenylene oxides”[tw] OR “hexachlorodiphenylene oxides”[tw] OR “heptachlorodiphenylene oxides”[tw] OR “octachlorodiphenylene oxides”[tw] OR “perchlorodiphenylene oxides”[tw] OR “polychlorodiphenylene oxides”[tw]) OR (“12378 PeCDFuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8,9-octachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 2,3,4,7,8-pentachloro-”[tw] OR “Dibenzofuran, 2,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetra-chloro-”[tw]) OR (“Dibenzofuran, 3-chloro-”[tw] OR “Dibenzofuran, 2-chloro-”[tw] OR “Dibenzofuran, 2,4,8-trichloro-”[tw] OR “Dibenzofuran, 1,3-dichloro-”[tw] OR “Dibenzofuran, 2,4,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,3,4-tetrachloro-”[tw] OR “Dibenzofuran, 2,8-dichloro-”[tw] OR “Dibenzofuran, 1,4,8-trichloro-”[tw] OR “Dibenzofuran, 2,3,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 3,4,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7-pentachloro-”[tw] OR “Dibenzofuran, 2,7-dichloro-”[tw] OR “Dibenzofuran, 1,2,3,6,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8,9-hexachloro-”[tw])) AND ((“Dioxins/toxicity”[mh] OR “Dioxins/adverse effects”[mh] OR “Dioxins/poisoning”[mh] OR “Dioxins/pharmacokinetics”[mh]) OR (“Dioxins”[mh] AND (“environmental exposure”[mh] OR “occupational groups”[mh] OR ci[sh])) OR (“Dioxins”[mh] AND toxicokinetics[mh:noexp]) OR (“Dioxins/blood”[mh] OR “Dioxins/cerebrospinal fluid”[mh] OR “Dioxins/urine”[mh]) OR (“Dioxins”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Dioxins”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Dioxins/antagonists and inhibitors”[mh]) OR (“Dioxins/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Dioxins/pharmacology”[majr])) AND (2019/06/01:3000[mhda] OR 2019/06/01:3000[crdat] OR 2019/06/01:3000[edat] OR 2019:3000[dp])
| ((((“DCDF”[tw] OR “diCDF”[tw] OR “di-CDF”[tw] OR “HCDF”[tw] OR “heptaCDF”[tw] OR “hepta-CDF”[tw] OR “hexaCDF”[tw] OR “hexa-CDF”[tw] OR “HpCDF”[tw] OR “HxCDF”[tw] OR “moCDF”[tw] OR “monoCDF”[tw] OR “mono-CDF”[tw] OR “OCDF”[tw] OR “octaCDF”[tw] OR “octa-CDF”[tw] OR “PCDF”[tw] OR “PeCDF”[tw] OR “pentaCDF”[tw] OR “penta-CDF”[tw] OR “Tcdbf”[tw] OR “TCDF”[tw] OR “tetraCDF”[tw] OR “tetra-CDF”[tw] OR “triCDF”[tw] OR “tri-CDF”[tw]) OR (“DCDFs”[tw] OR “diCDFs”[tw] OR “di-CDFs”[tw] OR “HCDFs”[tw] OR “heptaCDFs”[tw] OR “hepta-CDFs”[tw] OR “hexaCDFs”[tw] OR “hexa-CDFs”[tw] OR “HpCDFs”[tw] OR “HxCDFs”[tw] OR “moCDFs”[tw] OR “monoCDFs”[tw] OR “mono-CDFs”[tw] OR “OCDFs”[tw] OR “octaCDFs”[tw] OR “octa-CDFs”[tw] OR “PCDFs”[tw] OR “PeCDFs”[tw] OR “pentaCDFs”[tw] OR “penta-CDFs”[tw] OR “Tcdbfs”[tw] OR “TCDFs”[tw] OR “tetraCDFs”[tw] OR “tetra-CDFs”[tw] OR “triCDFs”[tw] OR “tri-CDFs”[tw]) OR (“CDF”[tw] AND “Benzofurans”[mh]) OR (“CDFs”[tw] AND “Benzofurans”[mh]) OR (“chlorodibenzofuran”[tw] OR “polychlorodibenzofuran”[tw] OR “monochlorodibenzofuran”[tw] OR “dichlorodibenzofuran”[tw] OR “trichlorodibenzofuran”[tw] OR “tetrachlorodibenzofuran”[tw] OR “pentachlorodibenzofuran”[tw] OR “hexachlorodibenzofuran”[tw] OR “heptachlorodibenzofuran”[tw] OR “octachlorodibenzofuran”[tw] OR “perchlorodibenzofuran”[tw] OR “chlorinated dibenzofuran”[tw] OR “polychlorinated dibenzofuran”[tw]) OR (“chlorodibenzofurans”[tw] OR “polychlorodibenzofurans”[tw] OR “monochlorodibenzofurans”[tw] OR “dichlorodibenzofurans”[tw] OR “trichlorodibenzofurans”[tw] OR “tetrachlorodibenzofurans”[tw] OR “pentachlorodibenzofurans”[tw] OR “hexachlorodibenzofurans”[tw] OR “heptachlorodibenzofurans”[tw] OR “octachlorodibenzofurans”[tw] OR “perchlorodibenzofurans”[tw] OR “chlorinated dibenzofurans”[tw] OR “polychlorinated dibenzofurans”[tw]) OR (“chloro dibenzofuran”[tw] OR “polychloro dibenzofuran”[tw] OR “monochloro dibenzofuran”[tw] OR “dichloro dibenzofuran”[tw] OR “trichloro dibenzofuran”[tw] OR “tetrachloro dibenzofuran”[tw] OR “pentachloro dibenzofuran”[tw] OR “hexachloro dibenzofuran”[tw] OR “heptachloro dibenzofuran”[tw] OR “octachloro dibenzofuran”[tw] OR “perchloro dibenzofuran”[tw]) OR (“chloro dibenzofurans”[tw] OR “polychloro dibenzofurans”[tw] OR “monochloro dibenzofurans”[tw] OR “dichloro dibenzofurans”[tw] OR “trichloro dibenzofurans”[tw] OR “tetrachloro dibenzofurans”[tw] OR “pentachloro dibenzofurans”[tw] OR “hexachloro dibenzofurans”[tw] OR “heptachloro dibenzofurans”[tw] OR “octachloro dibenzofurans”[tw] OR “perchloro dibenzofurans”) OR (“dibenzofuran, chloro-”[tw] OR “dibenzofuran, dichloro-”[tw] OR “dibenzofuran, trichloro-”[tw] OR “dibenzofuran, tetrachloro-”[tw] OR “dibenzofuran, pentachloro-”[tw] OR “dibenzofuran, hexachloro-”[tw] OR “dibenzofuran, heptachloro-”[tw] OR “Dibenzofuran, octachloro-”[tw] OR “monochlordibenzofuran”[tw] OR “chlorinated dibenzo-furan”[tw] OR “polychlorinated dibenzo-furan”[tw]) OR (“chlorinated dibenzo-furans”[tw] OR “dibenzofurans, chlorinated”[tw] OR “hepta chloro furans”[tw] OR “heptachlorofurans”[tw] OR “penta chloro furans”[tw] OR “polychlorinated dibenzo-furans”[tw]) OR ((“chlorinated”[tw] AND “dibenzofuran”[tw]) OR (“polychlorinated”[tw] AND “dibenzofuran”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated”[tw] OR “pentachlorinated”[tw] OR “hexachlorinated”[tw] OR “heptachlorinated”[tw] OR “octachlorinated”[tw] OR “perchlorinated”) AND “dibenzofuran”[tw]) OR ((“dipolychlorinated”[tw] OR “tripolychlorinated”[tw] OR “tetrapolychlorinated”[tw] OR “pentapolychlorinated”[tw] OR “hexapolychlorinated”[tw] OR “heptapolychlorinated”[tw] OR “octapolychlorinated”[tw] OR “perpolychlorinated”[tw] OR “polypolychlorinated”[tw]) AND “dibenzofuran”[tw])) OR ((“chlorinated”[tw] AND “dibenzofurans”[tw]) OR (“polychlorinated”[tw] AND “dibenzofurans”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated”[tw] OR “pentachlorinated”[tw] OR “hexachlorinated”[tw] OR “heptachlorinated”[tw] OR “octachlorinated”[tw] OR “perchlorinated”) AND “dibenzofurans”[tw]) OR ((“dipolychlorinated”[tw] OR “tripolychlorinated”[tw] OR “tetrapolychlorinated”[tw] OR “pentapolychlorinated”[tw] OR “hexapolychlorinated”[tw] OR “heptapolychlorinated”[tw] OR “octapolychlorinated”[tw] OR “perpolychlorinated”[tw] OR “polypolychlorinated”[tw]) AND “dibenzofurans”[tw])) OR (“CDD/F”[tw] OR “DCDD/F”[tw] OR “diCDD/F”[tw] OR “HCDD/F”[tw] OR “HpCDD/F”[tw] OR “HxCDD/F”[tw] OR “MCDD/F”[tw] OR “moCDD/F”[tw] OR “monoCDD/F”[tw] OR “OCDD/F”[tw] OR “PCDD/F”[tw] OR “PeCDD/F”[tw] OR “TCDD/F”[tw] OR “triCDD/F”[tw] OR “CDD/Fs”[tw] OR “DCDD/Fs”[tw] OR “diCDD/Fs”[tw] OR “HCDD/Fs”[tw] OR “HpCDD/Fs”[tw] OR “HxCDD/Fs”[tw] OR “MCDD/Fs”[tw] OR “moCDD/Fs”[tw] OR “monoCDD/Fs”[tw] OR “OCDD/Fs”[tw] OR “PCDD/Fs”[tw] OR “PeCDD/Fs”[tw] OR “TCDD/Fs”[tw] OR “triCDD/Fs”[tw]) OR (“chlorodiphenylene oxide”[tw] OR “monochlorodiphenylene oxide”[tw] OR “dichlorodiphenylene oxide”[tw] OR “trichlorodiphenylene oxide”[tw] OR “tetrachlorodiphenylene oxide”[tw] OR “pentachlorodiphenylene oxide”[tw] OR “hexachlorodiphenylene oxide”[tw] OR “heptachlorodiphenylene oxide”[tw] OR “octachlorodiphenylene oxide”[tw] OR “perchlorodiphenylene oxide”[tw] OR “polychlorodiphenylene oxide”[tw] OR “chlorodiphenylene oxides”[tw] OR “monochlorodiphenylene oxides”[tw] OR “dichlorodiphenylene oxides”[tw] OR “trichlorodiphenylene oxides”[tw] OR “tetrachlorodiphenylene oxides”[tw] OR “pentachlorodiphenylene oxides”[tw] OR “hexachlorodiphenylene oxides”[tw] OR “heptachlorodiphenylene oxides”[tw] OR “octachlorodiphenylene oxides”[tw] OR “perchlorodiphenylene oxides”[tw] OR “polychlorodiphenylene oxides”[tw]) OR (“12378 PeCDFuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8,9-octachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 2,3,4,7,8-pentachloro-”[tw] OR “Dibenzofuran, 2,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetra-chloro-”[tw]) OR (“Dibenzofuran, 3-chloro-”[tw] OR “Dibenzofuran, 2-chloro-”[tw] OR “Dibenzofuran, 2,4,8-trichloro-”[tw] OR “Dibenzofuran, 1,3-dichloro-”[tw] OR “Dibenzofuran, 2,4,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,3,4-tetrachloro-”[tw] OR “Dibenzofuran, 2,8-dichloro-”[tw] OR “Dibenzofuran, 1,4,8-trichloro-”[tw] OR “Dibenzofuran, 2,3,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 3,4,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7-pentachloro-”[tw] OR “Dibenzofuran, 2,7-dichloro-”[tw] OR “Dibenzofuran, 1,2,3,6,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8,9-hexachloro-”[tw]))) NOT medline[sb]) AND (2019/06/01:3000[mhda] OR 2019/06/01:3000[crdat] OR 2019/06/01:3000[edat] OR 2019:3000[dp])
| ((((“Dibenzofurans, Polychlorinated”[mh]) OR (39001-02-0[rn] OR 51207-31-9[rn] OR 55673-89-7[rn] OR 57117-31-4[rn] OR 57117-35-8[rn] OR 57117-37-0[rn] OR 57117-41-6[rn] OR 57117-44-9[rn] OR 60851-34-5[rn] OR 67517-48-0[rn] OR 67562-39-4[rn] OR 69698-58-4[rn] OR 70648-25-8[rn] OR 70648-26-9[rn] OR 72918-21-9[rn] OR 75627-02-0[rn] OR 42934-53-2[rn] OR 30402-14-3[rn] OR 30402-15-4[rn] OR 55684-94-1[rn] OR 38998-75-3[rn] OR “1,2,3,4,6,7,8-heptachlorodibenzofuran”[nm] OR “1,2,3,4-tetrachlorodibenzofuran”[nm] OR “polychlorodibenzofuran”[nm]) OR (136677-10-6[rn] OR 43047-99-0[rn] OR 51230-49-0[rn] OR 25074-67-3[rn] OR 74992-96-4[rn] OR 94538-00-8[rn] OR 5409-83-6[rn] OR 64560-14-1[rn] OR 54589-71-8[rn] OR 24478-72-6[rn] OR 58802-19-0[rn] OR 58802-20-3[rn] OR 71998-72-6[rn] OR 74992-98-6[rn] OR 43048-00-6[rn] OR 57117-39-2[rn] OR 57117-40-5[rn] OR 57117-43-8[rn] OR 75198-38-8[rn] OR 79060-60-9[rn] OR 91538-83-9[rn] OR 91538-84-0[rn] OR 92341-05-4[rn] OR 92341-06-5[rn] OR 92341-07-6[rn]) OR (“DCDF”[tw] OR “diCDF”[tw] OR “di-CDF”[tw] OR “HCDF”[tw] OR “heptaCDF”[tw] OR “hepta-CDF”[tw] OR “hexaCDF”[tw] OR “hexa-CDF”[tw] OR “HpCDF”[tw] OR “HxCDF”[tw] OR “moCDF”[tw] OR “monoCDF”[tw] OR “mono-CDF”[tw] OR “OCDF”[tw] OR “octaCDF”[tw] OR “octa-CDF”[tw] OR “PCDF”[tw] OR “PeCDF”[tw] OR “pentaCDF”[tw] OR “penta-CDF”[tw] OR “Tcdbf ”[tw] OR “TCDF”[tw] OR “tetraCDF”[tw] OR “tetra-CDF”[tw] OR “triCDF”[tw] OR “tri-CDF”[tw]) OR (“DCDFs”[tw] OR “diCDFs”[tw] OR “di-CDFs”[tw] OR “HCDFs”[tw] OR “heptaCDFs”[tw] OR “hepta-CDFs”[tw] OR “hexaCDFs”[tw] OR “hexa-CDFs”[tw] OR “HpCDFs”[tw] OR “HxCDFs”[tw] OR “moCDFs”[tw] OR “monoCDFs”[tw] OR “mono-CDFs”[tw] OR “OCDFs”[tw] OR “octaCDFs”[tw] OR “octa-CDFs”[tw] OR “PCDFs”[tw] OR “PeCDFs”[tw] OR “pentaCDFs”[tw] OR “penta-CDFs”[tw] OR “Tcdbfs”[tw] OR “TCDFs”[tw] OR “tetraCDFs”[tw] OR “tetra-CDFs”[tw] OR “triCDFs”[tw] OR “tri-CDFs”[tw]) OR (“CDF”[tw] AND “Benzofurans”[mh]) OR (“CDFs”[tw] AND “Benzofurans”[mh]) OR (“chlorodibenzofuran”[tw] OR “polychlorodibenzofuran”[tw] OR “monochlorodibenzofuran”[tw] OR “dichlorodibenzofuran”[tw] OR “trichlorodibenzofuran”[tw] OR “tetrachlorodibenzofuran”[tw] OR “pentachlorodibenzofuran”[tw] OR “hexachlorodibenzofuran”[tw] OR “heptachlorodibenzofuran”[tw] OR “octachlorodibenzofuran”[tw] OR “perchlorodibenzofuran”[tw] OR “chlorinated dibenzofuran”[tw] OR “polychlorinated dibenzofuran”[tw]) OR (“chlorodibenzofurans”[tw] OR “polychlorodibenzofurans”[tw] OR “monochlorodibenzofurans”[tw] OR “dichlorodibenzofurans”[tw] OR “trichlorodibenzofurans”[tw] OR “tetrachlorodibenzofurans”[tw] OR “pentachlorodibenzofurans”[tw] OR “hexachlorodibenzofurans”[tw] OR “heptachlorodibenzofurans”[tw] OR “octachlorodibenzofurans”[tw] OR “perchlorodibenzofurans”[tw] OR “chlorinated dibenzofurans”[tw] OR “polychlorinated dibenzofurans”[tw]) OR (“chloro dibenzofuran”[tw] OR “polychloro dibenzofuran”[tw] OR “monochloro dibenzofuran”[tw] OR “dichloro dibenzofuran”[tw] OR “trichloro dibenzofuran”[tw] OR “tetrachloro dibenzofuran”[tw] OR “pentachloro dibenzofuran”[tw] OR “hexachloro dibenzofuran”[tw] OR “heptachloro dibenzofuran”[tw] OR “octachloro dibenzofuran”[tw] OR “perchloro dibenzofuran”[tw]) OR (“chloro dibenzofurans”[tw] OR “polychloro dibenzofurans”[tw] OR “monochloro dibenzofurans”[tw] OR “dichloro dibenzofurans”[tw] OR “trichloro dibenzofurans”[tw] OR “tetrachloro dibenzofurans”[tw] OR “pentachloro dibenzofurans”[tw] OR “hexachloro dibenzofurans”[tw] OR “heptachloro dibenzofurans”[tw] OR “octachloro dibenzofurans”[tw] OR “perchloro dibenzofurans”) OR (“dibenzofuran, chloro-”[tw] OR “dibenzofuran, dichloro-”[tw] OR “dibenzofuran, trichloro-”[tw] OR “dibenzofuran, tetrachloro-”[tw] OR “dibenzofuran, pentachloro-”[tw] OR “dibenzofuran, hexachloro-”[tw] OR “dibenzofuran, heptachloro-”[tw] OR “Dibenzofuran, octachloro-”[tw] OR “monochlordibenzofuran”[tw] OR “chlorinated dibenzo-furan”[tw] OR “polychlorinated dibenzo-furan”[tw]) OR (“chlorinated dibenzo-furans”[tw] OR “dibenzofurans, chlorinated”[tw] OR “hepta chloro furans”[tw] OR “heptachlorofurans”[tw] OR “penta chloro furans”[tw] OR “polychlorinated dibenzo-furans”[tw]) OR ((“chlorinated”[tw] AND “dibenzofuran”[tw]) OR (“polychlorinated”[tw] AND “dibenzofuran”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated”[tw] OR “pentachlorinated”[tw] OR “hexachlorinated”[tw] OR “heptachlorinated”[tw] OR “octachlorinated”[tw] OR “perchlorinated”) AND “dibenzofuran”[tw]) OR ((“dipolychlorinated”[tw] OR “tripolychlorinated”[tw] OR “tetrapolychlorinated”[tw] OR “pentapolychlorinated”[tw] OR “hexapolychlorinated”[tw] OR “heptapolychlorinated”[tw] OR “octapolychlorinated”[tw] OR “perpolychlorinated”[tw] OR “polypolychlorinated”[tw]) AND “dibenzofuran”[tw])) OR ((“chlorinated”[tw] AND “dibenzofurans”[tw]) OR (“polychlorinated”[tw] AND “dibenzofurans”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated”[tw] OR “pentachlorinated”[tw] OR “hexachlorinated”[tw] OR “heptachlorinated”[tw] OR “octachlorinated”[tw] OR “perchlorinated”) AND “dibenzofurans”[tw]) OR ((“dipolychlorinated”[tw] OR “tripolychlorinated”[tw] OR “tetrapolychlorinated”[tw] OR “pentapolychlorinated”[tw] OR “hexapolychlorinated”[tw] OR “heptapolychlorinated”[tw] OR “octapolychlorinated”[tw] OR “perpolychlorinated”[tw] OR “polypolychlorinated”[tw]) AND “dibenzofurans”[tw])) OR (“CDD/F”[tw] OR “DCDD/F”[tw] OR “diCDD/F”[tw] OR “HCDD/F”[tw] OR “HpCDD/F”[tw] OR “HxCDD/F”[tw] OR “MCDD/F”[tw] OR “moCDD/F”[tw] OR “monoCDD/F”[tw] OR “OCDD/F”[tw] OR “PCDD/F”[tw] OR “PeCDD/F”[tw] OR “TCDD/F”[tw] OR “triCDD/F”[tw] OR “CDD/Fs”[tw] OR “DCDD/Fs”[tw] OR “diCDD/Fs”[tw] OR “HCDD/Fs”[tw] OR “HpCDD/Fs”[tw] OR “HxCDD/Fs”[tw] OR “MCDD/Fs”[tw] OR “moCDD/Fs”[tw] OR “monoCDD/Fs”[tw] OR “OCDD/Fs”[tw] OR “PCDD/Fs”[tw] OR “PeCDD/Fs”[tw] OR “TCDD/Fs”[tw] OR “triCDD/Fs”[tw]) OR (“chlorodiphenylene oxide”[tw] OR “monochlorodiphenylene oxide”[tw] OR “dichlorodiphenylene oxide”[tw] OR “trichlorodiphenylene oxide”[tw] OR “tetrachlorodiphenylene oxide”[tw] OR “pentachlorodiphenylene oxide”[tw] OR “hexachlorodiphenylene oxide”[tw] OR “heptachlorodiphenylene oxide”[tw] OR “octachlorodiphenylene oxide”[tw] OR “perchlorodiphenylene oxide”[tw] OR “polychlorodiphenylene oxide”[tw] OR “chlorodiphenylene oxides”[tw] OR “monochlorodiphenylene oxides”[tw] OR “dichlorodiphenylene oxides”[tw] OR “trichlorodiphenylene oxides”[tw] OR “tetrachlorodiphenylene oxides”[tw] OR “pentachlorodiphenylene oxides”[tw] OR “hexachlorodiphenylene oxides”[tw] OR “heptachlorodiphenylene oxides”[tw] OR “octachlorodiphenylene oxides”[tw] OR “perchlorodiphenylene oxides”[tw] OR “polychlorodiphenylene oxides”[tw]) OR (“12378 PeCDFuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8,9-octachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 2,3,4,7,8-pentachloro-”[tw] OR “Dibenzofuran, 2,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetra-chloro-”[tw]) OR (“Dibenzofuran, 3-chloro-”[tw] OR “Dibenzofuran, 2-chloro-”[tw] OR “Dibenzofuran, 2,4,8-trichloro-”[tw] OR “Dibenzofuran, 1,3-dichloro-”[tw] OR “Dibenzofuran, 2,4,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,3,4-tetrachloro-”[tw] OR ”Dibenzofuran, 2,8-dichloro-”[tw] OR “Dibenzofuran, 1,4,8-trichloro-”[tw] OR “Dibenzofuran, 2,3,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 3,4,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7-pentachloro-”[tw] OR “Dibenzofuran, 2,7-dichloro-”[tw] OR “Dibenzofuran, 1,2,3,6,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8,9-hexachloro-”[tw])) AND (“Dibenzofurans, Polychlorinated”[mh] OR “Benzofurans”[mh] OR “Dioxins”[mh]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “occupational groups”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR “pharmacology”[sh:noexp] OR toxicokinetics[mh:noexp] OR “Polychlorinated Dibenzodioxins/antagonists and inhibitors”[MeSH Terms] OR “Benzofurans/antagonists and inhibitors”[MeSH Terms] OR “Dioxins/antagonists and inhibitors”[MeSH Terms])) AND (2019/06/01:3000[mhda] OR 2019/06/01:3000[crdat] OR 2019/06/01:3000[edat] OR 2019:3000[dp])) OR ((dioxin human toxicity) AND (2020/05/20:3000[mhda] OR 2020/05/20:3000[crdat] OR 2020/05/20:3000[edat]))
| (((“Dibenzofurans, Polychlorinated”[mh]) OR (39001-02-0[rn] OR 51207-31-9[rn] OR 55673-89-7[rn] OR 57117-31-4[rn] OR 57117-35-8[rn] OR 57117-37-0[rn] OR 57117-41-6[rn] OR 57117-44-9[rn] OR 60851-34-5[rn] OR 67517-48-0[rn] OR 67562-39-4[rn] OR 69698-58-4[rn] OR 70648-25-8[rn] OR 70648-26-9[rn] OR 72918-21-9[rn] OR 75627-02-0[rn] OR 42934-53-2[rn] OR 30402-14-3[rn] OR 30402-15-4[rn] OR 55684-94-1[rn] OR 38998-75-3[rn] OR “1,2,3,4,6,7,8-heptachlorodibenzofuran”[nm] OR “1,2,3,4-tetrachlorodibenzofuran”[nm] OR “polychlorodibenzofuran”[nm]) OR (136677-10-6[rn] OR 43047-99-0[rn] OR 51230-49-0[rn] OR 25074-67-3[rn] OR 74992-96-4[rn] OR 94538-00-8[rn] OR 5409-83-6[rn] OR 64560-14-1[rn] OR 54589-71-8[rn] OR 24478-72-6[rn] OR 58802-19-0[rn] OR 58802-20-3[rn] OR 71998-72-6[rn] OR 74992-98-6[rn] OR 43048-00-6[rn] OR 57117-39-2[rn] OR 57117-40-5[rn] OR 57117-43-8[rn] OR 75198-38-8[rn] OR 79060-60-9[rn] OR 91538-83-9[rn] OR 91538-84-0[rn] OR 92341-05-4[rn] OR 92341-06-5[rn] OR 92341-07-6[rn]) OR (“DCDF”[tw] OR “diCDF”[tw] OR “di-CDF”[tw] OR “HCDF”[tw] OR “heptaCDF”[tw] OR “hepta-CDF”[tw] OR “hexaCDF”[tw] OR “hexa-CDF”[tw] OR “HpCDF”[tw] OR “HxCDF”[tw] OR “moCDF”[tw] OR “monoCDF”[tw] OR “mono-CDF”[tw] OR “OCDF”[tw] OR “octaCDF”[tw] OR “octa-CDF”[tw] OR “PCDF”[tw] OR “PeCDF”[tw] OR “pentaCDF”[tw] OR “penta-CDF”[tw] OR “Tcdbf”[tw] OR “TCDF”[tw] OR “tetraCDF”[tw] OR “tetra-CDF”[tw] OR “triCDF”[tw] OR “tri-CDF”[tw]) OR (“DCDFs”[tw] OR “diCDFs”[tw] OR “di-CDFs”[tw] OR “HCDFs”[tw] OR “heptaCDFs”[tw] OR “hepta-CDFs”[tw] OR “hexaCDFs”[tw] OR “hexa-CDFs”[tw] OR “HpCDFs”[tw] OR “HxCDFs”[tw] OR “moCDFs”[tw] OR “monoCDFs”[tw] OR “mono-CDFs”[tw] OR “OCDFs”[tw] OR “octaCDFs”[tw] OR “octa-CDFs”[tw] OR “PCDFs”[tw] OR “PeCDFs”[tw] OR “pentaCDFs”[tw] OR “penta-CDFs”[tw] OR “Tcdbfs”[tw] OR “TCDFs”[tw] OR “tetraCDFs”[tw] OR “tetra-CDFs”[tw] OR “triCDFs”[tw] OR “tri-CDFs”[tw]) OR (“CDF”[tw] AND “Benzofurans”[mh]) OR (“CDFs”[tw] AND “Benzofurans”[mh]) OR (“chlorodibenzofuran”[tw] OR “polychlorodibenzofuran”[tw] OR “monochlorodibenzofuran”[tw] OR “dichlorodibenzofuran”[tw] OR “trichlorodibenzofuran”[tw] OR “tetrachlorodibenzofuran”[tw] OR “pentachlorodibenzofuran”[tw] OR “hexachlorodibenzofuran”[tw] OR “heptachlorodibenzofuran”[tw] OR “octachlorodibenzofuran”[tw] OR “perchlorodibenzofuran”[tw] OR “chlorinated dibenzofuran”[tw] OR “polychlorinated dibenzofuran”[tw]) OR (“chlorodibenzofurans”[tw] OR “polychlorodibenzofurans”[tw] OR “monochlorodibenzofurans”[tw] OR “dichlorodibenzofurans”[tw] OR “trichlorodibenzofurans”[tw] OR “tetrachlorodibenzofurans”[tw] OR “pentachlorodibenzofurans”[tw] OR “hexachlorodibenzofurans”[tw] OR “heptachlorodibenzofurans”[tw] OR “octachlorodibenzofurans”[tw] OR “perchlorodibenzofurans”[tw] OR “chlorinated dibenzofurans”[tw] OR “polychlorinated dibenzofurans”[tw]) OR (“chloro dibenzofuran”[tw] OR “polychloro dibenzofuran”[tw] OR “monochloro dibenzofuran”[tw] OR “dichloro dibenzofuran”[tw] OR “trichloro dibenzofuran”[tw] OR “tetrachloro dibenzofuran”[tw] OR “pentachloro dibenzofuran”[tw] OR “hexachloro dibenzofuran”[tw] OR “heptachloro dibenzofuran”[tw] OR “octachloro dibenzofuran”[tw] OR “perchloro dibenzofuran”[tw]) OR (“chloro dibenzofurans”[tw] OR “polychloro dibenzofurans”[tw] OR “monochloro dibenzofurans”[tw] OR “dichloro dibenzofurans”[tw] OR “trichloro dibenzofurans”[tw] OR “tetrachloro dibenzofurans”[tw] OR “pentachloro dibenzofurans”[tw] OR “hexachloro dibenzofurans”[tw] OR “heptachloro dibenzofurans”[tw] OR “octachloro dibenzofurans”[tw] OR “perchloro dibenzofurans”) OR (“dibenzofuran, chloro-”[tw] OR “dibenzofuran, dichloro-”[tw] OR “dibenzofuran, trichloro-”[tw] OR “dibenzofuran, tetrachloro-”[tw] OR “dibenzofuran, pentachloro-”[tw] OR “dibenzofuran, hexachloro-”[tw] OR “dibenzofuran, heptachloro-”[tw] OR “Dibenzofuran, octachloro-”[tw] OR “monochlordibenzofuran”[tw] OR “chlorinated dibenzo-furan”[tw] OR “polychlorinated dibenzo-furan”[tw]) OR (“chlorinated dibenzo-furans”[tw] OR “dibenzofurans, chlorinated”[tw] OR “hepta chloro furans”[tw] OR “heptachlorofurans”[tw] OR “penta chloro furans”[tw] OR “polychlorinated dibenzo-furans”[tw]) OR ((“chlorinated”[tw] AND “dibenzofuran”[tw]) OR (“polychlorinated”[tw] AND “dibenzofuran”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated”[tw] OR “pentachlorinated”[tw] OR “hexachlorinated”[tw] OR “heptachlorinated”[tw] OR “octachlorinated”[tw] OR “perchlorinated”) AND “dibenzofuran”[tw]) OR ((“dipolychlorinated”[tw] OR “tripolychlorinated”[tw] OR “tetrapolychlorinated”[tw] OR “pentapolychlorinated”[tw] OR “hexapolychlorinated”[tw] OR “heptapolychlorinated”[tw] OR “octapolychlorinated”[tw] OR “perpolychlorinated”[tw] OR “polypolychlorinated”[tw]) AND “dibenzofuran”[tw])) OR ((“chlorinated”[tw] AND “dibenzofurans”[tw]) OR (“polychlorinated”[tw] AND “dibenzofurans”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated”[tw] OR “pentachlorinated”[tw] OR “hexachlorinated”[tw] OR “heptachlorinated”[tw] OR “octachlorinated”[tw] OR “perchlorinated”) AND “dibenzofurans”[tw]) OR ((“dipolychlorinated”[tw] OR “tripolychlorinated”[tw] OR “tetrapolychlorinated”[tw] OR “pentapolychlorinated”[tw] OR “hexapolychlorinated”[tw] OR “heptapolychlorinated”[tw] OR “octapolychlorinated”[tw] OR “perpolychlorinated”[tw] OR “polypolychlorinated”[tw]) AND “dibenzofurans”[tw])) OR (“CDD/F”[tw] OR “DCDD/F”[tw] OR “diCDD/F”[tw] OR “HCDD/F”[tw] OR “HpCDD/F”[tw] OR “HxCDD/F”[tw] OR “MCDD/F”[tw] OR “moCDD/F”[tw] OR “monoCDD/F”[tw] OR “OCDD/F”[tw] OR “PCDD/F”[tw] OR “PeCDD/F”[tw] OR “TCDD/F”[tw] OR “triCDD/F”[tw] OR “CDD/Fs”[tw] OR “DCDD/Fs”[tw] OR “diCDD/Fs”[tw] OR “HCDD/Fs”[tw] OR “HpCDD/Fs”[tw] OR “HxCDD/Fs”[tw] OR “MCDD/Fs”[tw] OR “moCDD/Fs”[tw] OR “monoCDD/Fs”[tw] OR “OCDD/Fs”[tw] OR “PCDD/Fs”[tw] OR “PeCDD/Fs”[tw] OR “TCDD/Fs”[tw] OR “triCDD/Fs”[tw]) OR (“chlorodiphenylene oxide”[tw] OR “monochlorodiphenylene oxide”[tw] OR “dichlorodiphenylene oxide”[tw] OR “trichlorodiphenylene oxide”[tw] OR “tetrachlorodiphenylene oxide”[tw] OR “pentachlorodiphenylene oxide”[tw] OR “hexachlorodiphenylene oxide”[tw] OR “heptachlorodiphenylene oxide”[tw] OR “octachlorodiphenylene oxide”[tw] OR “perchlorodiphenylene oxide”[tw] OR “polychlorodiphenylene oxide”[tw] OR “chlorodiphenylene oxides”[tw] OR “monochlorodiphenylene oxides”[tw] OR “dichlorodiphenylene oxides”[tw] OR “trichlorodiphenylene oxides”[tw] OR “tetrachlorodiphenylene oxides”[tw] OR “pentachlorodiphenylene oxides”[tw] OR “hexachlorodiphenylene oxides”[tw] OR “heptachlorodiphenylene oxides”[tw] OR “octachlorodiphenylene oxides”[tw] OR “perchlorodiphenylene oxides”[tw] OR “polychlorodiphenylene oxides”[tw]) OR (“12378 PeCDFuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8,9-octachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 2,3,4,7,8-pentachloro-”[tw] OR “Dibenzofuran, 2,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetra-chloro-”[tw]) OR (“Dibenzofuran, 3-chloro-”[tw] OR “Dibenzofuran, 2-chloro-”[tw] OR “Dibenzofuran, 2,4,8-trichloro-”[tw] OR “Dibenzofuran, 1,3-dichloro-”[tw] OR “Dibenzofuran, 2,4,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,3,4-tetrachloro-”[tw] OR “Dibenzofuran, 2,8-dichloro-”[tw] OR “Dibenzofuran, 1,4,8-trichloro-”[tw] OR “Dibenzofuran, 2,3,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 3,4,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7-pentachloro-”[tw] OR “Dibenzofuran, 2,7-dichloro-”[tw] OR “Dibenzofuran, 1,2,3,6,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8,9-hexachloro-”[tw])) AND (“Dibenzofurans, Polychlorinated”[mh] OR “Benzofurans”[mh] OR “Dioxins”[mh]) AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) AND (2019/06/01:3000[mhda] OR 2019/06/01:3000[crdat] OR 2019/06/01:3000[edat] OR 2019:3000[dp])
| (((“Dibenzofuran, 1,2,3,4,6,7,8,9-octachloro-”[tw] OR “Dibenzofuran, octachloro-”[tw] OR “OCDF”[tw] OR “Octachlorodibenzofuran”[tw] OR “Octapolychlorinated dibenzofuran”[tw] OR “PCDF 135”[tw] OR “Perchlorodibenzofuran”[tw] OR “2,3,7,8-Chlorodibenzofuran”[tw] OR “2,3,7,8-Tetrapolychlorinated dibenzofuran”[tw] OR “Dibenzofuran, 2,3,7,8-tetra-chloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetrachloro-”[tw] OR “PCDF 83”[tw] OR “Tcdbf”[tw] OR “TCDF”[tw] OR “Tetrachlorodibenzofuran”[tw] OR “Tetrachlorodibenzofurans”[tw] OR “1,2,3,4,7,8,9-Heptachloro-dibenzofuran”[tw] OR “1,2,3,4,7,8,9-Heptachlorodibenzofluran”[tw] OR “1,2,3,4,7,8,9-Heptachlorodibenzofuran”[tw] OR “1,2,3,4,7,8,9-HpCDF”[tw] OR “Dibenzofuran, 1,2,3,4,7,8,9-heptachloro-”[tw] OR “Heptachlorodibenzofuran, 1,2,3,4,7,8,9-”[tw] OR “HpCDF, 1,2,3,4,7,8,9-”[tw] OR “PCDF 134”[tw] OR “2,3,4,7,8-PeCDF”[tw] OR “2,3,4,7,8-pentachloro-dibenzofuran”[tw] OR “2,3,4,7,8-Pentachlorodibenzofuran”[tw] OR “2,3,4,7,8-Pentapolychlorinated dibenzofuran”[tw] OR “4-PeCDF”[tw] OR “Dibenzofuran, 2,3,4,7,8-pentachloro-”[tw] OR “PCDF”[tw] OR “PeCDF, 2,3,4,7,8-”[tw] OR “Pentachlorodibenzofuran, 2,3,4,7,8-”[tw] OR “1,3,7,8-Tetrachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,3,7,8-tetrachloro-”[tw] OR “2,3,6,8-Tetrachlorodibenzofuran”[tw] OR “Dibenzofuran, 2,3,6,8-tetrachloro-”[tw] OR “1,2,3,7,8-PeCDF”[tw] OR “1,2,3,7,8-Pentachlorodibenzofuran”[tw] OR “12378 PeCDFuran”[tw] OR “Dibenzofuran, 1,2,3,7,8-pentachloro-”[tw] OR “PCDF 94”[tw] OR “PeCDF, 1,2,3,7,8-”[tw] OR “Pentachlorodibenzofuran, 1,2,3,7,8-”[tw] OR “1,2,3,6,7,8-Hexa polychlorinated dibenzofuran”[tw] OR “1,2,3,6,7,8-Hexachloro- dibenzofuran”[tw] OR “1,2,3,6,7,8-Hexachlorodibenzofuran”[tw] OR “1,2,3,6,7,8-HxCDF”[tw] OR “2,3,4,7,8,9-Hexachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,6,7,8-hexachloro-”[tw] OR “PCDF 121”[tw] OR “2,3,4,6,7,8-Hexachloro-dibenzofuran”[tw] OR “2,3,4,6,7,8-Hexachlorodibenzofuran”[tw] OR “2,3,4,6,7,8-HxCDF”[tw] OR “Dibenzofuran, 2,3,4,6,7,8-hexachloro-”[tw] OR “Hexachlorodibenzofuran, 2,3,4,6,7,8-”[tw] OR “HxCDF, 2,3,4,6,7,8-”[tw] OR “PCDF 130”[tw] OR “1,2,3,4,8-Pentachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,4,8-pentachloro-”[tw] OR “1,2,3,4,6,7,8-Hepta polychlorinated dibenzofuran”[tw] OR “1,2,3,4,6,7,8-Heptachloro-dibenzofuran”[tw] OR “1,2,3,4,6,7,8-Heptachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8-heptachloro-”[tw] OR “Heptachlorodibenzofuran, 1,2,3,4,6,7,8-”[tw] OR “HpCDF”[tw] OR “PCDF 131”[tw] OR “1,2,3,4,6,8,9-Heptachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,8,9-heptachloro-”[tw] OR “1,2,3,4,6,7,9-Heptachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,9-heptachloro-”[tw] OR “1,2,3,4,7,8-HCDF”[tw] OR “1,2,3,4,7,8-Hexa polychlorinated dibenzofuran”[tw] OR “1,2,3,4,7,8-Hexachloro-dibenzofuran”[tw] OR “1,2,3,4,7,8-Hexachlorodibenzofuran”[tw] OR “1,2,3,4,7,8-HxCDF”[tw] OR “Dibenzofuran, 1,2,3,4,7,8-hexachloro-”[tw] OR “HCDF”[tw] OR “Hexachlorodibenzofuran, 1,2,3,4,7,8-”[tw] OR “HXCDF, 1,2,3,4,7,8-”[tw] OR “PCDF 118”[tw] OR “1,2,3,7,8,9-Hexachloro-dibenzofuran”[tw] OR “1,2,3,7,8,9-Hexachlorodibenzofuran”[tw] OR “1,2,3,7,8,9-HxCDF”[tw] OR ”Dibenzofuran, 1,2,3,7,8,9-hexachloro-”[tw] OR “Hexachlorodibenzofuran, 1,2,3,7,8,9-”[tw] OR “HxCDF, 1,2,3,7,8,9-”[tw] OR “PCDF 124”[tw] OR “1,2,4,6,7,9-Hexachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,4,6,7,9-hexachloro-”[tw]) OR (“3-Chlorodibenzofuran”[tw] OR “3-Monochlorodibenzofuran”[tw] OR “Dibenzofuran, 3-chloro-”[tw] OR “2-Chlorodibenzofuran”[tw] OR “2-Monochlorodibenzofuran”[tw] OR “Dibenzofuran, 2-chloro-”[tw] OR “2,4,8-Trichlorodibenzofuran”[tw] OR “Dibenzofuran, 2,4,8-trichloro-”[tw] OR “4-Chlorodibenzofuran”[tw] OR “1,3-Dichlorodibenzofuran”[tw] OR “Dibenzofuran, 1,3-dichloro-”[tw] OR “2,4,6,8-Tcdf”[tw] OR “2,4,6,8-Tetrachlorodibenzofuran”[tw] OR “Dibenzofuran, 2,4,6,8-tetrachloro-”[tw] OR “1,2,7,8-Tcdf”[tw] OR “1,2,7,8-Tetrachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,7,8-tetrachloro-”[tw] OR “1,3,6,8-Tcdf”[tw] OR “1,3,6,8-Tetrachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,3,6,8-tetrachloro-”[tw] OR “1,2,3,4-Tetrachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,4-tetrachloro-”[tw] OR “2,8-Dichlorodibenzofuran”[tw] OR “Dibenzofuran, 2,8-dichloro-”[tw] OR “1,4,8-Trichlorodibenzofuran”[tw] OR “Dibenzofuran, 1,4,8-trichloro-”[tw] OR “Dibenzofuran, trichloro-Trichlorodibenzofuran”[tw] OR “Dibenzofuran, 2,3,6,7-tetrachloro-”[tw] OR “2,3,6,7-Tetrachlorodibenzofuran”[tw] OR “Dibenzofuran, 3,4,6,7-tetrachloro-”[tw] OR “3,4,6,7-Tetrachlorodibenzofuran”[tw] OR “Dibenzofuran, 2,3,4,6,7-pentachloro-”[tw] OR “2,3,4,6,7-PeCDF”[tw] OR “2,3,4,6,7-Pentachlorodibenzofuran”[tw] OR “Dibenzofuran, 2,7-dichloro-”[tw] OR “2,7-Dichlorodibenzofuran”[tw] OR “1,2,3,6,8,9-Hexachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,6,8,9-hexachloro-”[tw] OR “1,2,3,4,6,7-Hexachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,7-hexachloro-”[tw] OR “1,2,3,4,6,9-Hexachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,9-hexachloro-”[tw] OR “1,2,3,4,7,9-Hexachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,4,7,9-hexachloro-”[tw] OR “1,3,4,6,7,9-Hexachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,3,4,6,7,9-hexachloro-”[tw] OR “1,2,3,6,7,9-Hexachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,6,7,9-hexachloro-”[tw] OR “1,2,3,4,8,9-Hexachlorodibenzofuran”[tw] OR “Dibenzofuran, 1,2,3,4,8,9-hexachloro”[tw])) OR (“Chlorinated dibenzo-furans”[tw] OR “Chlorinated dibenzofurans”[tw] OR “Chlorodibenzofuran”[tw] OR “Chlorodibenzofurans”[tw] OR “Dibenzofuran, chloro derivs.”[tw] OR “Dibenzofuran, chloro-”[tw] OR “Dibenzofuran, dichloro-”[tw] OR “Dibenzofuran, heptachloro-”[tw] OR “Dibenzofuran, hexachloro-”[tw] OR “Dibenzofuran, pentachloro-”[tw] OR “Dibenzofuran, tetrachloro-”[tw] OR “Dibenzofurans, chlorinated”[tw] OR “Dichlorodibenzofuran”[tw] OR “HCDF”[tw] OR “Hepta chloro furans”[tw] OR “Heptachlordibenzofuran”[tw] OR “HEPTACHLORODIBENZOFURAN”[tw] OR “Heptachlorodibenzofurans”[tw] OR “Heptachlorofurans”[tw] OR “Hexachlorodibenzofuran”[tw] OR “Hexachlorodibenzofurans”[tw] OR “HpCDF”[tw] OR “HpCDFs”[tw] OR “HxCDF”[tw] OR “Monochlordibenzofuran”[tw] OR “Monochlorodibenzofuran”[tw] OR “PCDFs”[tw] OR “PeCDF”[tw] OR “PeCDFs”[tw] OR “Penta chloro furans”[tw] OR “Pentachlorodibenzofuran”[tw] OR “Pentachlorodibenzofurans”[tw] OR “Polychlorinated dibenzo-furans”[tw] OR “Polychlorinated Dibenzofurans, Total”[tw] OR “Polychlorodibenzofurans”[tw] OR “TCDF”[tw] OR “TCDFs”[tw] OR “Tetrachlorodibenzofuran”[tw] OR “Tetrachlorodibenzofurans”[tw])) NOT ((“DCDF”[tw] OR “diCDF”[tw] OR “di-CDF”[tw] OR “HCDF”[tw] OR “heptaCDF”[tw] OR “hepta-CDF”[tw] OR “hexaCDF”[tw] OR “hexa-CDF”[tw] OR “HpCDF”[tw] OR “HxCDF”[tw] OR “moCDF”[tw] OR “monoCDF”[tw] OR “mono-CDF”[tw] OR “OCDF”[tw] OR “octaCDF”[tw] OR “octa-CDF”[tw] OR “PCDF”[tw] OR “PeCDF”[tw] OR “pentaCDF”[tw] OR “penta-CDF”[tw] OR “Tcdbf”[tw] OR “TCDF”[tw] OR “tetraCDF”[tw] OR “tetra-CDF”[tw] OR “triCDF”[tw] OR “tri-CDF”[tw]) OR (“DCDFs”[tw] OR “diCDFs”[tw] OR “di-CDFs”[tw] OR “HCDFs”[tw] OR “heptaCDFs”[tw] OR “hepta-CDFs”[tw] OR “hexaCDFs”[tw] OR “hexa-CDFs”[tw] OR “HpCDFs”[tw] OR “HxCDFs”[tw] OR “moCDFs”[tw] OR “monoCDFs”[tw] OR “mono-CDFs”[tw] OR “OCDFs”[tw] OR “octaCDFs”[tw] OR “octa-CDFs”[tw] OR “PCDFs”[tw] OR “PeCDFs”[tw] OR “pentaCDFs”[tw] OR “penta-CDFs”[tw] OR “Tcdbfs”[tw] OR “TCDFs”[tw] OR “tetraCDFs”[tw] OR “tetra-CDFs”[tw] OR “triCDFs”[tw] OR “tri-CDFs”[tw]) OR (“CDF”[tw] AND “Benzofurans”[mh]) OR (“CDFs”[tw] AND “Benzofurans”[mh]) OR (“chlorodibenzofuran”[tw] OR “polychlorodibenzofuran”[tw] OR “monochlorodibenzofuran”[tw] OR “dichlorodibenzofuran”[tw] OR “trichlorodibenzofuran”[tw] OR “tetrachlorodibenzofuran”[tw] OR “pentachlorodibenzofuran”[tw] OR “hexachlorodibenzofuran”[tw] OR “heptachlorodibenzofuran”[tw] OR “octachlorodibenzofuran”[tw] OR “perchlorodibenzofuran”[tw] OR “chlorinated dibenzofuran”[tw] OR “polychlorinated dibenzofuran”[tw]) OR (“chlorodibenzofurans”[tw] OR “polychlorodibenzofurans”[tw] OR “monochlorodibenzofurans”[tw] OR “dichlorodibenzofurans”[tw] OR “trichlorodibenzofurans”[tw] OR “tetrachlorodibenzofurans”[tw] OR “pentachlorodibenzofurans”[tw] OR “hexachlorodibenzofurans”[tw] OR “heptachlorodibenzofurans”[tw] OR “octachlorodibenzofurans”[tw] OR “perchlorodibenzofurans”[tw] OR “chlorinated dibenzofurans”[tw] OR “polychlorinated dibenzofurans”[tw]) OR (“chloro dibenzofuran”[tw] OR “polychloro dibenzofuran”[tw] OR “monochloro dibenzofuran”[tw] OR “dichloro dibenzofuran”[tw] OR “trichloro dibenzofuran”[tw] OR “tetrachloro dibenzofuran”[tw] OR “pentachloro dibenzofuran”[tw] OR “hexachloro dibenzofuran”[tw] OR “heptachloro dibenzofuran”[tw] OR “octachloro dibenzofuran”[tw] OR “perchloro dibenzofuran”[tw]) OR (“chloro dibenzofurans”[tw] OR “polychloro dibenzofurans”[tw] OR “monochloro dibenzofurans”[tw] OR “dichloro dibenzofurans”[tw] OR “trichloro dibenzofurans”[tw] OR “tetrachloro dibenzofurans”[tw] OR “pentachloro dibenzofurans”[tw] OR “hexachloro dibenzofurans”[tw] OR “heptachloro dibenzofurans”[tw] OR “octachloro dibenzofurans”[tw] OR “perchloro dibenzofurans”) OR (“dibenzofuran, chloro-”[tw] OR “dibenzofuran, dichloro-”[tw] OR “dibenzofuran, trichloro-”[tw] OR “dibenzofuran, tetrachloro-”[tw] OR “dibenzofuran, pentachloro-”[tw] OR “dibenzofuran, hexachloro-”[tw] OR “dibenzofuran, heptachloro-”[tw] OR “Dibenzofuran, octachloro-”[tw] OR “monochlordibenzofuran”[tw] OR “chlorinated dibenzo-furan”[tw] OR “polychlorinated dibenzo-furan”[tw]) OR (“dibenzofuran, chloro-”[tw] OR “dibenzofuran, dichloro-”[tw] OR “dibenzofuran, trichloro-”[tw] OR “dibenzofuran, tetrachloro-”[tw] OR “dibenzofuran, pentachloro-”[tw] OR “dibenzofuran, hexachloro-”[tw] OR “dibenzofuran, heptachloro-”[tw] OR “Dibenzofuran, octachloro-”[tw] OR “monochlordibenzofuran”[tw] OR “chlorinated dibenzo-furan”[tw] OR “polychlorinated dibenzo-furan”[tw]) OR (“chlorinated dibenzo-furans”[tw] OR “dibenzofurans, chlorinated”[tw] OR “hepta chloro furans”[tw] OR “heptachlorofurans”[tw] OR “penta chloro furans”[tw] OR “polychlorinated dibenzo-furans”[tw]) OR ((“chlorinated”[tw] AND “dibenzofuran”[tw]) OR (“polychlorinated”[tw] AND “dibenzofuran”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated”[tw] OR “pentachlorinated”[tw] OR “hexachlorinated”[tw] OR “heptachlorinated”[tw] OR “octachlorinated”[tw] OR “perchlorinated”) AND “dibenzofuran”[tw]) OR ((“dipolychlorinated”[tw] OR “tripolychlorinated”[tw] OR “tetrapolychlorinated”[tw] OR “pentapolychlorinated”[tw] OR “hexapolychlorinated”[tw] OR “heptapolychlorinated”[tw] OR “octapolychlorinated”[tw] OR “perpolychlorinated”[tw] OR “polypolychlorinated”[tw]) AND “dibenzofuran”[tw])) OR ((“chlorinated”[tw] AND “dibenzofurans”[tw]) OR (“polychlorinated”[tw] AND “dibenzofurans”[tw]) OR ((“monochlorinated”[tw] OR “dichlorinated”[tw] OR “trichlorinated”[tw] OR “tetrachlorinated”[tw] OR “pentachlorinated”[tw] OR “hexachlorinated”[tw] OR “heptachlorinated”[tw] OR “octachlorinated”[tw] OR “perchlorinated”) AND “dibenzofurans”[tw]) OR ((“dipolychlorinated”[tw] OR “tripolychlorinated”[tw] OR “tetrapolychlorinated”[tw] OR “pentapolychlorinated”[tw] OR “hexapolychlorinated”[tw] OR “heptapolychlorinated”[tw] OR “octapolychlorinated”[tw] OR “perpolychlorinated”[tw] OR “polypolychlorinated”[tw]) AND “dibenzofurans”[tw])) OR (“CDD/F”[tw] OR “DCDD/F”[tw] OR “diCDD/F”[tw] OR “HCDD/F”[tw] OR “HpCDD/F”[tw] OR “HxCDD/F”[tw] OR “MCDD/F”[tw] OR “moCDD/F”[tw] OR “monoCDD/F”[tw] OR “OCDD/F”[tw] OR “PCDD/F”[tw] OR “PeCDD/F”[tw] OR “TCDD/F”[tw] OR “triCDD/F”[tw] OR “CDD/Fs”[tw] OR “DCDD/Fs”[tw] OR “diCDD/Fs”[tw] OR “HCDD/Fs”[tw] OR ”HpCDD/Fs”[tw] OR “HxCDD/Fs”[tw] OR “MCDD/Fs”[tw] OR “moCDD/Fs”[tw] OR “monoCDD/Fs”[tw] OR “OCDD/Fs”[tw] OR “PCDD/Fs”[tw] OR “PeCDD/Fs”[tw] OR “TCDD/Fs”[tw] OR “triCDD/Fs”[tw]) OR (“chlorodiphenylene oxide”[tw] OR “monochlorodiphenylene oxide”[tw] OR “dichlorodiphenylene oxide”[tw] OR “trichlorodiphenylene oxide”[tw] OR “tetrachlorodiphenylene oxide”[tw] OR “pentachlorodiphenylene oxide”[tw] OR “hexachlorodiphenylene oxide”[tw] OR “heptachlorodiphenylene oxide”[tw] OR “octachlorodiphenylene oxide”[tw] OR “perchlorodiphenylene oxide”[tw] OR “polychlorodiphenylene oxide”[tw] OR “chlorodiphenylene oxides”[tw] OR “monochlorodiphenylene oxides”[tw] OR “dichlorodiphenylene oxides”[tw] OR “trichlorodiphenylene oxides”[tw] OR “tetrachlorodiphenylene oxides”[tw] OR “pentachlorodiphenylene oxides”[tw] OR “hexachlorodiphenylene oxides”[tw] OR “heptachlorodiphenylene oxides”[tw] OR “octachlorodiphenylene oxides”[tw] OR “perchlorodiphenylene oxides”[tw] OR “polychlorodiphenylene oxides”[tw]) OR (“chlorodiphenylene oxide”[tw] OR “monochlorodiphenylene oxide”[tw] OR “dichlorodiphenylene oxide”[tw] OR “trichlorodiphenylene oxide”[tw] OR “tetrachlorodiphenylene oxide”[tw] OR “pentachlorodiphenylene oxide”[tw] OR “hexachlorodiphenylene oxide”[tw] OR “heptachlorodiphenylene oxide”[tw] OR “octachlorodiphenylene oxide”[tw] OR “perchlorodiphenylene oxide”[tw] OR “polychlorodiphenylene oxide”[tw] OR “chlorodiphenylene oxides”[tw] OR “monochlorodiphenylene oxides”[tw] OR “dichlorodiphenylene oxides”[tw] OR “trichlorodiphenylene oxides”[tw] OR “tetrachlorodiphenylene oxides”[tw] OR “pentachlorodiphenylene oxides”[tw] OR “hexachlorodiphenylene oxides”[tw] OR “heptachlorodiphenylene oxides”[tw] OR “octachlorodiphenylene oxides”[tw] OR “perchlorodiphenylene oxides”[tw] OR “polychlorodiphenylene oxides”[tw]) OR (“12378 PeCDFuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8,9-octachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 2,3,4,7,8-pentachloro-”[tw] OR “Dibenzofuran, 2,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetra-chloro-”[tw]) OR (“12378 PeCDFuran”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8,9-octachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,8-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8,9-heptachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,7,8-pentachloro-”[tw] OR “Dibenzofuran, 1,2,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7,8-hexachloro-”[tw] OR “Dibenzofuran, 2,3,4,7,8-pentachloro-”[tw] OR “Dibenzofuran, 2,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,7,8-tetra-chloro-”[tw]) OR (“Dibenzofuran, 3-chloro-”[tw] OR “Dibenzofuran, 2-chloro-”[tw] OR “Dibenzofuran, 2,4,8-trichloro-”[tw] OR “Dibenzofuran, 1,3-dichloro-”[tw] OR “Dibenzofuran, 2,4,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,3,4-tetrachloro-”[tw] OR “Dibenzofuran, 2,8-dichloro-”[tw] OR “Dibenzofuran, 1,4,8-trichloro-”[tw] OR “Dibenzofuran, 2,3,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 3,4,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7-pentachloro-”[tw] OR “Dibenzofuran, 2,7-dichloro-”[tw] OR “Dibenzofuran, 1,2,3,6,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8,9-hexachloro-”[tw]) OR (“Dibenzofuran, 3-chloro-”[tw] OR “Dibenzofuran, 2-chloro-”[tw] OR “Dibenzofuran, 2,4,8-trichloro-”[tw] OR “Dibenzofuran, 1,3-dichloro-”[tw] OR “Dibenzofuran, 2,4,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,7,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,3,6,8-tetrachloro-”[tw] OR “Dibenzofuran, 1,2,3,4-tetrachloro-”[tw] OR “Dibenzofuran, 2,8-dichloro-”[tw] OR “Dibenzofuran, 1,4,8-trichloro-”[tw] OR “Dibenzofuran, 2,3,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 3,4,6,7-tetrachloro-”[tw] OR “Dibenzofuran, 2,3,4,6,7-pentachloro-”[tw] OR “Dibenzofuran, 2,7-dichloro-”[tw] OR “Dibenzofuran, 1,2,3,6,8,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,7-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,6,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,3,4,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,6,7,9-hexachloro-”[tw] OR “Dibenzofuran, 1,2,3,4,8,9-hexachloro-”[tw]))
NTRL
06/2022 | Date Published 2018 to 2022
| “DCDF” OR “diCDF” OR “di-CDF” OR “HCDF” OR “heptaCDF” OR “hepta-CDF” OR “hexaCDF” OR “hexa-CDF” OR “HpCDF” OR “HxCDF” OR “moCDF” OR “monoCDF” OR “mono-CDF” OR “OCDF” OR “octaCDF” OR “octa-CDF” OR “PCDF” OR “PeCDF” OR “pentaCDF” OR “penta-CDF” OR “Tcdbf” OR “TCDF” OR “tetraCDF” OR “tetra-CDF” OR “triCDF” OR “tri-CDF” OR “DCDFs” OR “diCDFs” OR “di-CDFs” OR “HCDFs” OR “heptaCDFs” OR “hepta-CDFs” OR “hexaCDFs” OR “hexa-CDFs” OR “HpCDFs” OR “HxCDFs” OR “moCDFs” OR “monoCDFs” OR “mono-CDFs” OR “OCDFs” OR “octaCDFs” OR “octa-CDFs” OR “PCDFs” OR “PeCDFs” OR “pentaCDFs” OR “penta-CDFs” OR “Tcdbfs” OR “TCDFs” OR “tetraCDFs” OR “tetra-CDFs” OR “triCDFs” OR “tri-CDFs” OR “chlorodibenzofuran” OR “polychlorodibenzofuran” OR “monochlorodibenzofuran” OR “dichlorodibenzofuran” OR “trichlorodibenzofuran” OR “tetrachlorodibenzofuran” OR “pentachlorodibenzofuran” OR “hexachlorodibenzofuran” OR “heptachlorodibenzofuran” OR “octachlorodibenzofuran” OR “perchlorodibenzofuran” OR “chlorinated dibenzofuran” OR “polychlorinated dibenzofuran” OR “chlorodibenzofurans” OR “polychlorodibenzofurans” OR “monochlorodibenzofurans” OR “dichlorodibenzofurans” OR “trichlorodibenzofurans” OR “tetrachlorodibenzofurans” OR “pentachlorodibenzofurans” OR “hexachlorodibenzofurans” OR “heptachlorodibenzofurans” OR “octachlorodibenzofurans” OR “perchlorodibenzofurans” OR “chlorinated dibenzofurans” OR “polychlorinated dibenzofurans”
| Date Published 2018 to 2022; “chlorinated dibenzofuran” OR “polychlorinated dibenzofuran” OR “monochlorinated dibenzofuran” OR “dichlorinated dibenzofuran” OR “trichlorinated dibenzofuran” OR “tetrachlorinated dibenzofuran” OR “pentachlorinated dibenzofuran” OR “hexachlorinated dibenzofuran” OR “heptachlorinated dibenzofuran” OR “octachlorinated dibenzofuran” OR “perchlorinated dibenzofuran” OR “dipolychlorinated dibenzofuran” OR “tripolychlorinated dibenzofuran” OR “tetrapolychlorinated dibenzofuran” OR “pentapolychlorinated dibenzofuran” OR “hexapolychlorinated dibenzofuran” OR “heptapolychlorinated dibenzofuran” OR “octapolychlorinated dibenzofuran” OR “perpolychlorinated dibenzofuran” OR “polypolychlorinated dibenzofuran” OR “chlorinated dibenzofurans” OR “polychlorinated dibenzofurans” OR “monochlorinated dibenzofurans” OR “dichlorinated dibenzofurans” OR “trichlorinated dibenzofurans” OR “tetrachlorinated dibenzofurans” OR “pentachlorinated dibenzofurans” OR “hexachlorinated dibenzofurans” OR “heptachlorinated dibenzofurans” OR “octachlorinated dibenzofurans” OR “perchlorinated dibenzofurans” OR “dipolychlorinated dibenzofurans” OR “tripolychlorinated dibenzofurans” OR “tetrapolychlorinated dibenzofurans” OR “pentapolychlorinated dibenzofurans” OR “hexapolychlorinated dibenzofurans” OR “heptapolychlorinated dibenzofurans” OR “octapolychlorinated dibenzofurans” OR “perpolychlorinated dibenzofurans” OR “polypolychlorinated dibenzofurans” OR “chloro dibenzofuran” OR “polychloro dibenzofuran” OR “monochloro dibenzofuran” OR “dichloro dibenzofuran” OR “trichloro dibenzofuran” OR “tetrachloro dibenzofuran” OR “pentachloro dibenzofuran” OR “hexachloro dibenzofuran” OR “heptachloro dibenzofuran” OR “octachloro dibenzofuran” OR “perchloro dibenzofuran” OR “chloro dibenzofurans” OR “polychloro dibenzofurans” OR “monochloro dibenzofurans” OR “dichloro dibenzofurans” OR “trichloro dibenzofurans” OR “tetrachloro dibenzofurans” OR “pentachloro dibenzofurans” OR “hexachloro dibenzofurans” OR “heptachloro dibenzofurans” OR “octachloro dibenzofurans” OR “perchloro dibenzofurans” OR “dibenzofuran, chloro-” OR “dibenzofuran, dichloro-” OR “dibenzofuran, trichloro-” OR “dibenzofuran, tetrachloro-” OR “dibenzofuran, pentachloro-” OR “dibenzofuran, hexachloro-” OR “dibenzofuran, heptachloro-” OR “Dibenzofuran, octachloro-” OR “monochlordibenzofuran” OR “chlorinated dibenzo-furan” OR “polychlorinated dibenzo-furan” OR “chlorinated dibenzo-furans” OR “dibenzofurans, chlorinated” OR “hepta chloro furans” OR “heptachlorofurans” OR “penta chloro furans” OR “polychlorinated dibenzo-furans”
| Date Published 2018 to 2022; “chlorodiphenylene oxide” OR “monochlorodiphenylene oxide” OR “dichlorodiphenylene oxide” OR “trichlorodiphenylene oxide” OR “tetrachlorodiphenylene oxide” OR “pentachlorodiphenylene oxide” OR “hexachlorodiphenylene oxide” OR “heptachlorodiphenylene oxide” OR “octachlorodiphenylene oxide” OR “perchlorodiphenylene oxide” OR “polychlorodiphenylene oxide” OR “chlorodiphenylene oxides” OR “monochlorodiphenylene oxides” OR “dichlorodiphenylene oxides” OR “trichlorodiphenylene oxides” OR “tetrachlorodiphenylene oxides” OR “pentachlorodiphenylene oxides” OR “hexachlorodiphenylene oxides” OR “heptachlorodiphenylene oxides” OR “octachlorodiphenylene oxides” OR “perchlorodiphenylene oxides” OR “polychlorodiphenylene oxides” OR “12378 PeCDFuran” OR “Dibenzofuran, 1,2,3,4,6,7,8,9-octachloro-” OR “Dibenzofuran, 1,2,3,4,6,7,8-heptachloro-” OR “Dibenzofuran, 1,2,3,4,6,7,9-heptachloro-” OR “Dibenzofuran, 1,2,3,4,6,8,9-heptachloro-” OR “Dibenzofuran, 1,2,3,4,7,8,9-heptachloro-” OR “Dibenzofuran, 1,2,3,4,7,8-hexachloro-” OR “Dibenzofuran, 1,2,3,4,8-pentachloro-” OR “Dibenzofuran, 1,2,3,6,7,8-hexachloro-” OR “Dibenzofuran, 1,2,3,7,8,9-hexachloro-” OR “Dibenzofuran, 1,2,3,7,8-pentachloro-” OR “Dibenzofuran, 1,2,4,6,7,9-hexachloro-” OR “Dibenzofuran, 1,3,7,8-tetrachloro-” OR “Dibenzofuran, 2,3,4,6,7,8-hexachloro-” OR “Dibenzofuran, 2,3,4,7,8-pentachloro-” OR “Dibenzofuran, 2,3,6,8-tetrachloro-” OR “Dibenzofuran, 2,3,7,8-tetrachloro-” OR “Dibenzofuran, 2,3,7,8-tetra-chloro-” OR “Dibenzofuran, 3-chloro-” OR “Dibenzofuran, 2-chloro-” OR “Dibenzofuran, 2,4,8-trichloro-” OR “Dibenzofuran, 1,3-dichloro-” OR “Dibenzofuran, 2,4,6,8-tetrachloro-” OR “Dibenzofuran, 1,2,7,8-tetrachloro-” OR “Dibenzofuran, 1,3,6,8-tetrachloro-” OR “Dibenzofuran, 1,2,3,4-tetrachloro-” OR “Dibenzofuran, 2,8-dichloro-” OR “Dibenzofuran, 1,4,8-trichloro-” OR “Dibenzofuran, 2,3,6,7-tetrachloro-” OR “Dibenzofuran, 3,4,6,7-tetrachloro-” OR “Dibenzofuran, 2,3,4,6,7-pentachloro-” OR “Dibenzofuran, 2,7-dichloro-” OR “Dibenzofuran, 1,2,3,6,8,9-hexachloro-” OR “Dibenzofuran, 1,2,3,4,6,7-hexachloro-” OR “Dibenzofuran, 1,2,3,4,6,9-hexachloro-” OR “Dibenzofuran, 1,2,3,4,7,9-hexachloro-” OR “Dibenzofuran, 1,3,4,6,7,9-hexachloro-” OR “Dibenzofuran, 1,2,3,6,7,9-hexachloro-” OR “Dibenzofuran, 1,2,3,4,8,9-hexachloro-”
Toxcenter
06/2022 | FILE ‘TOXCENTER’ ENTERED AT 16:55:43 ON 02 JUN 2022
| L1 8780 SEA FILE=TOXCENTER 39001-02-0 OR 51207-31-9 OR 55673-89-7 OR 57117-31-4 OR 57117-35-8 OR 57117-37-0 OR 57117-41-6 OR 57117-44-9 OR 60851-34-5 OR 67517-48-0 OR 67562-39-4 OR 69698-58-4 OR 70648-25-8 OR 70648-26-9 OR 72918-21-9 OR 75627-02-0 OR 42934-53-2 OR 30402-14-3 OR 30402-15-4 OR 55684-94-1 OR 38998-75-3
| L2 901 SEA FILE=TOXCENTER 136677-10-6 OR 43047-99-0 OR 51230-49-0 OR 25074-67-3 OR 74992-96-4 OR 94538-00-8 OR 5409-83-6 OR 64560-14-1 OR 54589-71-8 OR 24478-72-6 OR 58802-19-0 OR 58802-20-3 OR 71998-72-6 OR 74992-98-6 OR 43048-00-6
| L3 500 SEA FILE=TOXCENTER 57117-39-2 OR 57117-40-5 OR 57117-43-8 OR 75198-38-8 OR 79060-60-9 OR 91538-83-9 OR 91538-84-0 OR 92341-05-4 OR 92341-06-5 OR 92341-07-6
| L4 8203 SEA FILE=TOXCENTER 24478-72-6 OR 24478-73-7 OR 24478-74-8 OR 25074-67-3 OR 30402-14-3 OR 30402-15-4 OR 38998-75-3 OR 39001-02-0 OR 42934-53-2 OR 43047-99-0 OR 43048-00-6 OR 51207-31-9 OR 51230-49-0 OR 5409-83-6 OR 54589-71-8 OR 55673-89-7 OR 55684-94-1 OR 55722-27-5
| L5 6044 SEA FILE=TOXCENTER 57117-31-4 OR 57117-32-5 OR 57117-33-6 OR 57117-34-7 OR 57117-35-8 OR 57117-36-9 OR 57117-37-0 OR 57117-38-1 OR 57117-39-2 OR 57117-40-5 OR 57117-41-6 OR 57117-42-7 OR 57117-43-8 OR 57117-44-9 OR 58802-14-5 OR 58802-15-6 OR 58802-16-7 OR 58802-17-8
| L6 4489 SEA FILE=TOXCENTER 58802-18-9 OR 58802-19-0 OR 58802-20-3 OR 58802-21-4 OR 60390-27-4 OR 60851-34-5 OR 62615-08-1 OR 64126-85-8 OR 64126-86-9 OR 64126-87-0 OR 64560-13-0 OR 64560-14-1 OR 64560-15-2 OR 64560-16-3 OR 64560-17-4 OR 66794-59-0 OR 67481-22-5 OR 67517-48-0 DIS COST
| L7 4907 SEA FILE=TOXCENTER 67562-39-4 OR 67562-40-7 OR 67652-39-5 OR 69433-00-7 OR 69698-57-3 OR 69698-58-4 OR 69698-59-5 OR 69698-60-8 OR 70648-13-4 OR 70648-14-5 OR 70648-15-6 OR 70648-16-7 OR 70648-18-9 OR 70648-19-0 OR 70648-20-3 OR 70648-21-4 OR 70648-22-5 OR 70648-23-6
| L8 5141 SEA FILE=TOXCENTER 70648-24-7 OR 70648-25-8 OR 70648-26-9 OR 70872-82-1 OR 71998-72-6 OR 71998-73-7 OR 71998-74-8 OR 71998-75-9 OR 72918-21-9 OR 74423-73-7 OR 74918-40-4 OR 74992-96-4 OR 74992-97-5 OR 74992-98-6 OR 75198-38-8 OR 75627-02-0 OR 76621-12-0 OR 79060-60-9
| L9 273 SEA FILE=TOXCENTER 81638-37-1 OR 82911-58-8 OR 82911-59-9 OR 82911-60-2 OR 82911-61-3 OR 83636-47-9 OR 83690-98-6 OR 83704-21-6 OR 83704-22-7 OR 83704-23-8 OR 83704-24-9 OR 83704-25-0 OR 83704-26-1 OR 83704-27-2 OR 83704-28-3 OR 83704-29-4 OR 83704-30-7 OR 83704-31-8
| L10 286 SEA FILE=TOXCENTER 83704-32-9 OR 83704-33-0 OR 83704-34-1 OR 83704-35-2 OR 83704-36-3 OR 83704-37-4 OR 83704-38-5 OR 83704-39-6 OR 83704-40-9 OR 83704-41-0 OR 83704-42-1 OR 83704-43-2 OR 83704-44-3 OR 83704-45-4 OR 83704-46-5 OR 83704-47-6 OR 83704-48-7 OR 83704-49-8
| L11 531 SEA FILE=TOXCENTER 83704-50-1 OR 83704-51-2 OR 83704-52-3 OR 83704-53-4 OR 83704-54-5 OR 83704-55-6 OR 83710-07-0 OR 83719-40-8 OR 84761-86-4 OR 89059-46-1 OR 91538-83-9 OR 91538-84-0 OR 92341-04-3 OR 92341-05-4 OR 92341-06-5 OR 92341-07-6 OR 94538-00-8 OR 94538-01-9 OR 94538-02-0 OR 94570-83-9
| L14 9010 SEA FILE=TOXCENTER L1 OR L2 OR L3 OR L4 OR L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11
| L16 8986 SEA FILE=TOXCENTER L14 NOT TSCATS/FS
| L17 8768 SEA FILE=TOXCENTER L16 NOT PATENT/DT
| L18 293 SEA FILE=TOXCENTER L17 AND ED>=20190701 ACTIVATE TOXQUERY/Q ---------
| L19 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?)
| L20 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT)
| L21 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50)
| L22 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT
| L23 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?)
| L24 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?)
| L25 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?)
| L26 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE))
| L27 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?)
| L28 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?)
| L29 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?)
| L30 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?)
| L31 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?)
| L32 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?)
| L33 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?)
| L34 QUE (ENDOCRIN? AND DISRUPT?)
| L35 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?)
| L36 QUE (WEAN? OR OFFSPRING OR AG E(W) FACTOR?)
| L37 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?)
| L38 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?)
| L39 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?)
| L40 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?)
| L41 QUE (NEPHROTOX? OR HEPATOTOX?)
| L42 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?)
| L43 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?)
| L44 QUE L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32 OR L33 OR L34 OR L35 OR L36 OR L37 OR L38 OR L39 OR L40 OR L41 OR L42 OR L43
| L45 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?)
| L46 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE)
| L47 QUE L44 OR L45 OR L46
| L48 QUE (NONHUMAN MAMMALS)/ORGN
| L49 QUE L47 OR L48
| L50 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?)
| L51 QUE L49 OR L50 ---------
| L52 141 SEA FILE=TOXCENTER L18 AND L51
| L53 5 SEA FILE=TOXCENTER L52 AND MEDLINE/FS
| L54 135 DUP REM L52 (6 DUPLICATES REMOVED) D SCAN L54

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via Chemview
06/2022 | 39001-02-0; 51207-31-9; 55673-89-7; 57117-31-4; 57117-35-8; 57117-37-0; 57117-41-6; 57117-44-9; 60851-34-5; 67517-48-0; 67562-39-4; 69698-58-4; 70648-25-8; 70648-26-9; 72918-21-9; 75627-02-0; 42934-53-2; 30402-14-3; 30402-15-4; 55684-94-1; 38998-75-3; 136677-10-6; 43047-99-0; 51230-49-0; 25074-67-3; 74992-96-4; 94538-00-8; 5409-83-6; 64560-14-1; 54589-71-8; 24478-72-6; 58802-19-0; 58802-20-3; 71998-72-6; 74992-98-6; 43048-00-6; 57117-39-2; 57117-40-5; 57117-43-8; 75198-38-8; 79060-60-9; 91538-83-9; 91538-84-0; 92341-05-4; 92341-06-5; 92341-07-6
NTP
06/2022 | Date limited 2020-present or 2010-2019 (or Not Dated); “39001-02-0” “51207-31-9” “55673-89-7” “57117-31-4” “57117-35-8” “57117-37-0” “57117-41-6” “57117-44-9” “60851-34-5” “67517-48-0” “67562-39-4” “69698-58-4” “70648-25-8” “70648-26-9” “72918-21-9” “75627-02-0” “42934-53-2” “30402-14-3” “30402-15-4” “55684-94-1” “38998-75-3” “136677-10-6” “43047-99-0” “51230-49-0” “25074-67-3” “74992-96-4” “94538-00-8” “5409-83-6” “64560-14-1” “54589-71-8” “24478-72-6” “58802-19-0” “58802-20-3” “71998-72-6” “74992-98-6” “43048-00-6” “57117-39-2” “57117-40-5” “57117-43-8” “75198-38-8” “79060-60-9” “91538-83-9” “91538-84-0” “92341-05-4” “92341-06-5” “92341-07-6” “PCDFs” “CDFs” “chlorinated dibenzofurans” “polychlorinated dibenzofurans” “chlorodibenzofuran” “polychlorodibenzofuran” “monochlorodibenzofuran” “dichlorodibenzofuran” “heptachlorodibenzofuran” “octachlorodibenzofuran” “perchlorodibenzofuran” “trichlorodibenzofuran” “tetrachlorodibenzofuran” “pentachlorodibenzofuran” “hexachlorodibenzofuran”
Regulations.gov
06/2022 | 39001-02-0; 51207-31-9; 55673-89-7; 57117-31-4; 57117-35-8; 57117-37-0; 57117-41-6; 57117-44-9; 60851-34-5; 67517-48-0; 67562-39-4; 69698-58-4; 70648-25-8; 70648-26-9; 72918-21-9; 75627-02-0; 42934-53-2; 30402-14-3; 30402-15-4; 55684-94-1; 38998-75-3; 136677-10-6; 43047-99-0; 51230-49-0; 25074-67-3; 74992-96-4; 94538-00-8; 5409-83-6; 64560-14-1; 54589-71-8; 24478-72-6; 58802-19-0; 58802-20-3; 71998-72-6; 74992-98-6; 43048-00-6; 57117-39-2; 57117-40-5; 57117-43-8; 75198-38-8; 79060-60-9; 91538-83-9; 91538-84-0; 92341-05-4; 92341-06-5; 92341-07-6; PCDF; CDF; “chlorinated dibenzofuran”; “chlorinated dibenzofurans”; “polychlorinated dibenzofuran”; “polychlorinated dibenzofurans”; chlorodibenzofuran; polychlorodibenzofuran; monochlorodibenzofuran; dichlorodibenzofuran; heptachlorodibenzofuran; octachlorodibenzofuran; perchlorodibenzofuran; trichlorodibenzofuran; tetrachlorodibenzofuran; pentachlorodibenzofuran; hexachlorodibenzofuran
NIH RePORTER
09/2022 | Fiscal Year: Active Projects; Text Search: “DCDF” OR “diCDF” OR “di-CDF” OR “HCDF” OR “heptaCDF” OR “hepta-CDF” OR “hexaCDF” OR “hexa-CDF” OR “HpCDF” OR “HxCDF” OR “moCDF” OR “monoCDF” OR “mono-CDF” OR “OCDF” OR “octaCDF” OR “octa-CDF” OR “PCDF” OR “PeCDF” OR “pentaCDF” OR “penta-CDF” OR “Tcdbf” OR “TCDF” OR “tetraCDF” OR “tetra-CDF” OR “triCDF” OR “tri-CDF” OR “DCDFs” OR “diCDFs” OR “di-CDFs” OR “HCDFs” OR “heptaCDFs” OR “hepta-CDFs” OR “hexaCDFs” OR “hexa-CDFs” OR “HpCDFs” OR “HxCDFs” OR “moCDFs” OR “monoCDFs” OR “mono-CDFs” OR “OCDFs” OR “octaCDFs” OR “octa-CDFs” OR “PCDFs” OR “PeCDFs” OR “pentaCDFs” OR “penta-CDFs” OR “Tcdbfs” OR “TCDFs” OR “tetraCDFs” OR “tetra-CDFs” OR “triCDFs” OR “tri-CDFs” OR “chlorodibenzofuran” OR “polychlorodibenzofuran” OR “monochlorodibenzofuran” OR “dichlorodibenzofuran” OR “trichlorodibenzofuran” OR “tetrachlorodibenzofuran” OR “pentachlorodibenzofuran” OR “hexachlorodibenzofuran” OR “heptachlorodibenzofuran” OR “octachlorodibenzofuran” OR “perchlorodibenzofuran” OR “chlorinated dibenzofuran” OR “polychlorinated dibenzofuran” OR “chlorodibenzofurans” OR “polychlorodibenzofurans” OR “monochlorodibenzofurans” OR “dichlorodibenzofurans” OR “trichlorodibenzofurans” OR “tetrachlorodibenzofurans” OR “pentachlorodibenzofurans” OR “hexachlorodibenzofurans” OR “heptachlorodibenzofurans” OR “octachlorodibenzofurans” OR “perchlorodibenzofurans” OR “chlorinated dibenzofurans” OR “polychlorinated dibenzofurans” OR “chlorinated dibenzofuran” OR “polychlorinated dibenzofuran” OR “monochlorinated dibenzofuran” OR “dichlorinated dibenzofuran” OR “trichlorinated dibenzofuran” OR “tetrachlorinated dibenzofuran” OR “pentachlorinated dibenzofuran” OR “hexachlorinated dibenzofuran” OR “heptachlorinated dibenzofuran” OR “octachlorinated dibenzofuran” OR “perchlorinated dibenzofuran” OR “dipolychlorinated dibenzofuran” OR “tripolychlorinated dibenzofuran” OR “tetrapolychlorinated dibenzofuran” OR “pentapolychlorinated dibenzofuran” OR “hexapolychlorinated dibenzofuran” OR “heptapolychlorinated dibenzofuran” OR “octapolychlorinated dibenzofuran” OR “perpolychlorinated dibenzofuran” OR “polypolychlorinated dibenzofuran” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
| Fiscal Year: Active Projects; Text Search: “chlorinated dibenzofurans” OR “polychlorinated dibenzofurans” OR “monochlorinated dibenzofurans” OR “dichlorinated dibenzofurans” OR “trichlorinated dibenzofurans” OR “tetrachlorinated dibenzofurans” OR “pentachlorinated dibenzofurans” OR “hexachlorinated dibenzofurans” OR “heptachlorinated dibenzofurans” OR “octachlorinated dibenzofurans” OR “perchlorinated dibenzofurans” OR “dipolychlorinated dibenzofurans” OR “tripolychlorinated dibenzofurans” OR “tetrapolychlorinated dibenzofurans” OR “pentapolychlorinated dibenzofurans” OR “hexapolychlorinated dibenzofurans” OR “heptapolychlorinated dibenzofurans” OR “octapolychlorinated dibenzofurans” OR “perpolychlorinated dibenzofurans” OR “polypolychlorinated dibenzofurans” OR “chloro dibenzofuran” OR “polychloro dibenzofuran” OR “monochloro dibenzofuran” OR “dichloro dibenzofuran” OR “trichloro dibenzofuran” OR “tetrachloro dibenzofuran” OR “pentachloro dibenzofuran” OR “hexachloro dibenzofuran” OR “heptachloro dibenzofuran” OR “octachloro dibenzofuran” OR “perchloro dibenzofuran” OR “chloro dibenzofurans” OR “polychloro dibenzofurans” OR “monochloro dibenzofurans” OR “dichloro dibenzofurans” OR “trichloro dibenzofurans” OR “tetrachloro dibenzofurans” OR “pentachloro dibenzofurans” OR “hexachloro dibenzofurans” OR “heptachloro dibenzofurans” OR “octachloro dibenzofurans” OR “perchloro dibenzofurans” OR “dibenzofuran, chloro-” OR “dibenzofuran, dichloro-” OR “dibenzofuran, trichloro-” OR “dibenzofuran, tetrachloro-” OR “dibenzofuran, pentachloro-” OR “dibenzofuran, hexachloro-” OR “dibenzofuran, heptachloro-” OR “Dibenzofuran, octachloro-” OR “monochlordibenzofuran” OR “chlorinated dibenzo-furan” OR “polychlorinated dibenzo-furan” OR “chlorinated dibenzo-furans” OR “dibenzofurans, chlorinated” OR “hepta chloro furans” OR “heptachlorofurans” OR “penta chloro furans” OR “polychlorinated dibenzo-furans” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
| Fiscal Year: Active Projects; Text Search: “chlorodiphenylene oxide” OR “monochlorodiphenylene oxide” OR “dichlorodiphenylene oxide” OR “trichlorodiphenylene oxide” OR “tetrachlorodiphenylene oxide” OR “pentachlorodiphenylene oxide” OR “hexachlorodiphenylene oxide” OR “heptachlorodiphenylene oxide” OR “octachlorodiphenylene oxide” OR “perchlorodiphenylene oxide” OR “polychlorodiphenylene oxide” OR “chlorodiphenylene oxides” OR “monochlorodiphenylene oxides” OR “dichlorodiphenylene oxides” OR “trichlorodiphenylene oxides” OR “tetrachlorodiphenylene oxides” OR “pentachlorodiphenylene oxides” OR “hexachlorodiphenylene oxides” OR “heptachlorodiphenylene oxides” OR “octachlorodiphenylene oxides” OR “perchlorodiphenylene oxides” OR “polychlorodiphenylene oxides” OR “12378 PeCDFuran” OR “Dibenzofuran, 1,2,3,4,6,7,8,9-octachloro-” OR “Dibenzofuran, 1,2,3,4,6,7,8-heptachloro-” OR “Dibenzofuran, 1,2,3,4,6,7,9-heptachloro-” OR “Dibenzofuran, 1,2,3,4,6,8,9-heptachloro-” OR “Dibenzofuran, 1,2,3,4,7,8,9-heptachloro-” OR “Dibenzofuran, 1,2,3,4,7,8-hexachloro-” OR “Dibenzofuran, 1,2,3,4,8-pentachloro-” OR “Dibenzofuran, 1,2,3,6,7,8-hexachloro-” OR “Dibenzofuran, 1,2,3,7,8,9-hexachloro-” OR “Dibenzofuran, 1,2,3,7,8-pentachloro-” OR “Dibenzofuran, 1,2,4,6,7,9-hexachloro-” OR “Dibenzofuran, 1,3,7,8-tetrachloro-” OR “Dibenzofuran, 2,3,4,6,7,8-hexachloro-” OR “Dibenzofuran, 2,3,4,7,8-pentachloro-” OR “Dibenzofuran, 2,3,6,8-tetrachloro-” OR “Dibenzofuran, 2,3,7,8-tetrachloro-” OR “Dibenzofuran, 2,3,7,8-tetra-chloro-” OR “Dibenzofuran, 3-chloro-” OR “Dibenzofuran, 2-chloro-” OR “Dibenzofuran, 2,4,8-trichloro-” OR “Dibenzofuran, 1,3-dichloro-” OR “Dibenzofuran, 2,4,6,8-tetrachloro-” OR “Dibenzofuran, 1,2,7,8-tetrachloro-” OR “Dibenzofuran, 1,3,6,8-tetrachloro-” OR “Dibenzofuran, 1,2,3,4-tetrachloro-” OR “Dibenzofuran, 2,8-dichloro-” OR “Dibenzofuran, 1,4,8-trichloro-” OR “Dibenzofuran, 2,3,6,7-tetrachloro-” OR “Dibenzofuran, 3,4,6,7-tetrachloro-” OR “Dibenzofuran, 2,3,4,6,7-pentachloro-” OR “Dibenzofuran, 2,7-dichloro-” OR “Dibenzofuran, 1,2,3,6,8,9-hexachloro-” OR “Dibenzofuran, 1,2,3,4,6,7-hexachloro-” OR “Dibenzofuran, 1,2,3,4,6,9-hexachloro-” OR “Dibenzofuran, 1,2,3,4,7,9-hexachloro-” OR “Dibenzofuran, 1,3,4,6,7,9-hexachloro-” OR “Dibenzofuran, 1,2,3,6,7,9-hexachloro-” OR “Dibenzofuran, 1,2,3,4,8,9-hexachloro-” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
| Fiscal Year: Active Projects; Text Search: “CDD/F” OR “DCDD/F” OR “diCDD/F” OR “HCDD/F” OR “HpCDD/F” OR “HxCDD/F” OR “MCDD/F” OR “moCDD/F” OR “monoCDD/F” OR “OCDD/F” OR “PCDD/F” OR “PeCDD/F” OR “TCDD/F” OR “triCDD/F” OR “CDD/Fs” OR “DCDD/Fs” OR “diCDD/Fs” OR “HCDD/Fs” OR “HpCDD/Fs” OR “HxCDD/Fs” OR “MCDD/Fs” OR “moCDD/Fs” OR “monoCDD/Fs” OR “OCDD/Fs” OR “PCDD/Fs” OR “PeCDD/Fs” OR “TCDD/Fs” OR “triCDD/Fs” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2022 results were:

- Number of records identified from PubMed, Toxline, and TOXCENTER (after duplicate removal): 663
- Number of records identified from other strategies: 30
- Total number of records to undergo literature screening: 693

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on CDFs:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 693
- Number of studies considered relevant and moved to the next step: 95

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 95
- Number of studies cited in the pre-public draft of the toxicological profile: 576
- Total number of studies cited in the profile: 633

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 July 2019 Literature Search Results and Screen for CDFs