# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## INTRODUCTION

In the environment, humans are rarely exposed to a single CDF congener; exposure is typically to complex mixtures of CDFs, CDDs, and PCBs. For most adverse health effects, 2,3,7,8-substituted CDFs and CDDs, and some non-ortho substituted PCBs share a common mechanism of action that is mediated through the Ah receptor. To evaluate the toxicity associated with exposure to mixtures of CDFs, CDDs, and PCBs, a TEF approach has been developed for 2,3,7,8-substituted congeners. The TEF approach involves assessment of the comparative effects of individual congeners on various biological endpoints; derivation of TEFs is based on the upper range of potency data for these effects. The TEF approach compares the relative potency of individual congeners to that of 2,3,7,8-TCDD, which is the most extensively studied of the halogenated aromatic hydrocarbons that interact with the Ah receptor. The TEF for 2,3,7,8-TCDD is defined as unity; TEFs for all other CDD congeners, CDFs, and dioxin-like PCBs are ≤1, thus reflecting their lower toxic potency. The WHO 2005 TEFs for 2,3,7,8-substituted CDFs are presented in Table A-1; see Table 2-1 for a list of TEFs for CDDs and PCBs (van den Berg et al. 2006). The TEQ for a mixture of congeners is the sum of the products of the TEFs for each congener and its concentration in the mixture.

Table A-1 Summary of World Health Organization (WHO) 2005 Toxicity Equivalency Factors (TEFs) for 2,3,7,8-Substituted Chlorodibenzofurans (CDFs)

Compound | TEF
2,3,7,8-TetraCDF | 0.1
1,2,3,7,8-PentaCDF | 0.03
2,3,4,7,8-PentaCDF | 0.3
1,2,3,4,7,8-HexaCDF | 0.1
1,2,3,6,7,8-HexaCDF | 0.1
1,2,3,7,8,9-HexaCDF | 0.1
2,3,4,6,7,8-HexaCDF | 0.1
1,2,3,4,6,7,8-HeptaCDF | 0.01
1,2,3,4,7,8,9-HeptaCDF | 0.01
OctaCDF | 0.0003

Source: van den Berg et al. 2006

MRLs derived for 2,3,7,8-substituted CDFs based on empirical data are presented in Table A-2. Toxicity data were only available for seven 2,3,7,8-substituted CDF congeners and the databases were considered adequate to derive an intermediate MRL for 1,2,3,7,8-pentaCDF; acute, intermediate and chronic oral MRLs for 2,3,4,7,8-pentaCDF; and an intermediate MRL for 1,2,3,6,7,8-hexaCDF.

Table A-2 Oral Minimal Risk Levels for 2,3,7,8-Substituted Chlorodibenzofurans (CDFs) Derived Using Congener Specific Toxicity Data

| MRL
CDF congener | Acute (μg/kg/day) | Intermediate (μg/kg/day) | Chronic (μg/kg/day)
2,3,7,8-TetraCDF | ND | ND | ND
1,2,3,7,8-PentaCDF | ND | 0.007 (7×10^−3^) | ND
2,3,4,7,8-PentaCDF | 0.0005 (5×10^−4^) | 0.000007 (7×10^−6^) | 0.000004 (4×10^−6^)
1,2,3,4,7,8-HexaCDF | ND | ND | ND
1,2,3,6,7,8-HexaCDF | ND | 0.005 (5×10^−3^) | ND
1,2,3,4,6,7,8-HeptaCDF | ND | ND | ND
OctaCDF | ND | ND | ND

ND = not derived due to inadequacies of the database

An alternative approach would be to derive MRLs for 2,3,7,8-substituted CDF congeners using 2,3,7,8-TCDD MRLs adjusted by the TEF and assuming that the TEFs are equal in magnitude across all exposure durations. As presented in ATSDR (1998), acute-, intermediate-, and chronic-duration oral MRLs are available for 2,3,7,8-TCDD. The acute oral MRL of 0.0002 μg/kg/day is based on impaired immune response in mice, the intermediate oral MRL of 0.00002 μg/kg/day is based on decreased thymus weight in guinea pigs, and the chronic oral MRL of 0.000001 μg/kg/day is based on developmental effects in monkeys. To calculate a TEF-derived CDF MRL, the duration-specific 2,3,7,8-TCDD MRL is divided by the TEF for the CDF congener. For example,

T E F - d e r i v e d a c u t e o r a l M R L f o r 2 , 3 , 4 , 7 , 8 - p e n t a C D F = 2 , 3 , 4 , 7 , 8 - T C D D a c u t e o r a l M R L ÷ T E F T E F - d e r i v e d a c u t e o r a l M R L f o r 2 , 3 , 4 , 7 , 8 - p e n t a C D F = 0 . 0002 μ g / k g / d a y ÷ 0 . 3 T E F - d e r i v e d a c u t e o r a l M R L f o r 2 , 3 , 4 , 7 , 8 - p e n t a C D F = 0 . 0007 μ g / k g / d a y

CDF MRLs derived using this approach are presented in Table A-3. The TEF-derived MRLs for the 2,3,4,7,8-pentaCDF chronic duration and for 1,2,3,6,7,8-hexaCDF intermediate duration are similar to empirically based MRLs. The TEF-derived intermediate oral MRL for 1,2,3,7,8-pentaCDF and the acute-duration MRL for 2,3,4,7,8-pentaCDF are an order of magnitude lower than the empirically based MRLs, and the TEF-derived intermediate oral MRL for 2,3,4,7,8-pentaCDF is an order of magnitude higher than the empirically based MRL. Empirical-based MRLs are preferred over the TEF-based MRLs because they are based on experimental data for the exposure route and duration.

Table A-3 Oral Minimal Risk Levels for Chlorodibenzofurans (CDFs) Derived Using a Toxicity Equivalency Factor (TEF) Approach

| MRL^a^
CDF congener | Acute (μg/kg/day) | Intermediate (μg/kg/day) | Chronic (μg/kg/day)
2,3,7,8-TetraCDF | 0.002 | 0.0002 | 0.00001
1,2,3,7,8-PentaCDF | 0.007 | 0.0007 | 0.00003
2,3,4,7,8-PentaCDF | 0.0007 | 0.00007 | 0.000003
1,2,3,4,7,8-HexaCDF | 0.002 | 0.0002 | 0.00001
1,2,3,6,7,8-HexaCDF | 0.002 | 0.0002 | 0.00001
1,2,3,7,8,9-HexaCDF | 0.002 | 0.0002 | 0.00001
2,3,4,6,7,8-HexaCDF | 0.002 | 0.0002 | 0.00001
1,2,3,4,6,7,8-HeptaCDF | 0.02 | 0.002 | 0.0001
1,2,3,4,7,8,9-HeptaCDF | 0.02 | 0.002 | 0.0001
OctaCDF | 0.7 | 0.07 | 0.003

a MRLs are calculated by dividing the MRL for 2,3,7,8-tetraCDD by the TEF. The acute, intermediate, and chronic oral MRLs for 2,3,7,8-CDD are 0.0002, 0.00002, and 0.000001 μg/kg/day (ATSDR 1998), respectively. The TEFs are presented in Table A-1.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,7,8-Tetrachlorodibenzofuran
CAS Numbers: | 51207-31-9
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute, Intermediate, and Chronic

MRL Summary: There are insufficient data for the derivation of acute-, intermediate-, or chronic-duration inhalation MRLs for 2,3,7,8-tetraCDF due to the lack of studies evaluating toxicity following inhalation exposure.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 2,3,7,8-tetraCDF following inhalation exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,7,8-Tetrachlorodibenzofuran
CAS Numbers: | 51207–31-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: The acute-duration oral database for 2,3,7,8-tetraCDF is considered inadequate for derivation of an MRL. Although the available studies identify several targets of toxicity, the database was considered inadequate for identifying the most sensitive target of toxicity.

Rationale for Not Deriving an MRL: A small number of acute oral exposure studies evaluated the toxicity of 2,3,7,8-tetraCDF. Studies by Moore et al. (1976, 1979) evaluated a number of potential endpoints following a single gavage exposure of monkeys, mice, or guinea pigs; the animals were allowed to recover for 30 (mice and guinea pigs) or 60 (monkeys) days. The remaining studies focused on thyroid hormone levels (Crofton et al. 2005; Ross et al. 2000) or developmental toxicity (Taura et al. 2014; Weber et al. 1984, 1985), but did not evaluate other endpoints. The results of these studies are summarized in Table A-4. A mouse study reporting no histological alterations in major tissues or organs at <6,000 μg/kg (Moore et al. 1976, 1979) is not included in the table.

Table A-4 Summary of Health Effects Following Acute-Duration Oral Exposure to 2,3,7,8-Tetrachlorodibenzofuran

Species, duration | NOAEL (μg/kg/day) | LOAEL (μg/kg/day) | Effect | Reference
Body weight effects
Monkey 1 day | | 500 | Decreased body weight gain (magnitude not reported) | Moore et al. 1979
| | 1,000 (serious LOAEL) | Weight loss
Guinea pig 1 day | | 1 | Decreased body weight gain (magnitude not reported) | Moore et al. 1979
| | 10 (serious LOAEL) | Rapid and progressive weight loss
Hematological effects
Monkey 1 day | | 500 | Mild anemia | Moore et al. 1979
Dermal and ocular effects
Monkey 1 day | | 500 | Facial edema, occluded or dilated ceruminous and sebaceous glands, nail loss, epidermal hyperkeratosis | Moore et al. 1979
| | | Occluded or dilated meibomian glands, eyelash loss
Endocrine effects
Rat 4 days | | 4.65 | Decrease (30%) in serum total T4 levels | Crofton et al. 2005
Rat 4 days | 0.3 | 1 | Decrease (26%) in serum total T4 levels | Ross et al. 2000
Immunological effects
Guinea pig 1 day | | 5 | Marked decrease in thymus size | Moore et al. 1979
Developmental effects
Mouse GD 10 | | 10 (serious LOAEL) | Hydronephrosis | Weber et al. 1984
Rat GD 15 | 15 | 50 | Altered sexual behavior in male offspring (ED_50_ for decreases in serum luteinizing hormone levels at 21.5–25.5 μg/kg and growth hormone at 12.6–27.4 μg/kg) | Taura et al. 2014
Mouse GD 10 | | 250 (serious LOAEL) | Fetal mortality, hydronephrosis | Weber et al. 1984
Mouse GD 10 | | 300 (serious LOAEL) | Hydronephrosis | Weber et al. 1985

ED_50_ = 50% effective dose; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; T4 = thyroxine

Four studies have identified LOAEL values between 1 and 10 μg/kg: decreases in serum total T4 levels in rats at 1 and 4.65 μg/kg (Crofton et al. 2005; Ross et al. 2000), marked decrease in thymus size in guinea pigs at 5 μg/kg (Moore et al. 1979), and fetal hydronephrosis at 10 μg/kg (Weber et al. 1984). Although the intermediate-duration data for 2,3,7,8-tetraCDF and acute- and intermediate-duration databases for 2,3,4,7,8-pentaCDF provide support for identifying the thyroid, thymus, and developing fetus as sensitive targets of toxicity, the acute-duration oral database for 2,3,7,8-tetraCDF was not considered adequate for identifying the most sensitive target of acute oral toxicity of 2,3,7,8-tetraCDF. The acute oral database is missing a reliable study that examined multiple potential targets of toxicity. The Crofton et al. (2005), Ross et al. (2000), and Weber et al. (1984) studies only examined single endpoints. The Moore et al. (1979) study examined a number of potential endpoints; however, interpretation of the findings is limited by inadequate reporting of the study results. The study evaluated three compounds (2,3,7,8-tetraCDF, 2,3,4,7,8-pentaCDF, and 2,3,7,8-tetrabromodibenzofuran) and it is unclear if the reported effects were observed for all three compounds or for just some of the compounds; no information on the incidence or severity of the lesions was provided. Additionally, the 30-day recovery period makes it difficult to identify NOAEL and LOAEL values.

Agency Contacts (Chemical Managers): Hana R. Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,7,8-Tetrachlorodibenzofuran
CAS Numbers: | 51207-31-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: The database was not considered adequate for derivation of an intermediate-duration oral MRL because deaths were observed at the lowest doses tested in two monkey studies (McNulty et al. 1981).

Rationale for Not Deriving an MRL: Four studies have evaluated the toxicity of 2,3,7,8-tetraCDF in laboratory animals orally exposed for intermediate durations. A summary of the results of these studies is presented in Table A-5. Several targets of toxicity were identified, including the thymus, stomach, bile duct, skin, and eyes. The lowest dose tested was 0.21 μg/kg/day; this dose level was associated with 1/3 deaths in monkeys (McNulty et al. 1981), thus precluding derivation of an MRL.

Table A-5 Summary of Health Effects Following Intermediate-Duration Oral Exposure to 2,3,7,8-Tetrachlorodibenzofuran

Species, duration | NOAEL (μg/kg/day) | LOAEL (μg/kg/day) | Effect | Reference
Monkey 6 months | | 0.21 (serious LOAEL) | - Death in 1/3 monkeys^a^; - Metaplasia of gastric mucosa; - Altered bile duct epithelium; - Partial sebaceous gland atrophy, hyperkeratotic nail beds; - Periorbital edema, meibomian gland enlargement; - Thymic atrophy^a^ | McNulty et al. 1981
Guinea pig 1 day/week 6 weeks | 0.17 | 0.5 | - Thymic atrophy; - Macrophage inhibition | Luster et al. 1979a, 1979b
Guinea pig 1 day/week 6 weeks | | 1 (serious LOAEL) | - 30% mortality^a^ | Luster et al. 1979a, 1979b
Monkey 2 months | | 2.1 (serious LOAEL) | - Death in 1/3 monkeys^a^; - Intramucosal cysts; - Altered bile duct epithelium; - Facial and body hair loss, nail loss, absent sebaceous glands^a^; - Periorbital edema; - Thymic atrophy^a^ | McNulty et al. 1981
Mouse 5 days/week 30 days | 100 | 300 | - 37% decrease in total leukocytes; - Marked decrease in thymus weight | Luster et al. 1979a, 1979b

a Considered a serious health effect.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Hana R. Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,7,8-Tetrachlorodibenzofuran
CAS Numbers: | 51207-31-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for the derivation of a chronic-duration oral MRL for 2,3,7,8-tetraCDF due to the lack of studies evaluating chronic toxicity.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 2,3,7,8-tetraCDF following chronic-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,8-Pentachlorodibenzofuran
CAS Numbers: | 67517–48-0
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute, Intermediate, Chronic

MRL Summary: There are insufficient data for the derivation of acute-, intermediate-, or chronic-duration inhalation MRLs for 1,2,3,4,8-pentaCDF due to the lack of studies evaluating toxicity following inhalation exposure.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,4,8-pentaCDF following inhalation exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,8-Pentachlorodibenzofuran
CAS Numbers: | 67517–48-0
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for the derivation of an acute-duration oral MRL for 1,2,3,4,8-pentaCDF due to the lack of studies evaluating toxicity following acute oral exposure.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,4,8-pentaCDF following acute-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,8-Pentachlorodibenzofuran
CAS Numbers: | 67517–48-0
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for the derivation of an acute-duration oral MRL for 1,2,3,4,8-pentaCDF because the only available intermediate-duration oral study did not identify targets of toxicity.

Rationale for Not Deriving an MRL: Information available on the intermediate-duration oral toxicity of 1,2,3,4,8-pentaCDF is limited to a 13-week dietary study in rats. In this study (Pluess et al. 1988a), no alterations in body weight, hematology, clinical chemistry, organ weight, or histology were observed at the highest dose tested (600 μg/kg/day). Thus, this study did not identify a critical target or provide dose-response data and was not considered adequate for derivation of an intermediate-duration oral MRL.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,8-Pentachlorodibenzofuran
CAS Numbers: | 67517-48-0
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for the derivation of a chronic-duration oral MRL for 1,2,3,4,8-pentaCDF due to the lack of studies evaluating toxicity following chronic oral exposure.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,4,8-pentaCDF following chronic-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,7,8-Pentachlorodibenzofuran
CAS Numbers: | 57117–41-6
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute, Intermediate, and Chronic

MRL Summary: There are insufficient data for the derivation of acute-, intermediate-, or chronic-duration inhalation MRLs for 1,2,3,7,8-pentaCDF due to the lack of studies evaluating toxicity following inhalation exposure.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,7,8-pentaCDF following inhalation exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,7,8-Pentachlorodibenzofuran
CAS Numbers: | 57117–41-6
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: The acute-duration oral database for 1,2,3,7,8-pentaCDF was considered inadequate for derivation of an MRL because the three available studies examined a limited number of endpoints and there is considerable uncertainty as to whether the most sensitive target of toxicity has been identified.

Rationale for Not Deriving an MRL: The available acute-duration studies for 1,2,3,7,8-pentaCDF, which are summarized in Table A-6, are limited in that they each only examined a single endpoint. Two studies observed decreases in serum total T4 levels in rats administered 1,2,3,7,8-pentaCDF for 4 days, with LOAEL values of 10 and 15.5 μg/kg/day (Crofton et al. 2005; Ross et al. 2000). Neither study evaluated other toxicologically relevant endpoints. The third study is a developmental toxicity study that reported an increase in the number of litters with hydronephrosis in the offspring of mice administered ≥30 μg/kg/day 1,2,3,7,8-pentaCDF on GDs 10–13 (Birnbaum et al. 1987a). At higher doses (≥100 μg/kg), the study reported decreases in maternal weight gain and increase in the number of litters with cleft palate; there were no effects on fetal viability, mortality, or weight at ≤200 μg/kg/day.

Table A-6 Summary of Health Effects Following Acute-Duration Oral Exposure to 1,2,3,7,8-Pentachlorodibenzofuran

Species, duration | NOAEL (μg/kg/day) | LOAEL (μg/kg/day) | Effect | Reference
Endocrine effects
Rat 4 days | | 15.6 | 30% decreased serum total T4 levels | Crofton et al. 2005
Rat 4 days | 3 | 10 | 15% decreased serum total T4 levels | Ross et al. 2000
Developmental effects
Mouse GDs 10–13 | 10 | 30 (serious LOAEL) | Hydronephrosis | Birnbaum et al. 1987a

GD = gestation day; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; T4 = thyroxine

Because the available studies examined a limited number of potential endpoints, the database was considered inadequate for derivation of an acute-duration oral MRL. Specifically, the database lacks studies examining the liver and thymus which have been identified as sensitive targets following intermediate-duration exposure to 1,2,3,7,8-pentaCDF.

Agency Contacts (Chemical Managers): Hana R. Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,7,8-Pentachlorodibenzofuran
CAS Numbers: | 57117–41-6
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.007 μg/kg/day (7xl0^−3^ μg/kg/day)
Critical Effect: | Increase in relative liver weight
Reference: | Pluess et al. 1988a
Point of Departure: | BMDL_1SD_ of 0.68 μg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 36
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.007 μg/kg/day (7×10^−3^ μg/kg/day) was derived for 1,2,3,7,8-pentaCDF based on increased relative liver weight in male rats exposed to 20 μg/kg/day 1,2,3,7,8-pentaCDF in the diet for 13 weeks (Pluess et al. 1988a). The MRL is derived from a BMDL_1SD_ of 0.68 μg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: One study evaluated the oral toxicity of 1,2,3,7,8-pentaCDF in laboratory animals following intermediate-duration oral exposure (Pluess et al. 1988a). In rats exposed to 20 μg/kg/day 1,2,3,7,8-pentaCDF in the diet for 13 weeks, decreased body weight gain (6.5–11%), increased relative liver weight (males only), histological alterations in the liver (hepatic vacuolization with lipid accumulation and single cell necrosis), and decreased absolute thymus weight were observed; no toxicologically relevant alterations were observed at 2 μg/kg/day.

The histological alterations in the liver, increased relative liver weight in males, and decreased thymus weight were selected as co-critical effects.

Selection of the Principal Study: The Pluess et al. (1988a) study was selected as the principal study because it had an adequate experimental design, examined multiple potential targets of toxicity, and provided dose-response data for sensitive endpoints.

Summary of the Principal Study:

Pluess N, Poiger H, Hohbach C, 1988a. Subchronic toxicity of some chlorinated dibenzofurans (PCDFs) and a mixture of PCDFs and chlorinated dibenzodioxins (PCDDs) in rats. Chemosphere. 17:973–984.

Groups of six male and six female Iva:SIV 50(SD) rats were exposed to 0, 2, 20, or 200 μg/kg 1,2,3,7,8-pentaCDF in the diet for 13 weeks. Daily doses were estimated using a reference food intake of 0.016 kg/day and reference body weight of 0.152 kg (EPA 1989b); the estimated doses were 0, 0.2, 2, and 20 μg/kg/day in the 0, 2, 20, and 200 μg/kg groups, respectively. The following parameters were used to evaluate toxicity: weekly body weight and food consumption measurements, hematological parameters (red blood cells, total and differential white blood cells, reticulocyte, and thrombocyte counts, hemoglobin levels, and packed cell volume), serum clinical chemistry indices (bilirubin, triglycerides, urea, cholesterol, alkaline phosphatase, ALT), organ weights (liver, thymus, spleen, kidneys, heart, and testes), and histopathology (lungs, liver, thymus, spleen, kidneys, heart, thyroid/parathyroids, adrenals, mesenteric and submandibular lymph nodes, uterus, ovaries, and testes).

No deaths were noted in either sex. Significant decreases in terminal body weight of approximately 6 and 11% were observed in males and females, respectively, exposed to 20 μg/kg/day. No alterations in food consumption were observed. Significantly increased packed cell volume (6.9 and 4.3%) were observed in males and females, respectively, and a 7% decrease in hemoglobin was observed in females at 20 μg/kg/day. No other significant hematological alterations were reported. Significantly decreased ALT (19%) and serum urea (15%) levels were observed in males at ≥2 μg/kg/day and decreased urea (23%) was observed in females at 20 μg/kg/day. No significant effects on serum bilirubin, cholesterol, alkaline phosphatase or triglycerides were observed. The toxicological significance of relatively small changes in hematological and serum chemistry indices is uncertain. A significant increase in relative liver weight (18.2%) in males and vacuolization with increased lipid content, single cell necrosis, and slight Kupffer cell hyperplasia (sex not specified) were observed at 20 μg/kg/day; the study did not provide incidence data. Significantly decreased absolute thymus weight (46 and 29% in males and females) was observed in both sexes at 20 μg/kg/day and histologic evidence of possible early thymic atrophy in females (no additional information provided) was observed at 20 μg/kg. No treatment-related histological effects were observed in the heart, adrenal glands, kidneys, lymph nodes, spleen, testes, uterus, or ovaries.

Selection of the Point of Departure for the MRL: A BMDL1SD of 0.68 μg/kg/day for decreases in thymus weight in female rats was selected as the point of departure (POD).

Benchmark dose (BMD) modeling was conducted to identify a potential POD using the relative liver weight in male and female rats and absolute thymus weight in the male and female rats from the Pluess et al. (1988a) study; the data are summarized in Table A-7. The lack of incidence data precluded using BMD modeling for the histological alterations in the liver. The data were fit to most of the available continuous models in EPA’s Benchmark Dose Software (BMDS, version 3.1.2) using the extra risk option. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined benchmark response (BMR). A BMR of 1 standard deviation from the control mean was selected in the absence of a biologically based BMR.

The model predictions for the increases in relative liver weight in male rats are shown in Table A-8. The best fitting model was the Exponential 4 model with constant variance, illustrated in Figure A-1; the model estimated BMD_1SD_ and BMDL_1SD_ values of 1.62 and 0.68 μg/kg/day, respectively. The model predictions for increased relative liver weight in female rats are shown in Table A-9. The best-fitting model was the Exponential 4 with constant variance (Figure A-2); the BMD_1SD_ estimated in this model was 1.67 μg/kg/day and the BMDL_1SD_ was 0.60 μg/kg/day. None of the models (with constant variance or nonconstant variance) provided adequate fit to the data for decreases in thymus weight in male rats. In female rats, the model predictions for decreased thymus weight are presented in Table A-10. All models provided adequate fit with constant variance. The best fitting model was the Exponential 5 model; this model estimated a BMD_1SD_ of 2.73 μg/kg/day and BMDL_1SD_ of 0.91 μg/kg/day; the model is presented in Figure A-3.

Table A-7 Relative Liver Weight and Absolute Thymus Weights in Male and Female Rats Exposed to 1,2,3,7,8-Pentachlorodibenzofuran in the Diet for 13 Weeks

Dose level (μg/kg/day) | Relative liver weight (mean±SD) (g/100 g) | | Absolute thymus weight (mean±SD) (g)
Dose level (μg/kg/day) | Males | Females | Males | Females
0 | 3.35±0.26 | 3.37±0.23 | 0.48±0.02 | 0.48±0.09
0.2 | 3.35±0.36 | 3.36±0.15 | 0.45±0.07 | 0.47±0.07
2 | 3.61±0.16 | 3.63±0.20^a^ | 0.42±0.07 | 0.43±0.04
20 | 3.95±0.19^a^ | 3.90±0.41 | 0.26±0.05^a^ | 0.34±0.06^a^

a Significantly different from controls, p<0.05.

SD = standard deviation

Source: Pluess et al. 1988a

Table A-8 Results from BMD Analysis (Constant Variance) of Relative Liver Weight in Male Rats Exposed to 1,2,3,7,8-Pentachlorodibenzofuran in the Diet for 13 Weeks (Pluess et al. 1988a)

Model | BMD_1SD_^a^ (μg/kg/day) | BMDL_1SD_^a^ (μg/kg/day) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (μg/kg/day) | BMDL_1SD_^a^ (μg/kg/day) | Test 4 p-value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential 2^d^ | 9.41 | 6.72 | 0.210 | 7.15 | 1.43 | −0.632
Exponential 3^d^ | 9.41 | 6.72 | 0.210 | 7.15 | 1.43 | −0.632
Exponential 4 ^d,e^ | 1.62 | 0.68 | 0.792 | 6.10 | 0.03 | 0.169
Exponential 5^d^ | | | NA | 8.03 | 0.00 | 0.001
Hill^d^ | | | NA | 8.03 | 0.00 | 0.01
Polynomial Degree 3^d^ | 8.97 | 6.26 | 0.220 | 7.06 | 1.42 | −0.613
Polynomial Degree 2^d^ | 8.97 | 6.26 | 0.220 | 7.06 | 1.42 | −0.613
Power^d^ | 8.97 | 6.26 | 0.220 | 7.06 | 1.42 | −0.613
Linear | 8.97 | 6.26 | 0.220 | 7.06 | 1.42 | −0.613

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model. There was an adequate fit to the variance when assuming constant variance. Of the models providing adequate fit, the BMDLs were not sufficiently close (differed by >3-fold); therefore, the model with the lowest BMDL was selected (Exponential 4 model).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control); NA = not applicable, goodness-of-fit test cannot be calculated

Figure A-1 Fit of Exponential Degree 4 Model (with Constant Variance) to Relative Liver Weight in Male Rats Exposed to 1,2,3,7,8-Pentachlorodibenzofuran

Table A-9 Results from BMD Analysis (Constant Variance) of Relative Liver Weight in Female Rats Exposed to 1,2,3,7,8-Pentachlorodibenzofuran in the Diet for 13 Weeks (Pluess et al. 1988a)

Model | BMD_1SD_^a^ (μg/kg/day) | BMDL_1SD_^a^ (μg/kg/day) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (μg/kg/day) | BMDL_1SD_^a^ (μg/kg/day) | Test 4 p-value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential 2^d^ | 11.13 | 7.64 | 0.207 | 9.36 | −0.12 | −0.59
Exponential 3^d^ | 11.13 | 7.64 | 0.207 | 9.36 | −0.12 | −0.59
Exponential 4 ^d,e^ | 1.67 | 0.60 | 0.734 | 8.32 | 0.05 | 0.22
Exponential 5^d^ | | | NA | 10.21 | 0.00 | 0.05
Hill^d^ | | | NA | 10.21 | 0.00 | 0.05
Polynomial Degree 3^d^ | 10.72 | 7.18 | 0.214 | 9.29 | 1.43 | −0.57
Polynomial Degree 2^d^ | 10.72 | 7.18 | 0.214 | 9.29 | 1.43 | −0.57
Power^d^ | 10.72 | 7.18 | 0.214 | 9.29 | 1.43 | −0.57
Linear | 10.72 | 7.18 | 0.214 | 9.29 | 1.43 | −0.57

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model. There was an adequate fit to the variance when assuming constant variance. Of the reliable models providing adequate fit, the BMDLs were not sufficiently close (differed by >3-fold); therefore, the model with the lowest BMDL was selected (Exponential 4).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control); NA = not applicable, goodness-of-fit test cannot be calculated

Figure A-2 Fit of Exponential Degree 4 Model (with Constant Variance) to Relative Liver Weight in Female Rats Exposed to 1,2,3,7,8-Pentachlorodibenzofuran

Table A-10 Results from BMD Analysis (Constant Variance) of Absolute Thymus Weight in Female Rats Exposed to 1,2,3,7,8-Pentachlorodibenzofuran in the Diet for 13 Weeks (Pluess et al. 1988a)

Model | BMD_1SD_^a^ (μg/kg/day) | BMDL_1SD_^a^ (μg/kg/day) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (μg/kg/day) | BMDL_1SD_^a^ (μg/kg/day) | Test 4 p-value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential 2^d^ | 8.94 | 5.74 | 0.590 | −58.634 | −0.836 | 0.531
Exponential 3^d^ | 8.94 | 5.74 | 0.590 | −58.634 | −0.836 | 0.531
Exponential 4^d^ | 8.93 | 0.77 | 0.305 | −56.636 | −0.835 | 0.530
Exponential 5 ^d,e^ | 2.73 | 0.91 | 0.905 | −57.676 | 0.013 | 0.077
Hill^d^ | | | 0.921 | −57.676 | 0.015 | 0.063
Polynomial Degree 3^d^ | 9.89 | 6.76 | 0.554 | −58.509 | −0.879 | 0.566
Polynomial Degree 2^d^ | 9.89 | 6.76 | 0.554 | −58.509 | −0.879 | 0.566
Power^d^ | 9.89 | 6.75 | 0.554 | −58.509 | −0.879 | 0.566
Linear | 9.89 | 6.76 | 0.554 | −58.509 | −0.879 | 0.566

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model. There was an adequate fit to the variance when assuming constant variance. Of the models providing adequate fit, the BMDLs were not sufficiently close (differed by >3-fold); therefore, the model with the lowest BMDL was selected (Exponential 5 model).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control)

Figure A-3 Fit of Exponential 5 Model (with Constant Variance) to Absolute Thymus Weight in Female Rats Exposed to 1,2,3,7,8-Pentachlorodibenzofuran

Potential POD candidates based on histological alterations in the liver, increased relative liver weight in male and female rats, and decreased absolute thymus weight in male and female rats are summarized in Table A-11. The BMDL_1SD_ of 0.68 μg/kg/day for increased relative liver weight in male rats was selected as the POD because it has the lowest BMD_1SD_.

Table A-11 Candidate Points of Departure 1,2,3,7,8-Pentachlorodibenzofuran Intermediate-Duration Oral MRL

Endpoint | NOAEL (μg/kg/day) | LOAEL (μg/kg/day) | BMD_1SD_ (μg/kg/day) | BMDL_1SD_ (μg/kg/day)
Histological alterations in the liver (vacuolization with increased lipid content, single cell necrosis and slight Kupffer cell hyperplasia) | 2 | 20
Increases in relative liver weight in males | | | 1.62 | 0.68
Increases in relative liver weight in females | | | 1.67 | 0.60
Decrease in absolute thymus weight in males | 2 | 20
Decrease in absolute thymus weight in females | | | 2.73 | 0.91

BMD = benchmark dose; BMDL = 95% lower limit on the BMD; MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level; LOAEL = lowest-observed-adverse-effect level

Calculations

Uncertainty Factor: The BMDL_1SD_ is divided by a total uncertainty factor (UF) of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_1 SD_ ÷ UF 0 . 68 μ g / kg / day ÷ (10 × 10) = 0 . 007 μ g / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Identification of the thymus as a critical target of 1,2,3,7,8-pentaCDF toxicity is supported by findings of decreased thymus weight, thymic atrophy, and impaired immune response in studies evaluating other 2,3,7,8-substituted congeners (Brewster et al. 1988; Johnson et al. 2000; Kerkvliet et al. 1985; Luster et al. 1979a, 1979b; McNulty et al. 1981; Moore et al. 1979, NTP 2006; Oishi et al. 1978; Oishi and Hiraga 1980; Pluess et al. 1988a, 1988b; Taura et al. 2014).

Agency Contacts (Chemical Managers): Hana R. Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,7,8-Pentachlorodibenzofuran
CAS Numbers: | 57117–41-6
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for the derivation of a chronic-duration oral MRL for 1,2,3,7,8-pentaCDF due to the lack of studies evaluating chronic toxicity.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,7,8-pentaCDF following chronic-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,7,8-Pentachlorodibenzofuran
CAS Numbers: | 57117–31-4
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute, Intermediate, and Chronic

MRL Summary: There are insufficient data for the derivation of acute-, intermediate-, or chronic-duration inhalation MRLs for 2,3,4,7,8-pentaCDF due to the lack of studies evaluating toxicity following inhalation exposure.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 2,3,4,7,8-pentaCDF following inhalation exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,7,8-Pentachlorodibenzofuran
CAS Numbers: | 57117–31-4
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.0005 μg/kg/day (5×10^−4^ μg/kg/day)
Critical Effect: | Decreased thymus weight in pups
Reference: | Madsen and Larsen 1989
Point of Departure: | NOAEL of 0.5 μg/kg/day
Uncertainty and Modifying Factors: | 100 (UF) 10 (MF)
LSE Graph Key: | 12
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.0005 μg/kg/day (5×10^−4^ μg/kg/day) was derived for 2,3,4,7,8-pentaCDF based on decreases in pup thymus weight in the offspring of rats administered 2 μg/kg on GD 16 (Madsen and Larsen 1989); the NOAEL for this effect was 0.5 μg/kg. The MRL is based on a NOAEL of 0.5 μg/kg and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) and a modifying factor of 10 for database deficiencies.

Selection of the Critical Effect: A number of laboratory animal studies have evaluated the toxicity of 2,3,4,7,8-pentaCDF following acute-duration oral exposure. A summary of the results of these studies are presented in Table A-12. Studies by Brewster et al. (1988) and Moore et al. (1979) examined a range of endpoints and reported hepatic and immunological effects at the lowest doses tested; however, both studies included a 30–35-day recovery post-exposure. Studies evaluating immunological endpoints reported decreased thymus weight at ≥3 μg/kg/day (Brewster et al. 1988; Moore et al. 1979; Taura et al. 2014) and impaired immune response at 10.119 μg/kg/day (Johnson et al. 2000). Developmental studies have reported decreased fetal weight, impaired development of the reproductive system, decreased thymus weight, and hydronephrosis (Birnbaum et al. 1987a, 1987b; Couture et al. 1989; Madsen and Larsen 1989; Salisbury and Marcinkiewicz 2002).

Several studies have identified LOAEL values between 1 and 5 μg/kg. Effects observed at these doses include decreases in mature offspring weight at 1 μg/kg (decreased pup body weight was observed at 10 μg/kg) (Salisbury and Marcinkiewicz 2002), impaired development of the reproductive system at 1 μg/kg (Salisbury and Marcinkiewicz 2002), decreased neonatal relative thymus weight at 2 μg/kg (Madsen and Larsen 1989), decreased thymus size in adults at 3 μg/kg (Moore et al. 1979), and hydronephrosis at 5 μg/kg (Birnbaum et al. 1987b). Only one of these studies identified a NOAEL; no significant alterations in neonatal thymus weight were observed at 0.5 μg/kg (Madsen and Larsen 1989). These data provide evidence that immunotoxicity and developmental toxicity are the most sensitive targets of toxicity following acute oral exposure to 2,3,4,7,8-pentaCDF.

Table A-12 Summary of Health Effects Following Acute-Duration Oral Exposure to 2,3,4,7,8-Pentachlorodibenzofuran

Species, duration | NOAEL (μg/kg/day) | LOAEL (μg/kg/day) | Effect | Reference
Hepatic effects
Rat 1 day | | 100 | Lipid accumulation, increased cholesterol (60%) | Brewster et al. 1988
Endocrine effects
Rat 4 days | | 27.5 | Decrease in serum total T4 levels (30%) | Crofton et al. 2005
Rat 4 days | 9 | 30 | Decrease in serum total T4 levels (27%) | Ross et al. 2000
Immunological effects
Guinea pig 1 day | | 3 | Marked decrease in thymus size | Moore et al. 1979
Mouse 1 day | | 10.119 | 50% reduction in immune response to SRBC | Johnson et al. 2000
Rat 1 day | | 71.9 | ED_50_ for decreased thymus weight in pubertal rats | Taura et al. 2014
Rat 1 day | | 100 | Decreased thymus weight (30–90%) | Brewster et al. 1988
Developmental effects
Rat GD 15 | | 1 (serious LOAEL) | Decreased offspring body weight on PND 140 (~7%), decreased number of days spent in estrus (33%), and decreased ovulation rate (57%) | Salisbury and Marcinkiewicz 2002
Rat GD 16 | 0.5 | 2 | Decreased neonatal relative thymus weight (14%) | Madsen and Larsen 1989
Mouse GDs 10–13 | | 5 (serious LOAEL) | Hydronephrosis | Birnbaum et al. 1987b
Mouse GDs 10–13 | 3 | 10 (serious LOAEL) | Hydronephrosis | Birnbaum et al. 1987a
Rat GD 15 | | 12.6 | ED_50_ for decreased growth hormone in female fetuses | Taura et al. 2014
Rat GD 8, 10, or 12 | | 30 | Decreased fetal body weight | Couture et al. 1989
Rat GD 15 | 15 | 50 | Altered sexual behavior in male offspring | Taura et al. 2014
Rat GD 15 | | 56.3 | ED_50_ for decreased fetal weights in males | Taura et al. 2014
Mouse GDs 10–13 | | 80 | Impaired embryonic erythropoiesis in the liver, increased number of hepatocytes, reduction in liver sinusoids | Khera 1992

ED_50_ = 50% effective dose; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; PND = postnatal day; SRBC = sheep red blood cell; T4 = thyroxine

Selection of the Principal Study: The Madsen and Larsen (1989) study was selected as the principal study because it identified a NOAEL for developmental effects.

Summary of the Principal Study:

Madsen C, Larsen JC. 1989. Relative toxicity of chlorinated dibenzo-p-dioxins, and dibenzofurans measured by thymus weight and liver enzyme induction in perinatally dosed rats, 2,3,7,8-TCDD, 2,3,4,7,8-PeCDF, 1,2,3,7,8-PeCDD. Chemosphere 18:955–966.

Groups of 8–10 pregnant Wistar, SPF-rats were administered via gavage 0, 0.5, 2, or 10 μg/kg 2,3,4,7,8-pentaCDF in soybean oil on GD 16. Pups were sacrificed at 1 week of age. Parameters used to assess toxicity in the pups included measurement of thymus and liver weights, and activities of microsomal monooxygenase, 7-ethoxycoumarin deethylase, biphenyl-2-hydroxylase, and biphenyl-4-hydroxylase. No additional developmental endpoints and no maternal endpoints were evaluated. The investigators also conducted a cross-fostering study in which groups of 10 pregnant rats were administered 0 or 10 μg/kg 2,3,4,7,8-pentaCDF in soybean oil on GD 16. Within 17 hours of birth, the in utero exposed pups were fostered by control dams and control pups were fostered by 2,3,4,7,8-pentaCDF-exposed dams.

Dose-related decreased mean litter relative thymus weights were observed (approximately 6, 14, and 30% at 0.5, 2, and 10 μg/kg, respectively). The decrease in thymus weight was statistically significant (p≤0.05) at 2 ug/kg using the Mann-Whitney test. Dose-related increased mean fetal hepatic microsomal 7-ethoxycoumarin deethylase, biphenyl-2-hydroxylase, and biphenyl-4-hydroxylase activities were observed at 2 μg/kg. In the cross-fostering experiment, significant decreases in relative thymus weights were observed in the in utero only, lactation only, and in utero and lactation groups. The investigators noted that in utero and exposure via milk contributed almost equally to the thymus effects in the offspring.

Selection of the Point of Departure for the MRL: The NOAEL of 0.5 μg/kg was selected as the point of departure for the MRL. The thymus weight data presented in the Madsen and Larsen (1989) study was not considered suitable for benchmark dose (BMD) modeling because mean thymus weights and standard deviations were not reported.

Uncertainty Factor: The NOAEL is divided by a total uncertainty factor (UF) of 100 and modifying factor (MF) of 10:

- UF of 10 for extrapolation from animals to humans
- UF of 10 for human variability
- MF of 10 for database deficiencies

A modifying factor of 10 was used to account for the lack of a study identifying a NOAEL for impaired development of the reproductive system and the steep dose-response between the NOAEL of 0.5 μg/kg in the Madsen and Larsen (1989) study and the serious LOAEL of 1 μg/kg in the Salisbury and Marcinkiewicz (2002) study.

MRL = LOAEL ÷ (UF × MF) 0 . 5 μ g / kg / day ÷ (10 × 10 × 10) = 0 . 0005 μ g / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: As discussed in the Selection of the Critical Effect section, several studies support developmental toxicity, including impaired development of the reproductive system, as a sensitive target and several studies have identified similar LOAEL values for developmental and immunological endpoints.

Agency Contacts (Chemical Managers): Hana R. Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,7,8-Pentachlorodibenzofuran
CAS Numbers: | 57117–31-4
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.000007 μg/kg/day (7 × 10^−6^ μg/kg/day)
Critical Effect: | Decreased serum total T4 levels
Reference: | NTP 2006
Point of Departure: | BMDL_1SD_ of 0.00095 μg/kg (BMDL_ADJ_ of 0.00068 μg/kg/day)
Uncertainty Factor: | 100
LSE Graph Key: | 38
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.000007 μg/kg/day (7×10^−6^ μg/kg/day) was derived for 2,3,4,7,8-pentaCDF based on decreases in serum total T4 levels in female rats administered via gavage 0.006 μg/kg 2,3,4,7,8-pentaCDF 5 days/week for 31 weeks (NTP 2006). The MRL is based on a BMDL_1SD_ of 0.00098 μg/kg, which was adjusted to continuous duration exposure to a BMDL_ADJ_ of 0.00068 μg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Four studies evaluated the toxicity of 2,3,4,7,8-pentaCDF following intermediate-duration oral exposure. The targets of toxicity include the thyroid gland, liver, thymus, and reproductive system; the NOAEL and LOAEL values for these effects are presented in Table A-13.

Table A-13 Summary of Health Effects Following Intermediate-Duration Oral Exposure to 2,3,4,7,8-Pentachlorodibenzofuran

Species, duration | NOAEL (μg/kg/day) | LOAEL (μg/kg/day) | Effect | Reference
Rat 14 weeks (5 days/week) | 0.02 | 0.044 | - Thyroid gland follicular cell hypertrophy; - Hepatocellular hypertrophy; - Decreased serum total T4 levels (25%) | NTP 2006
Rat 14 weeks (5 days/week) | 0.02 | 0.092 | - Thyroid gland follicular cell hypertrophy; - Hepatocellular hypertrophy; - Decreased serum total T4 levels (25%) | NTP 2006
Rat 31 weeks (5 days/week) | | 0.006 | - Decreased serum total T4 levels (16%); - Hepatocellular hypertrophy | NTP 2006
Rat 31 weeks (5 days/week) | | 0.044 | - Decreased serum total T4 levels (16%); - Hepatocellular hypertrophy | NTP 2006
Rat 13 weeks (daily) | | 0.2 | - Increased serum bilirubin levels (35–52%); - Decreased serum triglyceride levels in males (18%); - Slight fatty degeneration in liver; - Decreased absolute thymus weight in females (24%) | Pluess et al. 1988a
Mouse 5 times in 16 weeks | 30 | 100 | - Endometriosis | Johnson et al. 1997

The available data suggest that the alterations in thyroid hormone levels and hepatocellular hypertrophy are the most sensitive endpoints following intermediate-duration oral exposure to 2,3,4,7,8-pentaCDF. At higher doses, decreased thymus weight, and endometriosis were observed.

Selection of the Principal Study: The 31-week NTP (2006) study was selected as the principal study because it identified lower LOAEL values for thyroid and liver effects than the 14-week NTP (2006) study and for decreased thymus weight or endometriosis.

Summary of the Principal Study:

NTP. 2006. Toxicology and carcinogenesis studies of 2,3,4,7,8-pentachlorodibenzofuran (PeCDF) (CAS No. 57117–31-4) in female Harlan Sprague-Dawley rats (gavage studies). NTP TR 525 .

Groups of 10 female Harlan Sprague-Dawley rats were administered via gavage 0, 6, 20, 44, 92, or 200 ng/kg (0, 0.006, 0.02, 0.044, 0.092, and 0.2 μg/kg) 2,3,4,7,8-pentaCDF in a corn oil:acetone vehicle 5 days/week for 31 weeks. The following parameters were used to assess toxicity: clinical observations, body weight, organ weights (kidney, liver, lung, ovary, spleen, thymus, and thyroid), thyroid hormone levels (TSH, T3, T4), cell proliferation measured in liver and duodenum samples, cytochrome P450 activities in liver and lung samples, and histopathological examination of the adrenal gland, liver, lung, mammary gland, ovary, pancreas, pituitary gland, spleen, stomach, thymus, thyroid gland, uterus, and vagina in the 0 and 0.2 μg/kg groups; liver, thymus, and uterus were evaluated in all groups.

No deaths were observed in rats exposed for 31 weeks. Body weights in the CDF groups were within 10% of controls. After 31 weeks of exposure, significantly decreased serum total T4 levels were observed at ≥0.006 μg/kg (16, 18, 25, 29, and 40% at 0.006, 0.02, 0.044, 0.092, and 0.2 μg/kg, respectively), serum free T4 levels were decreased at 0.2 μg/kg, and serum total T3 levels were increased at 0.092 and 0.2 μg/kg. Increases in relative liver weight were observed at ≥0.02 μg/kg. Significant increases in the incidence of hepatocellular hypertrophy and liver pigmentation were observed at ≥0.044 μg/kg. Nonsignificant increases in the incidence and severity of cystic endometrial hyperplasia were also observed at 0.2 μg/kg. The incidence of thymus cortical atrophy was nonsignificantly increased in rats exposed to 0.2 μg/kg; an increase in the severity of the lesion was also observed.

Selection of the Point of Departure for the MRL: The point of departure is a BMDL_1SD_ of 0.00095 μg/kg for decreases in serum total T4 levels.

BMD modeling was conducted to identify a potential POD using the data for serum total T4 levels and hepatocellular hypertrophy incidence, which are summarized in Table A-14. The data were fit to all available continuous models (serum T4 levels) or dichotomous models (hepatocellular hypertrophy) in EPA's BMDS (version 3.1.2) using the extra risk option. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. A BMR of 1 standard deviation from the control mean was selected in the absence of a biologically based BMR for the serum T4 levels. A BMR of 10% extra risk was selected for the hepatocellular hypertrophy modeling.

Table A-14 Serum Total T4 Levels in Female Rats Administered 2,3,4,7,8-Pentachlorodibenzofuran 5 Days/Week for 31 Weeks

Dose Level (μg/kg) | Number of animals per group | Serum total T4 levels | | Hepatocellular hypertrophy incidence
Dose Level (μg/kg) | Number of animals per group | Mean (μg/dL) | Standard deviation^a^ | Hepatocellular hypertrophy incidence
0 | 10 | 4.17 | 0.329 | 0/10
0.006 | 10 | 3.52^b^ | 0.471 | 1/10
0.02 | 10 | 3.41^b^ | 0.648 | 3/10
0.044 | 10 | 3.12^b^ | 1.031 | 6/10^b^
0.092 | 10 | 2.96^b^ | 0.772 | 8/10^b^
0.2 | 10 | 2.5^b^ | 0.705 | 8/10^b^

a Standard deviations estimated from reported standard error of the mean (SEM).

b Significantly different from vehicle control, p<0.01.

Source: NTP 2006

None of the available BMD models provided adequate fit to the serum T4 data with constant variance. Three models (Exponential 4, Exponential 5, and Hill) provided adequate fit with nonconstant variance; the results are summarized in Table A-15. The BMDL values from these models were sufficiently close and the model with the lowest AIC (Hill model) was selected. This model estimated a BMD_1SD_ of 0.00251 μg/kg and a BMDL_1SD_ of 0.00095 μg/kg. The Hill model fit is illustrated in Figure A-4.

Most dichotomous models provided adequate fit to the hepatocellular hypertrophy incidence data; the results are summarized in Table A-16. The BMDL values were not sufficiently close and the model with the lowest BMDL_10_ (LogProbit model) was selected; the fit of the LogProbit model is illustrated in Figure A-5. This model estimated a BMD_10_ of 0.0054 μg/kg and a BMDL_10_ of 0.0010 μg/kg.

The BMDL_1SD_ of 0.00095 μg/kg for alterations in serum T4 levels was selected as the POD because the BMD_1SD_ for this endpoint is lower than the BMD_10_ for hepatocellular hypertrophy.

Table A-15 Results from BMD Analysis (Nonconstant Variance) of Serum Total T4 Levels in Female Rats Administered 2,3,4,7,8-Pentachlorodibenzofuran 5 Days/Week for 31 Weeks (NTP 2006)

Model | BMD_1SD_^a^ (μg/kg) | BMDL_1SD_^a^ (μg/kg) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (μg/kg) | BMDL_1SD_^a^ (μg/kg) | Test 4 p-value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential 2^d^ | | | 0.00254 | 135.204 | −0.181 | 2.111
Exponential 3^d^ | | | 0.00254 | 124.016 | −0.815 | 0.226
Exponential 4^d^ | 0.00332 | 0.00219 | 0.362 | 124.016 | −0.807 | 0.225
Exponential 5^d^ | 0.00332 | 0.00219 | 0.362 | 122.778 | 0.037 | 0.037
Hill ^d,e^ | 0.00251 | 0.00095 | 0.581 | 136.393 | −0.480 | 2.275
Polynomial Degree 5^d^ | | | 0.00149 | 136.393 | −0.480 | 2.275
Polynomial Degree 4^d^ | | | 0.00149 | 136.393 | −0.480 | 2.275
Polynomial Degree 3^d^ | | | 0.00149 | 136.393 | −0.480 | 2.275
Polynomial Degree 2^d^ | | | 0.00149 | 136.393 | −0.480 | 2.275
Power^d^ | | | 0.00149 | 136.393 | −0.480 | 2.275
Linear | | | 0.00149 | −58.509 | −0.879 | 0.566

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model. There was an adequate fit to the variance when assuming constant variance. Of the models providing adequate fit, the BMDLs were sufficiently close (differed by <3-fold); therefore, the model with the lowest AIC was selected (Hill)

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control)

Figure A-4 Fit of Hill Model (with Nonconstant Variance) for Serum Total T4 Levels in Female Rats Administered 2,3,4,7,8-Pentachlorodibenzofuran

Table A-16 Results from BMD Analysis of Hepatocellular Hypertrophy Incidence in Female Rats Administered 2,3,4,7,8-Pentachlorodibenzofuran 5 Days/Week for 31 Weeks (NTP 2006)

Model | BMD_1SD_^a^ (μg/kg) | BMDL_1SD_^a^ (μg/kg) | p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (μg/kg) | BMDL_1SD_^a^ (μg/kg) | p-value^b^ | AIC | Dose below BMD | Dose above BMD
Dichotomous Hill | 0.00703 | 0.00203 | 0.862 | 60.494 | 0.2301 | −0.0007
Gamma^d^ | 0.00756 | 0.00535 | 0.325 | 59.695 | 0.2296 | −0.0004
Log-Logistic^e^ | 0.00522 | 0.00240 | 0.936 | 56.977 | −0.1473 | −0.0004
Multistage Degree 5^f^ | 0.00756 | 0.00535 | 0.459 | 57.695 | 0.2296 | −0.0004
Multistage Degree 4^f^ | 0.00756 | 0.00535 | 0.459 | 57.695 | 0.2296 | −0.0004
Multistage Degree 3^f^ | 0.00756 | 0.00535 | 0.459 | 57.695 | 0.2296 | −0.0004
Multistage Degree 2^f^ | 0.00756 | 0.00535 | 0.459 | 57.695 | 0.2296 | −0.0004
Multistage Degree 1^f^ | 0.00756 | 0.00535 | 0.325 | 59.695 | 0.2296 | −0.0004
Weibull^f^ | 0.00756 | 0.00535 | 0.325 | 59.695 | 0.2296 | −0.0016
Logistic | | | 0.041 | 67.242 | 0.2337 | −1.5569
Log-Probit ^ g ^ | 0.00541 | 0.00105 | 0.926 | 57.060 | −0.1258 | −0.0004
Probit | | | 0.042 | 67.658 | 0.2379 | −1.5698

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals for dose group near the BMD and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. Most models provided adequate fit to the data. BMDLs for models providing adequate fit were not sufficiently close (differed by >3-fold). Therefore, the model with lowest BMDL was selected (Log-Probit model).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with 10% extra risk)

Figure A-5 Fit of LogProbit Model for Hepatocellular Hypertrophy Incidence in Female Rats Administered 2,3,4,7,8-Pentachlorodibenzofuran

Intermittent Exposure: The BMDL_1SD_ of 0.00095 μg/kg was adjusted for intermittent exposure.

BMDL_ADJ_ = 0 . 00095 μ g / kg × 5 days / 7 days = 0 . 00068 μ g / kg / day .

Uncertainty Factor: The BMDL_ADJ_ is divided by a total uncertainty factor (UF) of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_ADJ_ ÷ UF MRL = 0 . 00068 μ g / kg / day ÷ 100 = 0 . 000007 μ g / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Decreases in serum total T4 levels have been reported in rats following 4 days of exposure to ≥27.5 μg/kg/day (Crofton et al. 2005; Ross et al. 2000), following 14 weeks of exposure to 0.092 μg/kg (NTP 2006), 31 weeks of exposure to ≥0.006 μg/kg (NTP 2006), and 53 weeks of exposure to 0.044 μg/kg (NTP 2006). Increases in serum total T3 levels have also been reported following 31 or 53 weeks of exposure. No alterations in serum TSH levels have been reported (NTP 2006). The lack of change in serum TSH levels is consistent with the findings of other chemicals which induce uridine 5′-diphospho-glucuronosyltransferase such as PCB and 3-methylcholanthrene (Hood and Klaassen 2000; Hood et al. 2003; Richardson and Klaassen 2010). Epidemiological studies on the potential thyroid toxicity of CDFs are inconclusive. However, occupational exposure studies involving CDDs (ATSDR 1998, 2012) and PCBs (ATSDR 2000) have found alterations in thyroid hormone levels.

Agency Contacts (Chemical Managers): Hana R. Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2,3,4,7,8-Pentachlorodibenzofuran
CAS Numbers: | 57117–31-4
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.000004 μg/kg/day (4xl0^−6^ pg/kg/day)
Critical Effect: | Hepatocellular hypertrophy and cystic degeneration in adrenal cortex
Reference: | NTP 2006
Point of Departure: | LOAEL of 0.006 μg/kg/day (LOAEL_ADJ_ of 0.0043 μg/kg/day)
Uncertainty Factor: | 1,000
LSE Graph Key: | 45
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.000004 μg/kg/day (4×10^−6^ μg/kg/day) was derived for 2,3,4,7,8-pentaCDF based on increased incidences of hepatocellular hypertrophy and cystic degeneration in adrenal cortex of female rats administered via gavage 0.006 μg/kg 2,3,4,7,8-pentaCDF 5 days/week for 2 years (NTP 2006). The MRL is based on a LOAEL of 0.006 μg/kg adjusted for continuous duration to a LOAEL_ADJ_ of 0.0043 μg/kg/day and a total uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: One study (NTP 2006) evaluated the chronic oral toxicity of 2,3,4,7,8-pentaCDF; the results of this study are summarized in Table A-17. The hepatocellular hypertrophy and cystic degeneration in the adrenal gland were selected as the co-critical effects because these endpoints had the lowest LOAEL values (0.006 μg/kg).

Table A-17 Summary of Health Effects in Female Rats Administered 2,3,4,7,8-Pentachlorodibenzofuran 5 Days/week for 2 Years

| NOAEL (μg/kg) | LOAEL (μg/kg) | Effect
Hepatic | | 0.006 | Minimal hepatocellular hypertrophy
Hepatic | | 0.02 | Diffuse fatty changes in liver
Hepatic | | 0.2 | Minimal to mild necrosis in liver; Bile duct hyperplasia, bile duct fibrosis, and cholangiofibrosis
Endocrine | | 0.006 | Cystic degeneration in adrenal cortex
Endocrine | | 0.02 | Follicular cell hypertrophy in thyroid gland
Endocrine | | 0.044 | Decreased serum total T4 levels (22%) and serum free T4 levels (17%) (measured at 53 weeks)
Endocrine | | 0.092 | Increased serum total T3 levels (23%) (measured at 53 weeks)
Endocrine | | 0.2 | Arterial chronic active inflammation in pancreas
Renal | 0.02 | 0.044 | Nephropathy
Reproductive | 0.02 | 0.044 | Squamous metaplasia in uterus
Other noncancer | 0.02 | 0.044 | Gingival squamous hyperplasia
Cardiovascular | 0.092 | 0.2 | Cardiomyopathy
Respiratory | 0.044 | 0.092 | Bronchiolar metaplasia of alveolar epithelium
Gastrointestinal | 0.092 | 0.2 | Squamous hyperplasia of the forestomach
Immunological | 0.092 | 0.2 | Increased severity of thymic atrophy

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; T4 = thyroxine

Source: NTP 2006

Selection of the Principal Study: The NTP (2006) study was selected as the principal study.

Summary of the Principal Study:

NTP. 2006. Toxicology and carcinogenesis studies of 2,3,4,7,8-pentachlorodibenzofuran (PeCDF) (CAS No. 57117–31-4) in female Harlan Sprague-Dawley rats (gavage studies). NTP TR 525.

Groups of 81 female Harlan Sprague-Dawley rats were administered via gavage 0, 6, 20, 44, 92, or 200 ng/kg (0, 0.006, 0.02, 0.044, 0.092, and 0.2 μg/kg) 2,3,4,7,8-pentaCDF in a corn oil:acetone vehicle 5 days/week for 105 weeks. Interim examinations were conducted in groups of 10 rats exposed for 53 weeks. Another group of 50 rats were exposed to 0.200 μg/kg for 30 weeks and held for the remainder of the 2-year study. The following parameters were used to assess toxicity in the core study groups and stop-exposure group: clinical observations, body weight, and complete histopathological examination. In rats exposed for 53 weeks, the following parameters were used to assess toxicity: clinical observations, body weight, organ weights (kidney, liver, lung, ovary, spleen, thymus, and thyroid), thyroid hormone levels (TSH, T3, T4), cell proliferation measured in liver and duodenum samples, cytochrome P450 activities in liver and lung samples, and histopathological examination of the adrenal gland, liver, lung, mammary gland, ovary, pancreas, pituitary gland, spleen, stomach, thymus, thyroid gland, uterus, and vagina in the 0 and 0.2 μg/kg groups; liver; thymus, and uterus in all groups.

No significant alterations in survival were observed. Some decreases in body weight were observed; however, throughout the study, body weights were within 10% of controls. After 53 weeks of exposure to 0.044, 0.092, and 0.2 μg/kg, decreased serum total T4 levels (22, 35, and 34%, respectively) and decreased free T4 levels (17, 22, and 9%, respectively) were observed; increased total T3 levels were observed at 0.092 and 0.2 μg/kg (16 and 19%). After 53 weeks of exposure, an increase in the incidence of hepatocellular hypertrophy was observed at 0.2 μg/kg and an increase in liver pigmentation was observed at ≥0.044 μg/kg.

Nonneoplastic lesions were also observed in the lungs, heart, forestomach, liver, kidneys, pancreas, thyroid, adrenal gland, thymus, uterus, and gingiva of rats exposed for 2 years:

- Lungs: Bronchiolar metaplasia of alveolar epithelium was observed in rats exposed to ≥0.092 μg/kg for 2 years.
- Heart: Increased incidences of cardiomyopathy at 0.2 μg/kg.
- Forestomach: Increased incidences of squamous hyperplasia in the forestomach at 0.2 μg/kg.
- Liver: Minimal hepatocellular hypertrophy at ≥0.006 μg/kg; minimal diffuse fatty changes, pigmentation, and multinucleated hepatocytes at ≥0.02 μg/kg; minimal to mild toxic hepatopathy (includes all nonneoplastic liver alterations under one term) at ≥0.044 μg/kg; and mild necrosis, mild bile duct hyperplasia, minimal bile duct fibrosis, and mild cholangiofibrosis at 0.2 μg/kg. Most of the effects observed in the 0.2 μg/kg group were also observed in the 0.2 μg/kg stop exposure group, although the incidences were lower than in the rats exposed to 0.2 μg/kg for 2 years.
- Kidney: Increased incidence of nephropathy in the 0.044 and 0.2 μg/kg groups.
- Pancreas: Minimal acinar cytoplasmic vacuolization and moderate arterial chronic active inflammation in the 0.2 μg/kg groups.
- Thyroid: Follicular cell hypertrophy in the thyroid of rats exposed to ≥0.02 μg/kg.
- Adrenal gland: Mild cystic degeneration in the adrenal cortex of rats exposed to ≥0.006 μg/kg; also observed in the 0.2 μg/kg stop exposure group.
- Thymus: Dose-related increases in the severity of the thymic atrophy; the severity was mild in the control group compared to moderate to marked in the 0.2 μg/kg group. No significant increases in the incidence of thymus atrophy.
- Uterus: Cystic endometrial hyperplasia at ≥0.092 μg/kg and squamous metaplasia at ≥0.044 μg/kg; increased incidences of chronic active inflammation and squamous metaplasia were also observed in the 0.2 μg/kg stop exposure group.
- Gingiva: A nonsignificant increase in the incidence of gingival squamous hyperplasia was observed at 0.044 μg/kg; the investigators considered this to be treatment related.

A dose-related increase in the incidence of hepatocellular adenoma was observed; however, the incidence was not significantly increased at any dose level. A nonsignificant increase in the incidence of cholangiocarcinoma was observed at 0.2 μg/kg; the investigators noted that the observed cholangiocarcinoma differed morphologically from spontaneous cholangiocarcinoma and was considered treatment related. A nonsignificant increase in the incidence of gingival squamous cell carcinomas was observed in the 0.2 μg/kg group; the investigators considered these lesions to be treatment related. Nonsignificant increases in neoplastic lesions were also observed in the lungs, pancreas, and uterus; the incidence of some of these lesions was higher than historical controls and the investigators concluded that these lesions may be treatment related. The lesions included cystic keratinizing epithelioma in the lung of one rat in the 0.2 μg/kg group; acinus adenoma or carcinoma in the pancreas in the 0.092 μg/kg group and in the 0.2 μg/kg stop exposure group; and uterine carcinoma in the 0.092 and 0.2 μg/kg groups.

Selection of the Point of Departure for the MRL: The LOAEL of 0.006 μg/kg was selected as the POD.

BMD modeling was conducted to identify a potential POD using the incidence data for hepatocellular hypertrophy and cystic degeneration in the adrenal cortex, which are summarized in Table A-18. These two endpoints were selected for BMD analysis because they identified the lowest LOAEL values. The data were fit to all available dichotomous models in EPA’s BMDS (version 3.1.2) using the extra risk option. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. A BMR of 10% was used. None of the available BMD models provided adequate fit for the liver or adrenal data. Thus, a NOAEL/LOAEL approach was used to select the POD.

Table A-18 Incidence of Nonneoplastic Lesions in the Liver and Adrenal Gland of Female Rats Administered 2,3,4,7,8-Pentachlorodibenzofuran 5 Days/Week for 2 Years

Dose level (μg/kg) | Hepatocellular hypertrophy | Cystic degeneration in adrenal cortex
0 | 2/53 | 4/53
0.006 | 13/53^a^ | 17/53^a^
0.02 | 17/53^a^ | 14/53^a^
0.044 | 17/52^a^ | 18/52^a^
0.092 | 24/53^a^ | 12/53^a^
0.2 | 34/53^a^ | 14/53^a^

a Significantly different from vehicle control, p<0.01.

Source: NTP 2006

Intermittent Exposure: The LOAEL of 0.006 μg/kg/day was adjusted for intermittent exposure.

LOAEL_ADJ_ = 0 . 006 μ g / kg / day × 5 days / 7 days = 0 . 0043 μ g / kg / day .

Uncertainty Factor: The LOAEL_ADJ_ is divided by a total uncertainty factor (UF) of 1,000:

- 10 for the use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = LOAEL_ADJ_ ÷ UF MRL = 0 . 0043 μ g / kg / day ÷ 1000 = 0 . 000004 μ g / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Although only one study evaluated the chronic toxicity of 2,3,4,7,8-pentaCDF; 14- and 31-week studies conducted by NTP (2006) provide support for the selection of the critical effects and POD.

Agency Contacts (Chemical Managers): Hana R. Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,7,8-Hexachlorodibenzofuran
CAS Numbers: | 70648–26-9
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute, Intermediate, Chronic

MRL Summary: There are insufficient data for the derivation of acute-, intermediate-, or chronic-duration inhalation MRLs for 1,2,3,4,7,8-hexaCDF due to the lack of studies evaluating toxicity following inhalation exposure.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,4,7,8-hexaCDF following inhalation exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,7,8-Hexachlorodibenzofuran
CAS Numbers: | 70648–26-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for the derivation of an acute-duration oral MRL for 1,2,3,4,7,8-hexaCDF due to the limited scope of the available studies evaluating toxicity following acute oral exposure.

Rationale for Not Deriving an MRL: Two developmental toxicity studies have evaluated the toxicity of 1,2,3,4,7,8-hexaCDF following acute-duration oral exposure. Both studies identified a LOAEL of 100 μg/kg/day (lowest dose tested) for hydronephrosis in the offspring of mice administered 1,2,3,4,7,8-hexaCDF on GDs 10–13 (Birnbaum et al. 1987a, 1987b); an increased incidence of cleft palate was also observed at ≥300 μg/kg/day. Studies with other 2,3,7,8-substituted CDFs confirm that hydronephrosis is a sensitive endpoint of CDF toxicity. However, there are other sensitive targets, such as the liver and thymus, which were not fully examined in the Birnbaum et al. (1987a, 1987b) studies; both studies reported increases in maternal relative liver weight at ≥100 μg/kg/day.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,7,8-Hexachlorodibenzofuran
CAS Numbers: | 70648–26-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for the derivation of an intermediate-duration oral MRL for 1,2,3,4,7,8-hexaCDF due to the lack of studies evaluating intermediate toxicity.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,4,7,8-hexaCDF following intermediate-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,7,8-Hexachlorodibenzofuran
CAS Numbers: | 70648–26-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for the derivation of a chronic-duration oral MRL for 1,2,3,4,7,8-hexaCDF due to the lack of studies evaluating chronic toxicity.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,4,7,8-hexaCDF following chronic-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,6,7,8-Hexachlorodibenzofuran
CAS Numbers: | 57117–44-9
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute, Intermediate, Chronic

MRL Summary: There are insufficient data for the derivation of acute-, intermediate-, or chronic-duration inhalation MRLs for 1,2,3,6,7,8-hexaCDF due to the lack of studies evaluating toxicity following inhalation exposure.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,6,7,8-hexaCDF following inhalation exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,6,7,8-Hexachlorodibenzofuran
CAS Numbers: | 57117–44-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for the derivation of an acute-duration oral MRL for 1,2,3,6,7,8-hexaCDF due to the lack of studies evaluating acute toxicity.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,6,7,8-hexaCDF following acute-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,6,7,8-Hexachlorodibenzofuran
CAS Numbers: | 57117–44-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.005 μg/kg/day
Critical Effect: | Increased liver weight and decreased thymus weight
Reference: | Pluess et al. 1988a
Point of Departure: | BMDL_1SD_ of 0.48 μg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 41
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.005 μg/kg/day was derived for 1,2,3,6,7,8-hexaCDF based on increases in relative liver weight and decreases in absolute thymus weight in rats exposed to 2 μg/kg/day 1,2,3,6,7,8-hexaCDF in the diet for 13 weeks (Pluess et al. 1988a). The MRL is based on a BMDL_1SD_ of 0.48 μg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: One study evaluated the toxicity of 1,2,3,6,7,8-hexaCDF following intermediate-duration oral exposure (Pluess et al. 1988a). The results of this study are summarized in Table A-19. The study identified several targets of toxicity including the liver, thymus, and body weight. The increases in liver weight, histological alterations in the liver, and decreases in thymus weight were selected as co-critical effects.

Table A-19 Summary of Health Effects Following Intermediate-Duration Oral Exposure to 1,2,3,6,7,8-Hexachlorodibenzofuran

Species, duration | NOAEL (μg/kg/day) | LOAEL (μg/kg/day) | Effect | Reference
Rat 13 weeks | 0.2 | 2 | - Increased relative liver weight (15% in males), vacuolization with lipid accumulation, single cell necrosis; - Decreased absolute thymus weight (40–42%); - Decreased body weight gain (14–20%); - Thymic atrophy^a^ | Pluess et al. 1988a
Rat 13 weeks | 0.2 | 20 | | Pluess et al. 1988a

a Considered a serious health effect.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: The Pluess et al. (1988a) (data also reported in Poiger et al. 1989) study is the only study evaluating intermediate-duration toxicity of 1,2,3,6,7,8-hexaCDF and was selected as the principal study.

Summary of the Principal Study:

Pluess N, Poiger H, Hohbach C, 1988a. Subchronic toxicity of some chlorinated dibenzofurans (PCDFs) and a mixture of PCDFs and chlorinated dibenzodioxins (PCDDs) in rats. Chemosphere. 17:973–984.

Groups of six male and six female Iva:SIV 50(SD) rats were exposed to 0, 2, 20, or 200 μg/kg 1,2,3,6,7,8-hexaCDF in the diet for 13 weeks. Doses were calculated using a reference food intake of 0.016 kg/day and reference body weight of 0.152 kg (EPA 1989b); estimated doses were 0, 0.2, 2, and 20 μg/kg/day in the 0, 2, 20, and 200 μg/kg groups, respectively. The following parameters were used to evaluate toxicity: weekly body weight and food consumption measurements, hematological parameters (red blood cells, total and differential white blood cells, reticulocyte and thrombocyte counts, hemoglobin levels, and packed cell volume) and serum clinical chemistry indices (bilirubin, triglycerides, urea, cholesterol, alkaline phosphatase, ALT), organ weights (liver, thymus, spleen, kidneys, heart, and testes), and histopathology (lungs, liver, thymus, spleen, kidneys, heart, thyroid/parathyroids, adrenals, mesenteric and submandibular lymph nodes, uterus, ovaries, and testes).

No deaths occurred in either sex and there were no treatment-related effects on body weight or food consumption. Significant decreases in hemoglobin (9%) in both sexes and thrombocyte count (40%) in females were observed at 20 μg/kg/day. No significant effects on white blood cell count, red blood cell count, or packed cell volume were observed. Significant increases in serum alkaline phosphatase (18%) were observed in females at 2 μg/kg/day and increased serum cholesterol (26 and 33%) and decreased triglycerides (35 and 48%) were observed in both sexes at 20 μg/kg/day. No significant alterations in serum bilirubin, ALT, or urea were observed. Significant increases in relative liver weight were observed at 2 μg/kg/day in males (15%) and at 20 μg/kg/day in females (32%). Histological alterations were observed in the liver at 2 μg/kg/day and were more pronounced at 20 μg/kg/day; lesions included vacuolization with increased lipid content, single cell necrosis, and slight Kupffer cell hyperplasia. Significant decreases in relative thymus weight (40–42%) and histologic evidence of possible initial thymic atrophy were observed at 2 μg/kg/day. Marked thymic atrophy was observed at 20 μg/kg/day. The investigators did not provide incidence data for the liver or thymus histological alterations. No histological alterations were observed in the heart, kidneys, adrenal glands, spleen, lymph nodes, testes, uterus, or ovaries.

Selection of the Point of Departure for the MRL: A BMDL_1SD_ of 0.48 μg/kg/day for increases in relative liver weight and decreases in absolute thymus weight was selected as the POD.

BMD modeling was conducted to identify a potential POD using the data for increases in relative liver weight in males and decreases in absolute thymus weight in males and females, which are summarized in Table A-20. Relative liver weight data for females was not modeled because it was only significantly increased at 20 μg/kg/day. The investigators did not provide incidence data for the liver or thymus histological alterations, which precluded BMD analyses of these data. The organ weight data were fit to all available continuous models in EPA’s BMDS (version 3.1.2) using the extra risk option. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. A BMR of 1 standard deviation from the control mean was selected in the absence of a biologically based BMR.

Table A-20 Relative Liver and Absolute Thymus Weights in Male and Female Rats Exposed to 1,2,3,6,7,8-Hexachlorodibenzofuran in the Diet for 13 Weeks

Dose level (μg/kg/day) | Relative liver weight (mean±SD) (g) | | Absolute thymus weight (mean±SD) (g)
Dose level (μg/kg/day) | Males | Females | Males | Females
0 | 3.35±0.26 | 3.37±0.23 | 0.48±0.02 | 0.48±0.09
0.2 | 3.27±0.26 | 3.56±0.26 | 0.45±0.08 | 0.41±0.08
2 | 3.85±0.21^a^ | 3.57±0.07 | 0.28±0.07^a^ | 0.29±0.04^a^
20 | 4.83±0.28^a^ | 4.45±0.27^a^ | 0.12±0.02^a^ | 0.10±0.02^a^

a Significantly different from control, p<0.05.

SD = standard deviation

Source: Pluess et al. 1988a

Only one model (with constant variance) provided adequate fit to the increases in relative liver weight in male rats. The Exponential 4-degree model estimated a BMD_1SD_ and BMDL_1SD_ of 0.75 and 0.48 μg/kg/day, respectively. The results of the BMD modeling are summarized in Table A-21 and the Exponential 4 model is illustrated in Figure A-6. None of the BMD models (with constant variance or nonconstant variance) provided adequate fit to the absolute thymus weights in male rats. Two models provided adequate fit for the absolute thymus weight in female rats, summarized in Table A-22. Both models identified a BMD_1SD_ of 0.73 μg/kg/day and BMDL_1SD_ of 0.48 μg/kg/day. The Exponential 5-degree model (with nonconstant variance) is illustrated in Figure A-7.

Table A-21 Results from BMD Analysis (Constant Variance) of Relative Liver Weight in Male Rats Exposed to 1,2,3,6,7,8-Hexachlorodibenzofuran in the Diet for 13 Weeks (Pluess et al. 1988a)

Model | BMD_1SD_^a^ (μg/kg/day) | BMDL_1SD_^a^ (μg/kg/day) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (μg/kg/day) | BMDL_1SD_^a^ (μg/kg/day) | Test 4 p-value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential 2^d^ | | | 0.004 | 14.97 | 2.44 | −0.754
Exponential 3^d^ | | | 0.004 | 14.97 | 2.44 | −0.754
Exponential 4 ^d,e^ | 0.75 | 0.48 | 0.273 | 7.12 | −0.82 | 0.702
Exponential 5^d^ | | | NA | 8.27 | 0.00 | 0.420
Hill^c^ | | | NA | 8.27 | 0.00 | 0.420
Polynomial Degree 3^d^ | | | 0.006 | 14.17 | 2.38 | −0.674
Polynomial Degree 2^d^ | | | 0.006 | 14.17 | 2.38 | −0.674
Power^d^ | | | 0.006 | 14.17 | 2.38 | −0.674
Linear | | | 0.006 | 14.17 | 2.38 | −0.674

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model. There was an adequate fit to the variance when assuming constant variance. Only one model (Exponential 4) provided adequate fit.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control); NA = not applicable, goodness-of-fit test could not be performed

Figure A-6 Fit of Exponential 4 Model (with Constant Variance) to Relative Liver Weight in Male Rats Exposed to 1,2,3,6,7,8-Hexachlorodibenzofuran

Table A-22 Results from BMD Analysis (Nonconstant Variance) of Absolute Thymus Weight in Female Rats Exposed to 1,2,3,6,7,8-Hexachlorodibenzofuran in the Diet for 13 Weeks (Pluess et al. 1988a)

Model | BMD_1SD_^a^ (μg/kg/day) | BMDL_1SD_^a^ (μg/kg/day) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (μg/kg/day) | BMDL_1SD_^a^ (μg/kg/day) | Test 4 p-value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential 2^d^ | | | 0.003 | −60.23 | −2.11 | 1.828
Exponential 3^d^ | | | 0.003 | −60.23 | −2.11 | 1.828
Exponential 4^d^ | 0.73 | 0.48 | 0.265 | −68.91 | −0.86 | 0.656
Exponential 5 ^d,e^ | 0.73 | 0.48 | 0.265 | −68.91 | −0.87 | 0.653
Hill^c^ | | | NA | −65.55 | 0.21 | 1.005
Polynomial Degree 3^d^ | | | 0.001 | −57.26 | −2.28 | 1.972
Polynomial Degree 2^d^ | | | 0.001 | −57.26 | −2.28 | 1.972
Power^d^ | | | 0.001 | −57.26 | −2.28 | 1.972
Linear | | | 0.001 | −57.26 | −2.28 | 1.972

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model. There was an adequate fit to the variance when assuming constant variance. Of the models providing adequate fit, the BMDLs were sufficiently close (differed by <3-fold); therefore, the model with the lowest AIC was selected (Exponential 5).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control); NA = not applicable, goodness-of-fit test could not be performed

Figure A-7 Fit of Exponential 5 Model (with Nonconstant Variance) to Absolute Thymus Weight in Female Rats Exposed to 1,2,3,6,7,8-Hexachlorodibenzofuran

Table A-23 summarizes the potential candidate PODs for 1,2,3,6,7,8-hexaCDF. The lowest candidate POD was 0.48 μg/kg/day for increases in relative liver weight in males and decreases in absolute thymus weight in females; the BMDL_1SD_ for these endpoints was selected as the POD.

Table A-23 Candidate Points of Departure 1,2,3,6,7,8-Hexachlorodibenzofuran Intermediate-Duration Oral MRL

Endpoint | NOAEL (μg/kg/day) | BMD_1SD_ (μg/kg/day) | BMDL_1SD_ (μg/kg/day)
Increases in relative liver weight in males | | 0.75 | 0.48
Histological alterations in the liver (vacuolization with increased lipid content, single cell necrosis and slight Kupffer cell hyperplasia) | 2
Decrease in absolute thymus weight in males | 2
Decrease in absolute thymus weight in females | | 0.73 | 0.48

BMD = benchmark dose; BMDL = 95% lower confidence limit on the BMD; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level; SD = standard deviation

Uncertainty Factor: The BMDL_1SD_ is divided by a total uncertainty factor (UF) of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_1 SD_ ÷ UF 0 . 48 μ g / kg / day ÷ ( 10 × 10 ) = 0 . 0048 μ g / kg / day ≈ 0 . 005 μ g / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Although there are limited data on the toxicity of 12,3,6,7,8-hexaCDF, identification of the liver and thymus as sensitive targets is supported by other studies of 2,3,7,8-substituted CDF congeners. The liver and/or thymus were the most sensitive targets following intermediate-duration exposure to 2,3,7,8-tetraCDF (McNulty et al. 1981), 1,2,3,7,8-penta CDF (Pluess et al. 1988a), 2,3,4,7,8-pentaCDF (NTP 2006), and following chronic exposure to 2,3,4,7,8-pentaCDF (NTP 2006).

Agency Contacts (Chemical Managers): Hana R. Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,6,7,8-Hexachlorodibenzofuran
CAS Numbers: | 57117–44-9
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for the derivation of a chronic-duration oral MRL for 1,2,3,6,7,8-hexaCDF due to the lack of studies evaluating chronic toxicity.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,6,7,8-hexaCDF following chronic-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,6,7,8-Heptachlorodibenzofuran
CAS Numbers: | 67562–39-4
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute, Intermediate, Chronic

MRL Summary: There are insufficient data for the derivation of acute-, intermediate-, or chronic-duration inhalation MRLs for 1,2,3,4,6,7,8-heptaCDF due to the lack of studies evaluating toxicity following inhalation exposure.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,4,6,7,8-heptaCDF following inhalation exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,6,7,8-Heptachlorodibenzofuran
CAS Numbers: | 67562–39-4
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for the derivation of an acute-duration oral MRL for 1,2,3,4,6,7,8-heptaCDF because the only available acute-duration oral study examined a limited number of endpoints.

Rationale for Not Deriving an MRL: One study evaluated the oral toxicity of 1,2,3,4,6,7,8-heptaCDF in laboratory animals. In this study, an ED_50_ of 208 μg/kg was identified for decreased antibody response to SRBC in mice administered a single gavage dose of 1,2,3,4,6,7,8-heptaCDF (Kerkvliet et al. 1985). Although studies on other 2,3,7,8-substituted CDFs identify the immune system as a target of toxicity, there are inadequate data to evaluate whether this would be the most sensitive effect for 1,2,3,4,6,7,8-heptaCDF. Thus, the database was not considered adequate to support derivation of an acute-duration oral MRL.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,6,7,8-Heptachlorodibenzofuran
CAS Numbers: | 67562–39-4
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for the derivation of an intermediate-duration oral MRL for 1,2,3,4,6,7,8-heptaCDF due to the lack of studies evaluating intermediate toxicity.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,4,6,7,8-heptaCDF following intermediate-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,6,7,8-Heptachlorodibenzofuran
CAS Numbers: | 67562–39-4
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for the derivation of a chronic-duration oral MRL for 1,2,3,4,6,7,8-heptaCDF due to the lack of studies evaluating chronic toxicity.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of 1,2,3,4,6,7,8-heptaCDF following chronic-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,6,7,8,9-Octachlorodibenzofuran
CAS Numbers: | 39001–02-0
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute, Intermediate, Chronic

MRL Summary: There are insufficient data for the derivation of acute-, intermediate-, or chronic-duration inhalation MRLs for octaCDF due to the lack of studies evaluating toxicity following inhalation exposure.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of octaCDF following inhalation exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,6,7,8,9-Octachlorodibenzofuran
CAS Numbers: | 39001–02-0
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for the derivation of an acute-duration oral MRL for octaCDF because the only available study did not report adverse effects at the highest dose tested.

Rationale for Not Deriving an MRL: One animal study evaluated the toxicity of octaCDF following acute-duration oral exposure. In this study, no alterations in serum total T4 levels were observed in rats administered doses as high as 300 μg/kg/day for 4 days (Crofton et al. 2005).

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Numbers: | 1,2,3,4,6,7,8,9-Octachlorodibenzofuran
CAS Numbers: | 39001–02-0
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for the derivation of an intermediate-duration oral MRL for octaCDF due to the lack of studies evaluating chronic toxicity.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of octaCDF following intermediate-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2,3,4,6,7,8,9-Octachlorodibenzofuran
CAS Numbers: | 39001–02-0
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for the derivation of a chronic-duration oral MRL for octaCDF due to the lack of studies evaluating chronic toxicity.

Rationale for Not Deriving an MRL: No human or animal studies have evaluated the toxicity of octaCDF following chronic-duration oral exposure.

Agency Contacts (Chemical Managers): Hana Pohl