# CHAPTER 8 REFERENCES

Adrian L, Görisch H. 2002. Microbial transformation of chlorinated benzenes under anaerobic conditions. Res Microbiol 153(3):131–137. 10.1016/s0923-2508(02)01298-6.12002562
Anderson TA, Beauchamp JJ, Walton BT. 1991. Fate of volatile and semivolatile organic chemicals in soils: Abiotic versus biotic losses. J Environ Qual 20(2):420–424. 10.2134/jeq1991.00472425002000020014x.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634. https://www.govinfo.gov/app/details/FR-1989-09-11. July 21, 2020.
ATSDR. 2019. Chlorobenzene. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Azouz WM, Parke DV, Williams RT. 1952. Studies in detoxication, 42. Fluorobenzene: Spectrophotometric determination of the elimination of unchanged halogenobenzenes by rabbits; a comparison of the oxidation in vivo of fluorobenzene and of benzene. Biochem J 50(5):702–706. 10.1042/bj0500702.14934677
Babany G, Bernuau J, Cailleux A, 1991. Severe monochlorobenzene-induced liver cell necrosis. Gastroenterology 101(6):1734–1736. 10.1016/0016-5085(91)90416-i.1955139
Barkley J, Bunch J, Bursey JT, 1980. Gas chromatography mass spectrometry computer analysis of volatile halogenated hydrocarbons in man and his environment - a multimedia environmental study. Biol Mass Spectrom 7(4):139–147. 10.1002/bms.1200070402.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Bestetti G, Galli E, Leoni B, 1992. Regioselective hydroxylation of chlorobenzene and chlorophenols by a Pseudomonas putida. Appl Microbiol Biotechnol 37(2):260–263. 10.1007/bf00178181.
Bioassay Systems Corp. 1982. Nine reports regarding the effects of various chlorinated benzenes with cover letter dated 051183. Bioassay Systems Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0511274. 408320545. 47002B3A13. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0511274.xhtml. May 28, 2020.
Braeckevelt M, Rokadia H, Imfeld G, 2007a. Assessment of in situ biodegradation of chlorobenzene in contaminated groundwater treated in a constructed wetland. Environ Pollut 148(2):428–437. 10.1016/j.envpol.2006.12.008.17291643
Braeckevelt M, Rokadia H, Mirschel G, 2007b. Biodegradation of chlorobenzene in a constructed wetland treating contaminated groundwater. Water Sci Technol 56(3):57–62. 10.2166/wst.2007.520.
Brodie BB, Reid WD, Cho AK, 1971. Possible mechanism of liver necrosis caused by aromatic organic compounds. Proc Natl Acad Sci 68(1):160–164. 10.1073/pnas.68.1.160.4395686
Brunsbach FR, Reineke W. 1994. Degradation of chlorobenzenes in soil slurry by a specialized organism. Appl Microbiol Biotechnol 42(2–3):415–420. 10.1007/bf00902751.7765781
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: a review of past ATSDR public health evaluations. J Environ Health 75(9):36–41.
CDC. 2018. Fourth national report on human exposure to environmental chemicals. Updated tables, March 2018. Centers for Disease Control and Prevention. http://www.cdc.gov/exposurereport/. April 06, 2018.
CDC. 2019. Fourth national report on human exposure to environmental chemicals. Updated tables, January 2019. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/pdf/FourthReport_UpdatedTables_Volume1_Jan2019-508.pdf. May 28, 2020.
Chadwick RW, Scotti TM, Copeland MF, 1984. Antagonism of chlorobenzene-induced hepatotoxicity by lindane. Pestic Biochem Physiol 21(2):148–161. 10.1016/0048-3575(84)90050-6.
Clark CS, Meyer CR, Gartside PS, 1982. An environmental health survey of drinking water contamination by leachate from a pesticide waste dump in Hardeman County, Tennessee. Arch Environ Health 37(1):9–18. 10.1080/00039896.1982.10667526.7059235
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
CMA. 1986. Six copies of the final reported titled “An inhalation two-generation reproduction study in rats with monochlorobenzene, with cover letter dated 110786. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0511472. 408720866. 47002J2A2. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0511472.xhtml. May 28, 2020.
Cohen MA, Ryan PB, Yanagisawa Y, 1989. Indoor/outdoor measurements of volatile organic compounds in the Kanawha Valley of West Virginia. JAPCA 39(8):1086–1093. 10.1080/08940630.1989.10466593.2795113
Dilling WL, Bredeweg CJ, Tefertiller NB. 1976. Organic photochemistry. XIII. Simulated atmospheric photodecomposition rates of methylene chloride, 1,1,1-trichloroethane, trichloroethylene, tetrachloroethylene, and other compounds. Environ Sci Technol 10(4):351–356. 10.1021/es60115a006.
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
E.I. DuPont. 1977. Mutagenic activity of monochlorobenzene in the Salmonella/microsome assay with cover letter dated 5/10/94 (Sanitized). E.I. DuPont de Nemours & Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557146. 86940000736S. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557146.xhtml. May 28, 2020.
EPA. 1976. Frequency of organic compounds identified in water. Athens, GA: U.S. Environmental Protection Agency. PB265470. EPA600476062. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100PLS3.txt. May 28, 2020.
EPA. 1978. Measurement of carcinogenic vapors in ambient atmospheres. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600778062. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100M0DV.txt. May 28, 2020.
EPA. 1979. Identification of organic compounds in industrial effluent discharges. Athens, GA: U.S. Environmental Protection Agency. EPA600479016. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101LV4K.txt. May 28, 2020.
EPA. 1980a. Ambient water quality criteria for chlorinated benzenes. Washington, DC: U.S. Environmental Protection Agency. PB81117392. EPA440580028. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000M1QS.txt. May 28, 2020.
EPA. 1980b. Support document for proposed health effects test rule: Chlorinated benzenes. Washington, DC: U.S. Environmental Protection Agency. PB80220296. EPA5601180014. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000ZD3E.txt. May 28, 2020.
EPA. 1981. Atmospheric measurements of selected hazardous organic chemicals. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB81200628. EPA600381032. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100KKTP.txt. May 28, 2020.
EPA. 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. EPA440481014. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100O12M.txt. May 28, 2020.
EPA. 1983. Volatile organic chemicals in the atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600383027a. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100B68L.txt. May 28, 2020.
EPA. 1985. Health assessment document for chlorinated benzenes: Final Report. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600884015F. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=300054NP.txt. May 27, 2020.
EPA. 1986. Broad scan analysis of the FY82 National Human Adipose Tissue Survey specimens: Volume I - Executive summary. Washington, DC: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000HPAT.txt. May 28, 2020.
EPA. 1988. Land disposal restrictions for first third scheduled wastes. U.S. Environmental Protection Agency. Fed Regist 53(159):31138–31222. https://www.loc.gov/item/fr053159/. May 27, 2020.
EPA. 1989. Land disposal restrictions for second third scheduled wastes. U.S. Environmental Protection Agency. Fed Regist 54(7):1056–1119. https://www.epa.gov/sites/production/files/2016-03/documents/54fr26594.pdf. May 28, 2020.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100EI4V.txt. May 28, 2020.
EPA. 2006. Provisional peer-reviewed toxicity values for chlorobenzene. Washington, DC: U.S. Environmental Protection Agency. EPA690R06010F. https://cfpub.epa.gov/ncea/pprtv/documents/Chlorobenzene.pdf. May 27, 2020.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
EPA. 2011. Background indoor air concentrations of volatile organic compounds in North American residences (1990-2005): A compilation of statistics for assessing vapor intrusion. Washington, DC: U.S. Environmental Protection Agency. EPA530R10001. https://www.epa.gov/sites/production/files/2015-09/documents/oswer-vapor-intrusion-background-report-062411.pdf. August 12, 2020.
EPA. 2018a. Resident vapor intrusion screening levels (VISL) - May 2018. U.S. Environmental Protection Agency. https://www.epa.gov/vaporintrusion/vapor-intrusion-screening-level-calculator. March 8, 2019.
EPA. 2018b. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018c. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018d. About Acute Exposure Guideline Levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
FDA. 2017. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.gpo.gov/fdsys/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
FDA. 2020. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. April 12, 2020.
Feidieker D, Kämpfer P, Dott W. 1995. Field-scale investigations on the biodegradation of chlorinated aromatic compounds and HCH in the subsurface environment. J Contam Hydrol 19(2):145–169. 10.1016/0169-7722(95)00013-l.
Feltens R, Mogel I, Roder-Stolinski C, 2010. Chlorobenzene induces oxidative stress in human lung epithelial cells in vitro. Toxicol Appl Pharmacol 242:100–108. 10.1016/j.taap.2009.09.020.19800902
Fischäder G, Röder-Stolinski C, Wichmann G, 2008. Release of MCP-1 and IL-8 from lung epithelial cells exposed to volatile organic compounds. Toxicol in Vitro 22(2):359–366. 10.1016/j.tiv.2007.09.015.17993253
Fisher J, Mahle D, Bankston L, 1997. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J 58(5):425–431. 10.1080/15428119791012667.9183837
Fleming-Jones ME, Smith RE. 2003. Volatile organic compounds in foods: A five year study. J Agric Food Chem 51(27):8120–8127. 10.1021/jf0303159.14690406
Garrison AW, Hill DW. 1972. Organic pollutants from mill persist in downstream waters. Am Dyest Rep:21–25.
Gillham B, Young L. 1968. Biochemical studies of toxic agents. The isolation of premercapturic acids from the urine of animals dosed with chlorobenzene and bromobenzene. Biochem J 109(1):143–147. 10.1042/bj1090143.5669843
Hallbourg RR, Delfino JJ, Miller WL. 1992. Organic priority pollutants in groundwater and surface water at three landfills in north central Florida. Water Air Soil Pollut 65(3–4):307–322. 10.1007/bf00479894.
Harkov R, Gianti SJ, Bozzelli JW. 1985. Monitoring volatile organic compounds at hazardous and sanitary landfills in New Jersey. J Environ Sci Health A Environ Sci Eng Toxic Hazard A20:491–501. 10.1080/10934528509375237.
Harkov R, Kebbekus B, Bozzelli JW. 1987. Volatile organic compounds at urban sites in New Jersey. In: Lidy D, ed. Toxic air pollutants. Chelsea, MI: Lewis Pub, Inc., 69–88.
Haworth S, Lawlor T, Mortelmans K, 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl 1):1–142. 10.1002/em.2860050703.
Hazen TC. 2009. Cometabolic bioremediation. In: Timmis KN, ed. Handbook of hydrocarbon microbiology: Microbial interactions with hydrocarbons, oils, fats, and related hydrophobic substrates and products. Berlin, Germany: Springer Verlag, 2505–1515.
Hughes CS, Cox W, Kamatari O. 1983. CEH product review: Chlorobenzenes. In: Chemical economics handbook. Menlo Park, CA: SRI International, 633.5030A–5633.5031M.
IARC. 2020. Agents classified by the IARC Monographs, Volumes 1–125. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. April 30, 2020.
IRIS. 2003. Chlorobenzene. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0399_summary.pdf. November 7, 2017.
John JA, Hayes WC, Hanley TR, 1984. Inhalation teratology study on monochlorobenzene in rats and rabbits. Toxicol Appl Pharmacol 76(2):365–373. 10.1016/0041-008x(84)90018-8.6495340
Kaschl A, Vogt C, Uhlig S, 2005. Isotopic fractionation indicates anaerobic monochlorobenzene biodegradation. Environ Toxicol Chem 24(6):1315–1324. 10.1897/04-321r.1.16117106
Kiesel B, Balcke GU, Dietrich J, 2008. Microbial community shifts as a response to efficient degradation of chlorobenzene under hypoxic conditions. Biodegradation 19(3):435–446. 10.1007/s10532-007-9149-z.17882513
Kirschner DA. 2004. Chlorobenzene: April 5, 2004. Chem Market Rep 265(13):31.
Kluwe WM, Dill G, Persing R, 1985. Toxic responses to acute, subchronic, and chronic oral administrations of monochlorobenzene to rodents. J Toxicol Environ Health 15(6):745–767. 10.1080/15287398509530702.4057281
Knecht U, Woitowitz HJ. 2000. Human toxicokinetics of inhaled monochlorobenzene: Latest experimental findings regarding re-evaluation of the biological tolerance value. Int Arch Occup Environ Health 73(8):543–554. 10.1007/s004200000171.11100949
Kochany J, Bolton JR. 1992. Mechanism of photodegradation of aqueous organic pollutants. 2. Measurement of the primary rate constants for reaction of hydroxyl radicals with benzene and some halobenzenes using an EPR spin-trapping method following the photolysis of hydrogen peroxide. Environ Sci Technol 26(2):262–265. 10.1021/es00026a004.
Koelmans AA, Jiménez CS. 1994. Temperature dependency of chlorobenzene bioaccumulation in phytoplankton. Chemosphere 28(12):2041–2048. 10.1016/0045-6535(94)90174-0.
Krewet E, Müller G, Norpoth K. 1989. The excretion of chlorophenylmercapturic acid, chlorophenols and a guanine adduct in the urine of chlorobenzene-treated rats after phenobarbital pretreatment. Toxicology 59(1):67–79. 10.1016/0300-483x(89)90157-1.2815098
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Krost KJ, Pellizzari ED, Walburn SG, 2002. Collection and analysis of hazardous organic emissions. Anal Chem 54(4):810–817. 10.1021/ac00241a050.
Kumagai S, Matsunaga I. 1994. Concentrations of urinary metabolites in workers exposed to monochlorobenzene and variation in the concentration during a workshift. Occup Environ Med 51(2):120–124. 10.1136/oem.51.2.120.8111459
Kumagai S, Matsunaga I. 1995. Effect of variation of exposure to airborne chlorobenzene on internal exposure and concentration of urinary metabolites. Occup Environ Med 52(1):65–70. 10.1136/oem.52.1.65.7697144
Kusters E, Lauwerys R. 1990. Biological monitoring of exposure to chlorobenzene. Int Arch Occup Environ Health 62(4):329–331. 10.1136/oem.52.9.611.2379965
Lee S, Pardue JH, Moe WM, 2009. Effect of sorption and desorption-resistance on biodegradation of chlorobenzene in two wetland soils. J Hazard Mater 161(1):492–498. 10.1016/j.jhazmat.2008.03.129.18486334
Lehmann I, Röder-Stolinski C, Nieber K, 2008. In vitro models for the assessment of inflammatory and immuno-modulatory effects of the volatile organic compound chlorobenzene. Exp Toxicol Pathol 60(2–3):185–193. 10.1016/j.etp.2008.01.009.18514500
Leonardos G, Kendall D, Barnard N. 1969. Odor threshold determinations of 53 odorant chemicals. J Air Pollut Control Assoc 19(2):91–95. 10.1080/00022470.1969.10466465.
Lindsay Smith JR, Shaw BAJ, Foulkes DM. 1972. Mechanisms of mammalian hydroxylation: Some novel metabolites of chlorobenzene. Xenobiotica 2(3):215–226. 10.3109/00498257209111052.5076568
Loveday KS, Lugo MH, Resnick MA, 1989. Chromosome aberration and sister chromatid exchange tests in Chinese hamster ovary cells in vitro: II. Results with 20 chemicals. Environ Mol Mutagen 13(1):60–94. 10.1002/em.2850130108.2642806
Masunaga S, Susarla S, Yonezawa Y. 1996. Dechlorination of chlorobenzenes in anaerobic estuarine sediment. Water Sci Technol 33(6) 10.1016/0273-1223(96)00290-9.
McGregor DB, Brown A, Cattanach P, 1988. Responses of the L5178Y tk+/tk- mouse lymphoma cell forward mutation assay: III. 72 coded chemicals. Environ Mol Mutagen 12(1):85–154. 10.1002/em.2860120111.3383842
Miles Inc. 1984. Study for skin-sensitizing effect on guinea pigs of monochlorobenzene, with cover letter dated 05/09/94. Miles Incorporated. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557415. 86940001006. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557415.xhtml. May 28, 2020.
Mohamed MF, Kang D, Aneja VP. 2002. Volatile organic compounds in some urban locations in United States. Chemosphere 47(8):863–882. 10.1016/s0045-6535(02)00107-8.12079081
Mohtashamipur E, Triebel R, Straeter H, 1987. The bone marrow clastogenicity of eight halogenated benzenes in male NMRI mice. Mutagenesis 2(2):111–113. 10.1093/mutage/2.2.111.3331700
Monsanto Co. 1967a. 13-Week oral administration- dogs. Monochlorobenzene final report. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0200587. 877800212. 8DHQ10780212.
Monsanto Co. 1967b. Three-month subacute oral study - Rats monochlorobenzene. Final report. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0200587. 877800212. 8DHQ10780212.
Monsanto Co. 1976a. Mutagenicity evaluation of BIO-76-87 CP-5535 (LOX): Report/mutagenicity evaluation of chlorobenzene with cover letter dated 05/09/94. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557065. 86940000655. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557065.xhtml. May 28, 2020.
Monsanto Co. 1976b. Mutagenicity evaluation of BIO-76-88 CP-5535 (WGK): Final report/mutagenicity evaluation of chlorobenzene with cover letter dated 05/09/94. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557064. 86940000654. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557064.xhtml. May 28, 2020.
Monsanto Co. 1976c. Mutagenicity evaluation of BIO-76-88 CP-5535 (LOX): Final report/mutagenicity evaluation of chlorobenzene with cover letter dated 05/09/94. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557063. 86940000653. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557063.xhtml. May 28, 2020.
Monsanto Co. 1977. Teratogenic study with monochlorobenzene in albino rats with cover letter dated 05/09/94. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557066. 86940000656. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557066.xhtml. May 28, 2020.
Monsanto Co. 1980. Subchronic inhalation toxicity study of monochlorobenzene to male and female dogs (Study #ML-79-025 with cover letter dated 05/09/94. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557071. 86940000661. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557071.xhtml. May 28, 2020.
Nair R, Barter JA, Schroeder RE, 1987. A two-generation reproduction study with monochlorobenzene vapor in rats. Fundam Appl Toxicol 9(4):678–686. 10.1016/0272-0590(87)90174-6.3692024
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council. 15–35. https://www.ncbi.nlm.nih.gov/books/NBK218924/. May 28, 2020.
Nedelcheva V, Gut I, Souček P, 1998. Cytochrome P450 catalyzed oxidation of monochlorobenzene, 1,2- and 1,4-dichlorobenzene in rat, mouse, and human liver microsomes. Chem Biol Interact 115(1):53–70. 10.1016/s0009-2797(98)00058-1.9817075
NEMI. 2019. Chlorobenzene. National Environment Methods Index. https://www.nemi.gov/methods/analyte_results/?media_name=&source=&instrumentation=&analyte_code=108-90-7&category=. March 11, 2019.
Nestler H, Kiesel B, Kaschabek SR, 2007. Biodegradation of chlorobenzene under hypoxic and mixed hypoxic-denitrifying conditions. Biodegradation 18(6):755–767. 10.1007/s10532-007-9104-z.17279449
Nijenhuis I, Stelzer N, Kästner M, 2007. Sensitive detection of anaerobic monochlorobenzene degradation using stable isotope tracers. Environ Sci Technol 41(11):3836–3842. 10.1021/es0621896.17612157
NIOSH. 1977. Toxic evaluation of inhaled chlorobenzene (monochlorobenzene). Cincinnati, OH: National Institute for Occupational Safety and Health. PB276623. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB276623.xhtml. May 28, 2020.
NIOSH. 1981. Extent-of-exposure survey of monochlorobenzene. Cincinnati, OH: National Institute for Occupational Safety and Health. PB183963. https://www.cdc.gov/niosh/docs/81-105/pdfs/81-105.pdf?id=10.26616/NIOSHPUB81105. May 28, 2020.
NIOSH. 1994. Chlorobenzene. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/108907.html. November 7, 2017.
NIOSH. 2015. Chlorobenzene. International chemical safety cards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/ipcsneng/neng0642.html. February 7, 2018.
NIOSH. 2018a. NIOSH pocket guide to chemical hazards: Chlorobenzene (108-90-7). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgdcas.html. May 22, 2020.
NIOSH. 2018b. Appendix D: Substances with no established RELs. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/nengapdxd.html. May 27, 2020.
NIOSH. 2019. Chlorobenzene. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0121.html. May 26, 2020.
Nishino SF, Spain JC, Pettigrew CA. 1994. Biodegradation of chlorobenzene by indigenous bacteria. Environ Toxicol Chem 13(6):871–877. 10.1002/etc.5620130605.
NLM. 2020. PubChem: Chlorobenzene. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/7964. May 28, 2020.
Nowak J, Kirsch NH, Hegemann W, 1996. Total reductive dechlorination of chlorobenzenes to benzene by a methanogenic mixed culture enriched from Saale river sediment. Appl Microbiol Biotechnol 45(5):700–709. 10.1007/s002530050751 (http://doi.org/10.1007/s002530050751).
NTP. 1985. Toxicology and carcinogenesis studies of chlorobenzene (CAS No. 108-90-70) in F344/N rats and B6C3F mice (gavage studies). Research Triangle Park, NC: National Toxicology Program. TR261. NIH Publication No. 86-2517. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr261.pdf. May 27, 2020.
NTP. 2016. Report on carcinogens, Fourteenth edition. CASRN Index in MS Excel. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. March 1, 2017.
Oesch F, Jerina DM, Daly JW, 1973. Induction, activation and inhibition of epoxide hydrase: an anomalous prevention of chlorobenzene-induced hepatotoxicity by an inhibitor of epoxide hydrase. Chem Biol Interact 6(3):189–202. 10.1016/0009-2797(73)90071-9.4632460
Ogata M, Shimada Y. 1983. Differences in urinary monochlorobenzene metabolites between rats and humans. Int Arch Occup Environ Health 53(1):51–57. 10.1007/bf00406177.6654502
Ogata M, Taguchi T, Hirota N, 1991. Quantitation of urinary chlorobenzene metabolites by HPLC: Concentrations of 4-chlorocatechol and chlorophenols in urine and of chlorobenzene in biological specimens of subjects exposed to chlorobenzene. Int Arch Occup Environ Health 63(2):121–128. 10.1007/bf00379075.1889881
OSHA. 2019a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. October 25, 2019.
OSHA. 2019b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. October 25, 2019.
OSHA. 2019c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. October 25, 2019.
Parke DV, Williams RT. 1953. Studies in detoxication. XLIX. The metabolism of benzene containing (14C1) benzene. Biochem J 54(2):231–238. 10.1042/bj0540231.13058864
Prasad I. 1970. Mutagenic effects of the herbicide 3′,4′-dichloropropionanilide and its degradation products. Can J Microbiol 16(5):369–372. 10.1139/m70-064.5419803
Ramanand K, Balba MT, Duffy J. 1993. Reductive dehalogenation of chlorinated benzenes and toluenes under methanogenic conditions. Appl Environ Microbiol 59(10):3266–3272.8250553
Reich H. 1934. [Puran (monochlorobenzene) poisoning in a 2-year-old child]. Samml Vergiftungsfaellen 5:193–1934. (German)
RePORTER. 2020. Chlorobenzene. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. May 26, 2020.
Reygagne A, Garnier R, Babany G, 1992. [Cytolytic hepatitis following ingestion of monochlorobenzene. Two cases]. J Toxicol Clin Exp 12(4–5):213–216. (French)1295972
Röder-Stolinski C, Fischäder G, Oostingh GJ, 2008. Chlorobenzene induces the NF-κB and p38 MAP Kinase pathways in lung epithelial cells. Inhal Toxicol 20(9):813–820. 10.1080/08958370802020810.18645721
Rozenbaum ND, Blekh RS, Kremneva SN. 1947. [Use of chlorobenzene as a solvent from the standpoint of industrial hygiene]. Gig Sanit 12:21–24. (Russian)
Sax NI, Lewis RJ. 1987. Chlorobenzene. In: Hawley’s condensed chemical dictionary. 11th ed. New York, NY: Van Nostrand Reinhold Company, 253, 596.
Schaum J, Schuda L, Wu C, 2003. A national survey of persistent, bioaccumulative, and toxic (PBT) pollutants in the United States milk supply. J Expo Sci Environ Epidemiol 13(3):177–186. 10.1038/sj.jea.7500269.
Sharer M, Park J, Voice TC, 2003. Aging effects on the sorption - desorption characteristics of anthropogenic organic compounds in soil. Journal of Environment Quality 32(4):1385. 10.2134/jeq2003.1385.
Shelby MD, Witt KL. 1995. Comparison of results from mouse bone marrow chromosome aberration and micronucleus tests. Environ Mol Mutagen 25(4):302–313. 10.1002/em.2850250407.7607185
Shelby MD, Erexson GL, Hook GJ, 1993. Evaluation of a three-exposure mouse bone marrow micronucleus protocol: Results with 49 chemicals. Environ Mol Mutagen 21(2):160–179. 10.1002/em.2850210210.8444144
Sheldon LS, Hites RA. 1978. Organic compounds in the Delaware River. Environ Sci Technol 12(10):1188–1194. 10.1021/es60146a006.
Shell Oil Co. 1991. Initial submission: A Utah biomedical test laboratory report on NIOSH sponsored inhalation study for IDHL values (Final report) with cover letter dated 012291. Shell Oil Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0534605. 88920000156. 8EHQ11811509. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0534605.xhtml. May 28, 2020.
Shimada Y. 1981. [Studies on monochlorobenzene poisoning. Part 1. Quantitative determination of urinary metabolites (p-chloro phenylmercapturic acid and conjugates of 4-chlorocatechol) of monochlorobenzene by high-performance liquid chromatography]. Okayama Igakkai Zasshi 93(5–6):549–554. 10.4044/joma1947.93.5-6_549. (Japanese)
Shimada Y. 1988. [Studies on monochlorobenzene poisoning. Part II. Distribution of monochlorobenzene among the organs of mice]. Okayama Igakkai Zasshi 100(1–2):135–146. (Japanese)
Shimada T, McQueen CA, Williams GM. 1983. Study of effects on cultured liver cells of three chlorinated benzenes/liver-cell mutagenicity studies with chlorobenzene with cover letter dated 05/09/94. Monsanto Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557069. 86940000659. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557069.xhtml. May 28, 2020.
Shimizu M, Yasui Y, Matsumoto N. 1983. Structural specificity of aromatic compounds with special reference to mutagenic activity in Salmonella typhimurium- a series of chloro- or fluoro-nitrobenzene derivatives. Mutat Res 116:217–238. 10.1016/0165-1218(83)90060-5.6339893
Siddiqui MF, Ahmad R, Amad W, 2006. Micronuclei induction and chromosomal aberrations in Rattus norvegicus by chloroacetic acid and chlorobenzenes. Ecotoxicol Environ Saf 65(2):159–164. 10.1016/j.ecoenv.2006.03.002.16647117
Spencer B, Williams RT. 1950. The metabolism of halogenobenzenes. Isolation of a dihydrodihydroxychlorobenzene and other metabolites from chlorobenzene urine. Biochem J 2:15–16.15424202
SRI. 1985. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International. 489.
SRI. 1986. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International. 549.
SRI. 1987. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International. 532–533.
SRI. 1988. Directory of chemical producers: United States of America. Menlo Park, CA: SRI International. 526.
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4(2):131–142. 10.1002/etc.5620040202.
Sullivan TM, Born CS, Carlson GP, 1983. The pharmacokinetics of inhaled chlorobenzene in the rat. Toxicol Appl Pharmacol 71(2):194–203. 10.1016/0041-008x(83)90336-8.6636184
Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. Water Pollut Control 53:1503–1518.
Thrall KD, Woodstock AD, Kania MR. 2004. Development of a physiologically based pharmacokinetic model for chlorobenzene in F-344 rats. J Toxicol Environ Health 67(7):525–536. 10.1080/15287390490425731.
TRI18. 2020. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. May 21, 2020.
USGS. 2006. The quality of our nation’s waters-volatile organic compounds in the nation’s ground water and drinking-water supply wells. Reston, VA: U.S. Geological Survey. Circular 1292. https://pubs.usgs.gov/circ/circ1292/pdf/circular1292.pdf. July 21, 2020.
USITC. 1988. Synthetic organic chemicals: United States production and sales, 1987. Washington, DC: U.S. International Trade Commission. USITC Publication 2118.
Vaghef H, Hellman B. 1995. Demonstration of chlorobenzene-induced DNA damage in mouse lymphocytes using the single cell gel electrophoresis assay. Toxicology 96(1):19–28. 10.1016/0300-483x(94)02910-m.7863508
van der Meer JR, Werlen C, Nishino SF, 1998. Evolution of a pathway for chlorobenzene metabolism leads to natural attenuation in contaminated groundwater. Appl Environ Microbiol 64(11):4185–4193. 10.1128/AEM.64.11.4185-4193.1998.9797264
Van Wijk D, Thompson RS, De Rooij C, 2004. Monochlorobenzene marine risk assessment with special reference to the Osparcom Region: North Sea. Environ Monit Assess 97(1–3):69–86. 10.1023/B:EMAS.0000033042.01768.3f.15376380
Verschueren K. 1983. Chlorobenzene. In: Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Company, 356–359, 712–717.
Von Burg H. 1981. Toxicology updates - chlorobenzene. J Appl Toxicol 1(1):50–51.
Weast RC. 1985. Chlorobenzene. In: CRC handbook of chemistry and physics. Boca Raton, FL: CRC Press, Inc., C-109, C-114.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Willhite CC, Book SA. 1990. Toxicology update. Chlorobenzene. J Appl Toxicol 10(4):307–310. 10.1002/jat.2550100414.2202755
Wolska L, Konieczka P, Jastrzebska A, 2003. Analytical procedure for the determination of chlorobenzenes in sediments. J Chromatogr Sci 41(2):53–56. 10.1093/chromsci/41.2.53.12639250
WQP. 2020. Chlorobenzene. Water quality portal. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/#characteristicName=Chlorobenzene&mimeType=csv. May 28, 2020.
Yoshida M, Sunaga M, Hara I. 1986. Urinary metabolite levels in workers exposed to chlorobenzene. Ind Health 24:255–258. 10.2486/indhealth.24.255.3818367
Zeneca Specialties. 1982. Eye irritation classification on monochlorobenzene in rabbits with cover letter dated 05/06/94. Zeneca Specialties. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557374. 86940000964. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557374.xhtml. May 28, 2020.
Zub M. 1978. Reactivity of the white blood cell system to toxic action of benzene and its derivatives. Acta Biol Crac 21:163–174.