# VERSION HISTORY

Date | Description
October 2020 | Final toxicological profile released
December 2019 | Draft for public comment profile released
August 2013 | Addendum to the toxicological profile released
December 1990 | Final toxicological profile released