# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding chlorobenzene in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by referring to the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for chlorobenzene.

Table 7-1 Regulations and Guidelines Applicable to Chlorobenzene

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated | IRIS 2003
EPA | Provisional Peer Reviewed Toxicity Value | | EPA 2006
EPA | Provisional chronic RfC | 5×10^−2^ mg/m^3^ (0.01 ppm)
EPA | Provisional subchronic RfC | 5×10^−1^ mg/m^3^ (0.1 ppm)
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018b
EPA | 1-Day health advisory (10-kg child) | 4 mg/L
EPA | 10-Day health advisory (10-kg child) | 4 mg/L
EPA | DWEL | 0.7 mg/L
EPA | Lifetime health advisory | 0.1 mg/L
EPA | 10^−4^ Cancer risk | No data
EPA | National primary drinking water regulations | | EPA 2009
EPA | MCL | 0.1 mg/L
EPA | PHG | 0.1 mg/L
EPA | RfD | 2×10^−2^ mg/kg/day | EPA 2018b; IRIS 2003
EPA | Provisional Peer Reviewed Toxicity Value | | EPA 2006
EPA | Provisional subchronic RfD | 7×10^−2^ mg/kg/day
WHO | Drinking water quality guidelines | Guideline value not established | WHO 2017
FDA | Substances Added to Food^a^ | Not listed | FDA 2020
FDA | Allowable level in bottled water | 0.1 mg/L | FDA 2017
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | D^b^ | IRIS 2003
IARC | Carcinogenicity classification | No data | IARC 2020
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction | 75 ppm (350 mg/m^3^) | OSHA 2019a, 2019b, 2019c
NIOSH | REL (up to 10-hour TWA) | No data^c^ | NIOSH 2019
NIOSH | IDLH | 1,000 ppm | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | | EPA 2018c
EPA | AEGL 1^d^
EPA | 10-minute | 10 ppm
EPA | 30-minute | 10 ppm
EPA | 60-minute | 10 ppm
EPA | 4-hour | 10 ppm
EPA | 8-hour | 10 ppm
EPA | AEGL 2^d^
EPA | 10-minute | 430 ppm
EPA | 30-minute | 300 ppm
EPA | 60-minute | 150 ppm
EPA | 4-hour | 150 ppm
EPA | 8-hour | 150 ppm
EPA | AEGL 3^d^
EPA | 10-minute | 1,100 ppm
EPA | 30-minute | 800 ppm
EPA | 60-minute | 400 ppm
EPA | 4-hour | 400 ppm
EPA | 8-hour | 400 ppm
DOE | PACs-air | | DOE 2018a
DOE | PAC-1^e^ | 10 ppm
DOE | PAC-2^e^ | 150 ppm
DOE | PAC-3^e^ | 400 ppm

b The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b Group D: not classifiable as to human carcinogenicity.

c After reviewing available published literature, NIOSH provided comments to OSHA on August 1, 1988, regarding the “Proposed Rule on Air Contaminants” (29 CFR 1910, Docket No. H-020). In these comments, NIOSH questioned whether proposed PELs for certain chemicals including chlorobenzene (TWA 75 ppm) were adequate to protect workers from recognized health hazards (NIOSH 2018b).

d Definitions of AEGL terminology are available from U.S. Environmental Protection Agency (EPA 2018d).

e Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; CFR = Code of Federal Regulations; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health concentrations; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; PHG = public health goal; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization