# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of chlorobenzene are listed in Table 4-1.

Table 4-1 Chemical Identity of Chlorobenzene

Characteristic | Information | Reference
Chemical name | Chlorobenzene | NLM 2020
Synonym(s) and registered trade name(s) | Monochlorobenzene; Benzene chloride; Phenylchloride; MCB; Chlorobenzol; Caswell no. 183A | NLM 2020
Chemical formula | C_6_H_5_Cl | NLM 2020
Chemical structure | [image] | NLM 2020
CAS Registry Number | 108-90-7 | NLM 2020

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The odor threshold for chlorobenzene in humans has been reported to be as low as 0.21 ppm or 0.97 mg/m^3^ (Leonardos et al. 1969). However, others have reported its “almond-like odor” to be “barely perceptible” at 60 ppm (Von Burg 1981; Willhite and Book 1990). The physical and chemical properties of chlorobenzene are presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of Chlorobenzene

Property | Information | Reference
Molecular weight | 112.56 | Weast 1985
Color | Colorless | Verschueren 1983
Physical state | Liquid | Verschueren 1983
Melting point | −45.6°C | Weast 1985
Boiling point | 132°C | Weast 1985
Density at 20°C | 1.1058 | Weast 1985
Odor | Aromatic, almond-like | Sax and Lewis 1987
Odor threshold: | Conflicting data | Leonardos et al. 1969
Water | 0.050 mg/L | Verschueren 1983
Air | 1–8 mg/m^3^ | Verschueren 1983
Solubility:
Water at 20°C | 500 mg/L | Verschueren 1983
Organic solvents | Soluble in alcohol, ether, benzene | Weast 1985
Partition coefficients:
Log K_ow_ | 2.84 | Verschueren 1983
Log K_oc_ | 2.52 | EPA 1982
Vapor pressure at 20°C | 8.8 mmHg | Verschueren 1983
Henry’s law constant at 25°C | 3.58×10^−3^ atm-m^3^/mol | EPA 1982
Autoignition temperature | 637°C | Sax and Lewis 1987
Flashpoint | 29.4°C | Sax and Lewis 1987
Flammability limits | 1.8–9.6% | Sax and Lewis 1987
Conversion factors | 1 ppm=4.7 mg/m^3^; 1 mg/m^3^=0.22 ppm | Verschueren 1983
Explosive limits | 1.3-11 vol% in air) | NIOSH 2015